# EXCLUDED STUDIES

1 Chip developed to diagnose oral cancer in ten minutes. Br Dent J. Aug. 28. 2010;209(4):155. Not one of the specified study designs. [pmid: 20798709].
2 High-tech oral cancer detection. Less invasive, less painful microchip technology could identify mouth cancers in the very early stages. Duke Med Health News. Nov. 2010;16(11):4-5. Not one of the specified study designs. [pmid: 21186497].
3 Screening for oral cancer. Med Lett Drugs Ther. Feb. 23. 2009;51(1306):15-16. Not one of the specified study designs. [pmid: 19229163].
4 Ahmed HG, Ebnoof SO, Hussein MO, et al. Oral epithelial atypical changes in apparently healthy oral mucosa exposed to smoking, alcohol, peppers and hot meals, using the AgNOR and Papanicolaou staining techniques. Diagn Cytopathol. Jul. 2010;38(7):489-95. No relevant outcomes. [pmid: 19894260].
5 Al-Tarawneh SK, Border MB, Dibble CF, et al. Defining salivary biomarkers using mass spectrometry-based proteomics: a systematic review. OMICS. Jun. 2011;15(6):353-61. Intervention does not involve screening. [pmid: 21568728].
6 Balevi B. Assessing the usefulness of three adjunctive diagnostic devices for oral cancer screening: a probabilistic approach. Community Dent Oral Epidemiol. Apr. 2011;39(2):171-76. Not one of the specified study designs. [pmid: 21029147].
7 Baykul T, Yilmaz HH, Aydin U, et al. Early diagnosis of oral cancer. J Int Med Res. May. 2010;38(3):737-49. Not one of the specified study designs. [pmid: 20819411].
8 Bhalang K, Suesuwan A, Dhanuthai K, et al. The application of acetic acid in the detection of oral squamous cell carcinoma. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Sep. 2008;106(3):371-76. Wrong population. [pmid: 18547833].
9 Bhoopathi V, Mascarenhas AK. Effectiveness of oral surgeons compared with OralCDx brush biopsy in diagnosing oral dysplastic lesions. J Oral Maxillofac Surg. Feb. 2011;69(2):428-31. Wrong population. [pmid: 21122966].
10 Bocking A, Sproll C, Stocklein N, et al. Role of brush biopsy and DNA cytometry for prevention, diagnosis, therapy, and followup care of oral cancer. J Oncol. 2011;2011:875959. Not one of the specified study designs. [pmid: 21209723].
11 Brocklehurst P, Kujan O, Glenny AM, et al. Screening programmes for the early detection and prevention of oral cancer. Cochrane Database Syst Rev. 2010;11:CD004150. Did not provide primary data. [pmid: 21069680].
12 Brocklehurst PR, Baker SR, Speight PM. Oral cancer screening: what have we learnt and what is there still to achieve?. Future Oncol. Feb. 2010;6(2):299-304. Not one of the specified study designs. [pmid: 20146588].
13 Brocklehurst PR, Baker SR, Speight PM. Primary care clinicians and the detection and referral of potentially malignant disorders in the mouth: a summary of the current evidence. Prim Dent Care. Apr. 2010;17(2):65-71. Not one of the specified study designs. [pmid: 20353654].
14 Chaturvedi P, Majumder SK, Krishna H, et al. Fluorescence spectroscopy for noninvasive early diagnosis of oral mucosal malignant and potentially malignant lesions. J Canc Res Ther. Oct. 2010;6(4):497-502. Not an appropriate setting. [pmid: 21358088].
15 Chen CH, Chen RJ. Prevalence of telomerase activity in human cancer. J Formos Med Assoc. May. 2011;110(5):275-89. Not one of the specified study designs. [pmid: 21621148].
16 Choi CW, Lee MC, Ng WT, et al. An analysis of the efficacy of serial screening for familial nasopharyngeal carcinoma based on Markov chain models. Fam Cancer. Mar. 2011;10(1):133-39. Not one of the specified study designs. [pmid: 21052850].
17 DeCoro M, Wilder-Smith P. Potential of optical coherence tomography for early diagnosis of oral malignancies. Expert Rev Anticancer Ther. Mar. 2010;10(3):321-29. Not one of the specified study designs. [pmid: 20214513].
18 Delavarian Z, Mohtasham N, Mosannen-Mozafari P, et al. Evaluation of the diagnostic value of a Modified Liquid-Based Cytology using OralCDx Brush in early detection of oral potentially malignant lesions and oral cancer. Med Oral Patol Oral Cir Bucal. 2010;15(5):e671-e676. Wrong population. [pmid: 20383114].
19 Demko CA, Sawyer D, Slivka M, et al. Prevalence of oral lesions in the dental office. Gen Dent. Sep. 2009;57(5):504-09. Quality issues. [pmid: 19903642].
20 Downer MC, Moles DR, Palmer S, et al. A systematic review of test performance in screening for oral cancer and precancer. Oral Oncol. Mar. 2004;40(3):264-73. Did not provide primary data. [pmid: 14747057].
21 Epstein JB, Silverman S Jr, Epstein JD, et al. Analysis of oral lesion biopsies identified and evaluated by visual examination, chemiluminescence and toluidine blue. Oral Oncol. Jun. 2008;44(6):538-44. Wrong population. [pmid: 17996486].
22 Epstein JB, Villines D, Drahos G, et al. Oral lesions in patients participating in an oral examination screening week at an urban dental school. J Am Dent Assoc. Oct. 2008;139(10):1338-44. Not one of the specified study designs. [pmid: 18832269].
23 Epstein JB, Gorsky M, Cabay RJ, et al. Screening for and diagnosis of oral premalignant lesions and oropharyngeal squamous cell carcinoma: role of primary care physicians. Can Fam Physician. Jun. 2008;54(6):870-75. Not one of the specified study designs. [pmid: 18556495].
24 Epstein JB, Guneri P. The adjunctive role of toluidine blue in detection of oral premalignant and malignant lesions. Curr Opin Otolaryngol Head Neck Surg. Apr. 2009;17(2):79-87. Quality issues. [pmid: 19374030].
25 Fedele S. Diagnostic aids in the screening of oral cancer. Head Neck Oncol. 2009;1:5. Not one of the specified study designs. [pmid: 19284694].
26 Guneri P, Epstein JB, Kaya A, et al. The utility of toluidine blue staining and brush cytology as adjuncts in clinical examination of suspicious oral mucosal lesions. Int J Oral Maxillofac Surg. Feb. 2011;40(2):155-61. Wrong population. [pmid: 21112183].
27 Gurenlian JR. Diagnostic devices for detecting oral cancer. J Dent Hyg. 2009;83(4):177-78. Not one of the specified study designs. [pmid: 19909635].
28 Hakama M, Coleman MP, Alexe DM, et al. Cancer screening: evidence and practice in Europe 2008. Eur J Cancer. Jul. 2008;44(10):1404-13. Not one of the specified study designs. [pmid: 18343653].
29 Haxel BR, Goetz M, Kiesslich R, et al. Confocal endomicroscopy: a novel application for imaging of oral and oropharyngeal mucosa in human. Eur Arch Otorhinolaryngol. Mar. 2010;267(3):443-48. Quality issues. [pmid: 19590883].
30 Hoffmann RR, Yurgel LS, Campos MM. Endothelins and their receptors as biological markers for oral cancer. Oral Oncol. Sep. 2010;46(9):644-47. Not one of the specified study designs. [pmid: 20656542].
31 Huber MA. Assessment of the VELscope as an adjunctive examination tool. Tex Dent J. Jun. 2009;126(6):528-35. Quality issues. [pmid: 19639920].
32 Huff K, Stark PC, Solomon LW. Sensitivity of direct tissue fluorescence visualization in screening for oral premalignant lesions in general practice. Gen Dent. Jan. 2009;57(1):34-38. Quality issues. [pmid: 19146141].
33 Huff KD. Cancer screening. J Am Dent Assoc. 2008;139(10):1304. Not one of the specified study designs. [pmid: 18832263].
34 Huff KD. Photography: an integral component of oral cancer screening. Dent Today. Sep. 2009;28(9):100. Not one of the specified study designs. [pmid: 19771969].
35 Kanatas A, McCaul JA. Re: use of Lugol's iodine in oral cancer diagnosis: an overview. Oral Oncol. Nov. 2010;46(11):835. Not one of the specified study designs. [pmid: 20947412].
36 Kao SY, Chu YW, Chen YW, et al. Detection and screening of oral cancer and pre-cancerous lesions. J Chin Med Assoc. May. 2009;72(5):227-33. Not one of the specified study designs. [pmid: 19467945].
37 Katz P, Hartl DM, Guerre A. Clinical ultrasound of the salivary glands. Otolaryngol Clin North Am. 2009;42(6):973-1000. Not one of the specified study designs. [pmid: 19962004].
38 Kelloff GJ, Sigman CC, Contag CH. Early detection of oral neoplasia: watching with new eyes. Cancer Prev Res. May. 2009;2(5):405-08. Not one of the specified study designs. [pmid: 19401527].
39 Kujan O, Glenny AM, Oliver RJ, et al. Screening programmes for the early detection and prevention of oral cancer. Cochrane Database Syst Rev. 2006;3:CD004150. Did not provide primary data. [pmid: 16856035].
40 Le A, Messadi D, Epstein J, et al. Toward multimodality oral cancer diagnosis in the XXI century: Blending cutting edge imaging and genomic/proteomic definition of suspicious lesions. Bioinformation. 2010;5(7):304-06. Not one of the specified study designs. [pmid: 21364840].
41 Li S, Deng Y, Li X, et al. Diagnostic value of Epstein-Barr virus capsid antigen-IgA in nasopharyngeal carcinoma: a meta-analysis. Chin Med J (Engl). May. 5. 2010;123(9):1201-05. Wrong population. [pmid: 20529563].
42 Lingen MW, Kalmar JR, Karrison T, et al. Critical evaluation of diagnostic aids for the detection of oral cancer. Oral Oncol. Jan. 2008;44(1):10-22. Not one of the specified study designs. [pmid: 17825602].
43 Lingen MW, Pinto A, Mendes RA, et al. Genetics/epigenetics of oral premalignancy: current status and future research. Oral Dis. Apr. 2011;17. 22. Intervention does not involve screening. [pmid: 21382136].
44 Lopez-Jornet P, De la Mano-Espinosa T. The efficacy of direct tissue fluorescence visualization in screening for oral premalignant lesions in general practice: an update. Int J Dent Hyg. May. 2011;9(2):97-100. Quality issues. [pmid: 21356007].
45 McIntosh L, McCullough MJ, Farah CS. The assessment of diffused light illumination and acetic acid rinse (Microlux/DL) in the visualisation of oral mucosal lesions. Oral Oncol. Dec. 2009;45(12):e227-e231. Wrong population. [pmid: 19800285].
46 Mehrotra R, Singh M, Thomas S, et al. A cross-sectional study evaluating chemiluminescence and autofluorescence in the detection of clinically innocuous precancerous and cancerous oral lesions. J Am Dent Assoc. Feb. 2010;141(2):151-56. Wrong population. [pmid: 20123872].
47 Mehrotra R, Hullmann M, Smeets R, et al. Oral cytology revisited. J Oral Pathol Med. Feb. 2009;38(2):161-66. Quality issues. [pmid: 19213102].
48 Messadi DV, Wilder-Smith P, Wolinsky L. Improving oral cancer survival: the role of dental providers. CDA J. Nov. 2009;37(11):789-98. Not one of the specified study designs. [pmid: 19998655].
49 Moro A, Di NF, Boniello R, et al. Autofluorescence and early detection of mucosal lesions in patients at risk for oral cancer. J Craniofac Surg. Nov. 2010;21(6):1899-903. Not one of the specified study designs. [pmid: 21119451].
50 Murrah VA. Dentistry and the prevention, diagnosis, and treatment of oral cancer in North Carolina. N C Med J. Jul. 2008;69(4):313-15. Not one of the specified study designs. [pmid: 18828326].
51 Nagler RM. Saliva as a tool for oral cancer diagnosis and prognosis. Oral Oncol. Dec. 2009;45(12):1006-10. Not one of the specified study designs. [pmid: 19828359].
52 Naugler C. Practice tips. Brush biopsy sampling of oral lesions. Can Fam Physician. Feb. 2008;54(2):194. Not one of the specified study designs. [pmid: 18272633].
53 Navone R, Pentenero M, Gandolfo S. Liquid-based cytology in oral cavity squamous cell cancer. Curr Opin Otolaryngol Head Ne. Apr. 2011;19(2):77-81. Not one of the specified study designs. [pmid: 21252668].
54 Nieman LT, Kan CW, Gillenwater A, et al. Probing local tissue changes in the oral cavity for early detection of cancer using oblique polarized reflectance spectroscopy: a pilot clinical trial. J Biomed Opt. Mar. 2008;13(2). 024011-Apr. Wrong population. [pmid: 18465974].
55 Palmer O, Grannum R. Oral cancer detection. Dent Clin North Am. Jul. 2011;55(3):537-48. Not one of the specified study designs. [pmid: 21726688].
56 Patton LL, Epstein JB, Kerr AR. Adjunctive techniques for oral cancer examination and lesion diagnosis: a systematic review of the literature. J Am Dent Assoc. 2008;139(7):896-905. Did not provide primary data. [pmid: 18594075].
57 Perrone F, Gloghini A, Cortelazzi B, et al. Isolating p16-positive/HPV-negative oropharyngeal cancer: an effort worth making. Am J Surg Pathol. 2011;35(5):774-77. Wrong population. [pmid: 21436677].
58 Petruzzi M, Lucchese A, Baldoni E, et al. Use of Lugol's iodine in oral cancer diagnosis: an overview. Oral Oncol. Nov. 2010;46(11):811-13. Intervention does not involve screening. [pmid: 20729139].
59 Pfaffe T, Cooper-White J, Beyerlein P, et al. Diagnostic potential of saliva: current state and future applications. Clin Chem. May. 2011;57(5):675-87. Not one of the specified study designs. [pmid: 21383043].
60 Piazza C, Dessouky O, Peretti G, et al. Narrow-band imaging: a new tool for evaluation of head and neck squamous cell carcinomas. Review of the literature. Acta Otorhinolaryngol Ital. Apr. 2008;28(2):49-54. Not one of the specified study designs. [pmid: 18669067].
61 Rahman M, Chaturvedi P, Gillenwater AM, et al. Low-cost, multimodal, portable screening system for early detection of oral cancer. J Biomed Opt. May. 2008;13(3). 030502-Jun. Not one of the specified study designs. [pmid: 18601519].
62 Rahman MS, Ingole N, Roblyer D, et al. Evaluation of a low-cost, portable imaging system for early detection of oral cancer. Head Neck Oncol. 2010;2:10. Wrong population. [pmid: 20409347].
63 Remmerbach TW, Meyer-Ebrecht D, Aach T, et al. Toward a multimodal cell analysis of brush biopsies for the early detection of oral cancer. Cancer Cytopathol. Jun. 25. 2009;117(3):228-35. Wrong population. [pmid: 19373897].
64 Rethman MP, Carpenter W, Cohen EE, et al. Evidence-based clinical recommendations regarding screening for oral squamous cell carcinomas. J Am Dent Assoc. May. 2010;141(5):509-20. Did not provide primary data. [pmid: 20436098].
65 Rhodus NL. Oral cancer and precancer: improving outcomes. Compend Contin Educ Dent. Oct. 2009;30(8):486-88. Not one of the specified study designs. [pmid: 19824564].
66 Richards D. Clinical recommendations for oral cancer screening. Evid Based Dent. 2010;11(4):101-02. Not one of the specified study designs. [pmid: 21170006].
67 Richards D. Does toluidine blue detect more oral cancer?. Evid Based Dent. 2010;11(4):104-05. Not one of the specified study designs. [pmid: 21170008].
68 Richards D. Oral cancer screening programmes. Evid Based Dent. 2010;11(4):103. Not one of the specified study designs. [pmid: 21170007].
69 Richards D. Seek don't screen for oral cancer. Evid Based Dent. 2010;11(4):98. Not one of the specified study designs. [pmid: 21170004].
70 Richards D. Should we screen for oral cancer?. Evid Based Dent. 2009;10(4):98. Not one of the specified study designs. [pmid: 20023609].
71 Scheer M, Neugebauer J, Derman A, et al. Autofluorescence imaging of potentially malignant mucosa lesions. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. May. 2011;111(5):568-77. Not an appropriate setting. [pmid: 21429774].
72 Scully C, Bagan JV, Hopper C, et al. Oral cancer: current and future diagnostic techniques. Am J Dent. Aug. 2008;21(4):199-209. Not one of the specified study designs. [pmid: 18795514].
73 Seoane LJ, Diz DP. Diagnostic clinical aids in oral cancer. Oral Oncol. Jun. 2010;46(6):418-22. Not one of the specified study designs. [pmid: 20371204].
74 Shin D, Vigneswaran N, Gillenwater A, et al. Advances in fluorescence imaging techniques to detect oral cancer and its precursors. Future Oncol. Jul. 2010;6(7):1143-54. Not one of the specified study designs. [pmid: 20624126].
75 Slater LJ. Comment on “analysis of oral lesion biopsies identified and evaluated by visual examination, chemiluminescence and toluidine blue”. Oral Oncol. Mar. 2009;45(3):296-98. Not one of the specified study designs. [pmid: 19147390].
76 Sok JC, Grandis JR. Genetic screening for oral human papillomavirus infections and cancers of the head and neck. Clin Cancer Res. Nov. 1. 2008;14(21):6723-24. Not one of the specified study designs. [pmid: 18980962].
77 Steele TO, Meyers A. Early detection of premalignant lesions and oral cancer. Otolaryngol Clin North Am. 2010;44(1):221-29. Not one of the specified study designs. [pmid: 21093631].
78 Trullenque-Eriksson A, Munoz-Corcuera M, Campo-Trapero J, et al. Analysis of new diagnostic methods in suspicious lesions of the oral mucosa. Med Oral Patol Oral Cir Bucal. May. 2009;14(5):E210-E216. Quality issues. [pmid: 19218907].
79 Wang TW, Lu HY, Lou PJ, et al. Application of highly sensitive, modified glass substrate-based immuno-PCR on the early detection of nasopharyngeal carcinoma. Biomaterials. Nov. 2008;29(33):4447-54. Intervention does not involve screening. [pmid: 18752845].
80 Warnakulasuriya S, Kashyap R, Dasanayake AP. Is workplace screening for potentially malignant oral disorders feasible in India?. J Oral Pathol Med. Oct. 2010;39(9):672-76. Not one of the specified study designs. [pmid: 20738753].
81 Warnecke A, Averbeck T, Leinung M, et al. Contact endoscopy for the evaluation of the pharyngeal and laryngeal mucosa. Laryngoscope. Feb. 2010;120(2):253-58. Wrong population. [pmid: 19998420].
82 Willis RC. Identifying markers of premalignancy. J Proteome Res. Jan. 2009;8(1):4. Not one of the specified study designs. [pmid: 19072116].
83 Wu JY, Yi C, Chung HR, et al. Potential biomarkers in saliva for oral squamous cell carcinoma. Oral Oncol. Apr. 2010;46(4):226-31. Not one of the specified study designs. [pmid: 20138569].
84 Yao K, Takaki Y, Matsui T, et al. Clinical application of magnification endoscopy and narrow-band imaging in the upper gastrointestinal tract: new imaging techniques for detecting and characterizing gastrointestinal neoplasia. Gastrointest Endosc Clin N Am. Jul. 2008;18(3):415-33. Not one of the specified study designs. [pmid: 18674694].
85 Yokoyama A, Kumagai Y, Yokoyama T, et al. Health risk appraisal models for mass screening for esophageal and pharyngeal cancer: an endoscopic follow-up study of cancer-free Japanese men. Cancer Epidem Biomarker Prev. Feb. 2009;18(2):651-55. Not one of the specified study designs. [pmid: 19190142].
86 Zhou J, Cao J, Lu Z, et al. A 115-bp MethyLight assay for detection of p16 (CDKN2A) methylation as a diagnostic biomarker in human tissues. BMC Med Genet. 2011;12:67. Wrong population. [pmid: 21569495].
87 Zimmermann BG, Wong DT. Salivary mRNA targets for cancer diagnostics. Oral Oncol. May. 2008;44(5):425-29. Not one of the specified study designs. [pmid: 18061522].
88 Ziober BL, Mauk MG, Falls EM, et al. Lab-on-a-chip for oral cancer screening and diagnosis. Head Neck. Jan. 2008;30(1):111-21. Not one of the specified study designs. [pmid: 17902150].