# PRELIMINARY WORK METHODS

In 2008, the USPSTF did some preliminary work to update this topic. The following methods and search strategy describe this work.

## Methods

Oral cancer screening was defined as any test or combination of tests utilized for the purpose of detecting cancer or potentially premalignant lesions (leukoplakia and erythroplakia) within the oral cavity. Studies were excluded in which tests were used to diagnose previously identified lesions or to detect recurrent cancer in patients with a history of oral cancer. The evidence for the effectiveness of adjunctive diagnostic aids has been reviewed elsewhere.12, 18, 19

## Data Sources

For evidence on health outcomes associated with screening for oral cancer, PubMed and the Cochrane Library for English-language articles indexed between January 1, 2001 and October 6, 2008 were searched using combinations of the MeSH terms and key words “mouth neoplasms,” “mass screening,” and “screening.”

For evidence on the yield and accuracy of the screening oral examination, PubMed and the Cochrane Library for English-language articles indexed between 1966 and October 6, 2008 were searched using combinations of the MeSH terms and key words “mouth neoplasms,” “mass screening,” “diagnostic techniques and procedures,” “diagnostic accuracy,” and “sensitivity and specificity.”

Additional articles were identified through recommendations of experts and hand-searching of reference lists from major reviews and studies.