# LITERATURE SEARCH TERMS

Terms pertaining to oral cancer
- mouth neoplasms/
- gingival neoplasms/
- leukoplakia, oral/
- lip neoplasms/
- palatal neoplasms/
- salivary gland neoplasms/
- parotid neoplasms/
- sublingual gland neoplasms/
- submandibular gland neoplasms/
- tongue neoplasms/
- pharyngeal neoplasms/
- hypopharyngeal neoplasms/
- nasopharyngeal neoplasms/
- oropharyngeal neoplasms/
- tonsillar neoplasms/
- ((oral or mouth or lip$ or tongue$ or gingiv$ or oropharyn$ or pharyn$ or palate or cheek$) adj5 (cancer$ or carcinoma$ or neoplas$ or tumor$ or tumour$ or dysplasia$ or malignan$)).ti,ab.

Terms pertaining to screening
- Mass Screening/
- “early detection of cancer”/
- early diagnosis/
- screen$.ti,ab.
- (early adj3 (diagnos$ or detect$)).ti,ab.

Terms pertaining to diagnostic accuracy
- “Sensitivity and Specificity”/
- “Predictive Value of Tests”/
- ROC Curve/
- False Negative Reactions/
- False Positive Reactions/
- Diagnostic Errors/
- “Reproducibility of Results”/
- Reference Values/
- Reference Standards/
- specificit$ti,ab.
- sensitiv$.ti,ab.
- predictive value.ti,ab.
- accurac$.ti,ab.
- miss rate$.ti,ab.
- detection rate$.ti,ab.
- diagnostic yield$.ti,ab.
- likelihood ratio$.ti,ab.
- diagnostic odds ratio$.ti,ab.
- odds ratio/ and di.fs.