# REFERENCES

1 Nelson HD, Huffman LH, Fu R, et al. Genetic Risk Assessment and BRCA Mutation Testing for Breast and Ovarian Cancer Susceptibility. Evidence Synthesis No. 37. Rockville, MD. Agency for Healthcare Research and Quality. 2005. [pmid: 20722133].
2 Nelson HD, Huffman LH, Fu R, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2005;143(5):362-79. [pmid: 16144895].
3 U.S. Preventive Services Task Force. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: recommendation statement. Ann Intern Med. 2005;143(5):355-61. [pmid: 16144894].
4 U.S. Department of Health and Human Services. What Are My Preventive Care Benefits?. Washington, DC. U.S. Department of Health and Human Services. 2013. Accessed at https://www.healthcare.gov/what-are-my-preventive-care-benefits/ on. 25 November 2013.
5 U.S. Department of Health and Human Services. Healthy People 2020. Washington, DC. U.S. Department of Health and Human Services. 2013. Accessed at http://www.healthypeople.gov/2020/topicsobjectives2020/overview.aspx?topicid=15 on. 25 November 2013.
6 Miki Y, Swensen J, Shattuck-Eidens D, et al. A strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994;266(5182):66-71. [pmid: 7545954].
7 Wooster R, Weber BL. Breast and ovarian cancer. N Engl J Med. 2003;348(23):2339-47. [pmid: 12788999].
8 Zweemer R, van Diest P, Verheijen R, et al. Molecular evidence linking primary cancer of the fallopian tube to BRCA1 germline mutations. Gynecol Oncol. 2000;76(1):45-50. [pmid: 10620440].
9 Medeiros F, Muto M, Lee Y, et al. The tubal fimbria is a preferred site for early adenocarcinoma in women with familial ovarian cancer syndrome. Am J Surg Pathol. 2006;30(2):230-6. [pmid: 16434898].
10 Tone A, Begley H, Sharma M, et al. Gene expression profiles of luteal phase fallopian tube epithelium from BRCA mutation carriers resemble high-grade serous carcinoma. Clin Cancer Res. 2008;14(13):4067-78. [pmid: 18593983].
11 Antoniou A, Pharoah P, Narod S, et al. Average risks of breast and ovarian cancer associated with BRCA1 or BRCA2 mutations detected in case series unselected for family history: a combined analysis of 22 studies. Am J Hum Genet. 2003;72(5):1117-30. [pmid: 12677558].
12 Chen S, Parmigiani G. Meta-analysis of BRCA1 and BRCA2 penetrance. J Clin Oncol. 2007;25(11):1329-33. [pmid: 17416853].
13 Anglian Breast Cancer Study Group. Prevalence and penetrance of BRCA1 and BRCA2 mutations in a population-based series of breast cancer cases. Br J Cancer. 2000;83(10):1301-8. [pmid: 11044354].
14 Antoniou AC, Gayther SA, Stratton JF, et al. Risk models for familial ovarian and breast cancer. Genet Epidemiol. 2000;18(2):173-90. [pmid: 10642429].
15 Antoniou AC, Pharoah PD, McMullan G, et al. A comprehensive model for familial breast cancer incorporating BRCA1, BRCA2 and other genes. Br J Cancer. 2002;86(1):76-83. [pmid: 11857015].
16 Peto J, Collins N, Barfoot R, et al. Prevalence of BRCA1 and BRCA2 gene mutations in patients with early-onset breast cancer. J Natl Cancer Inst. 1999;91(11):943-9. [pmid: 10359546].
17 Whittemore AS, Gong G, John EM, et al. Prevalence of BRCA1 mutation carriers among U.S. non-Hispanic whites. Cancer Epidemiol Biomarkers Prev. 2004;13(12):2078-83. [pmid: 15598764].
18 Neuhausen S, Gilewski T, Norton L, et al. Recurrent BRCA2 6174delT mutations in Ashkenazi Jewish women affected by breast cancer. Nat Genet. 1996;13(1):126-8. [pmid: 8673092].
19 Struewing JP, Hartge P, Wacholder S, et al. The risk of cancer associated with specific mutations of BRCA1 and BRCA2 among Ashkenazi Jews. N Engl J Med. 1997;336(20):1401-8. [pmid: 9145676].
20 Roa BB, Boyd AA, Volcik K, et al. Ashkenazi Jewish population frequencies for common mutations in BRCA1 and BRCA2. Nat Genet. 1996;14:185-7. [pmid: 8841191].
21 Weitzel JN, Lagos V, Blazer KR, et al. Prevalence of BRCA mutations and founder effect in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2005;14(7):1666-71. [pmid: 16030099].
22 Weitzel J, Lagos V, Blazer K, et al. Evidence for common ancestral origin of a recurring BRCA1 genomic rearrangement identified in high-risk Hispanic families. Cancer Epidemiol Biomarkers Prev. 2007;16(8):1615-20. [pmid: 17646271].
23 Mefford H, Baumbach L, Panguluri R. Evidence for BRCA1 founder mutation in families of West African ancestry. Am J Hum Genet. 1999;65(2):575-8. [pmid: 10417303].
24 Peelen T, van Vliet M, Petrij-Bosch A, et al. A high proportion of novel mutations in BRCA1 with strong founder effects among Dutch and Belgian hereditary breast and ovarian cancer families. Am J Hum Genet. 1997;60(5):1041-9. [pmid: 9150151].
25 Arason A, Jonasdottir A, Barkardottir RB, et al. A population study of mutations and LOH at breast cancer gene loci in tumours from sister pairs: two recurrent mutations seem to account for all BRCA1/BRCA2 linked breast cancer in Iceland. J Med Genet. 1998;35(6):446-9. [pmid: 9643283].
26 Thorlacius S, Olafsdottir G, Tryggvadottir L, et al. A single BRCA2 mutation in male and female breast cancer families from Iceland with varied cancer phenotypes. Nat Genet. 1996;13(1):117-9. [pmid: 8673089].
27 Einbeigi Z, Bergman A, Kindblom LG, et al. A founder mutation of the BRCA1 gene in Western Sweden associated with a high incidence of breast and ovarian cancer. Eur J Cancer. 2001;37(15):1904-9. [pmid: 11576847].
28 National Cancer Institute. Breast Cancer Treatment (PDQ®). Bethesda, MD. National Cancer Institute. 2013. Accessed at http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional on. 25 November 2013.
29 Lindor NM, Greene MH, Mayo Familial Cancer Program. The concise handbook of family cancer syndromes. J Natl Cancer Inst. 1998;90(14):1039-71. [pmid: 9672254].
30 Lakhani S, Manek S, Penault-Llorca F. Pathology of ovarian cancers in BRCA1 and BRCA2 carriers. Clin Cancer Res. 2004;10(7):2473-81. [pmid: 15073127].
31 Evans DG, Young K, Bulman M, et al. Probability of BRCA1/2 mutation varies with ovarian histology: results from screening 442 ovarian cancer families. Clin Genet. 2008;73(4):338-45. [pmid: 18312450].
32 Tonin P, Maugard C, Perret C. A review of histopathological subtypes of ovarian cancer in BRCA-related French Canadian cancer families. Fam Cancer. 2007;6(4):491-7. [pmid: 17636423].
33 Bolton K, Chenevix-Trench G, Goh C. Association between BRCA1 and BRCA2 mutations and survival in women with invasive epithelial ovarian cancer. JAMA. 2012;307(4):382-90. [pmid: 22274685].
34 Crum C, Drapkin R, Kindelberger DW. Lessons from BRCA: the tubal fimbria emerges as an origin for pelvic serous cancer. Clin Med Res. 2007;5(1):35-44. [pmid: 17456833].
35 Levine D, Argenta P, Yee C. Fallopian tube and primary perirtoneal carcinomas associated with BRCA mutations. J Clin Oncol. 2013;21(22):4222-7. [pmid: 14615451].
36 Mavaddat N, Barrowdale D, Andrulis I. Pathology of breast and ovarian cancers among BRCA1 and BRCA2 mutation carriers: results from the Consortium of Investigators of Modifiers of BRCA1/2 (CIMBA). Cancer Epidemiol Biomarkers Prev. 2012;21(1):134-47. [pmid: 22144499].
37 Centers for Disease Control and Prevention. Breast Cancer Statistics. Atlanta. Centers for Disease Control and Prevention. 2013. Accessed at http://www.cdc.gov/cancer/breast/statistics/ on. 25 November 2013.
38 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2007 Incidence and Mortality Web-Based Report. Atlanta. Centers for Disease Control and Prevention. 2013. Accessed at http://apps.nccd.cdc.gov/uscs/toptencancers.aspx on. 25 November 2013.
39 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2010. Bethesda, MD. National Cancer Institute. 2013. Accessed at http://seer.cancer.gov/csr/1975_2010/ on. 25 November 2013.
40 National Cancer Institute. Ovarian Epithelial Cancer Treatment (PDQ®). Bethesda, MD. National Cancer Institute. 2013. Accessed at http://cancer.gov/cancertopics/pdq/treatment/ovarianepithelial/HealthProfessional on. 25 November 2013.
41 Colditz GA, Willett WC, Hunter DJ. Family history, age, and risk of breast cancer. Prospective data from the Nurses' Health Study. JAMA. 1993;270(3):338-43. [pmid: 8123079].
42 Johnson N, Lancaster T, Fuller A. The prevalence of a family history of cancer in general practice. Fam Pract. 1995;12(3):287-9. [pmid: 8536831].
43 Pharoah PD, Day NE, Duffy S, et al. Family history and the risk of breast cancer: a systematic review and meta-analysis. Int J Cancer. 1997;71(5):800-9. [pmid: 9180149].
44 Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993;270(13):1563-8. [pmid: 8371466].
45 Yang Q, Khoury MJ, Rodriguez C, et al. Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am J Epidemiol. 1998;147(7):652-9. [pmid: 9554604].
46 Couch FJ, DeShano ML, Blackwood MA, et al. BRCA1 mutations in women attending clinics that evaluate the risk of breast cancer. N Engl J Med. 1997;336(20):1409-15. [pmid: 9145677].
47 Frank TS, Deffenbaugh AM, Reid JE, et al. Clinical characteristics of individuals with germline mutations in BRCA1 and BRCA2: analysis of 10,000 individuals. J Clin Oncol. 2002;20(6):1480-90. [pmid: 11896095].
48 Shattuck-Eidens D, Oliphant A, McClure M, et al. BRCA1 sequence analysis in women at high risk for susceptibility mutations: risk factor analysis and implications for genetic testing. JAMA. 1997;278(15):1242-50. [pmid: 9333265].
49 Srivastava A, McKinnon W, Wood ME. Risk of breast and ovarian cancer in women with strong family histories. Oncology (Williston Park). 2001;15(7):889-902. [pmid: 11499690].
50 National Comprehensive Cancer Network. Genetic/Familial High-Risk Assessment: Breast and Ovarian. Fort Washington, PA. National Comprehensive Cancer Network. 2012.
51 American College of Medical Genetics. Genetic Susceptibility to Breast and Ovarian Cancer: Assessment, Counseling, and Testing Guidelines. Bethesda, MD. American College of Medical Genetics. 1999. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK56955/ on. 25 November 2013.
52 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology: Breast Cancer Screening and Diagnosis. Fort Washington, PA. National Comprehensive Cancer Network. 2011.
53 Berry D, Parmigiani G, Sanchez J, et al. Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J Natl Cancer Inst. 1997;89(3):227-38. [pmid: 9017003].
54 Antoniou A, Cunningham A, Peto J. The BOADICEA model of genetic susceptibility to breast and ovarian cancers: updates and extensions. Br J Ca. 2008;98(8):1457-66. [pmid: 18349832].
55 Myriad Genetic Laboratories. Mutation Prevalence Tables. Salt Lake City, UT. Myriad Genetic Laboratories. 2010. Accessed at http://d1izdzz43r5o67.cloudfront.net/brac/brca-prevalence-tables.pdf on. 26 November 2013.
56 Antoniou AC, Hardy R, Walker L, et al. Predicting the likelihood of carrying a BRCA1 or BRCA2 mutation: validation of BOADICEA, BRCAPRO, IBIS, Myriad and the Manchester scoring system using data from UK genetics clinics. J Med Genet. 2008;45(7):425-31. [pmid: 18413374].
57 Bowen DJ, Burke W, Yasui Y, et al. Effects of risk counseling on interest in breast cancer genetic testing for lower risk women. Genet Med. 2002;4(5):359-65. [pmid: 12394349].
58 Burke W, Culver JO, Bowen DJ, et al. Genetic counseling for women with an intermediate family history of breast cancer. Am J Med Genet. 2000;90(5):361-8. [pmid: 10706356].
59 Cull A, Miller H, Porterfield T, et al. The use of videotaped information in cancer genetic counselling: a randomized evaluation study. Br J Cancer. 1998;77(5):830-7. [pmid: 9514066].
60 Lerman C, Hughes C, Benkendorf JL, et al. Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing. Cancer Epidemiol Biomarkers Prev. 1999;8(4 Pt 2):361-7. [pmid: 10207641].
61 Lerman C, Narod S, Schulman K, et al. BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996;275(24):1885-92. [pmid: 8648868].
62 Bowen DJ, Burke W, McTiernan A, et al. Breast cancer risk counseling improves women's functioning. Patient Educ Couns. 2004;53:79-86. [pmid: 15062908].
63 American College of Surgeons. Cancer Program Standards 2012, Version 1.2: Ensuring Patient-Centered Care. Chicago. American College of Surgeons. 2013. Accessed at http://www.facs.org/cancer/coc/programstandards2012.html on. 26 November 2013.
64 Rahman N, Stratton MR. The genetics of breast cancer susceptibility. Annu Rev Genet. 1998;32:95-121. [pmid: 9928476].
65 Myriad Genetic Laboratories. BRACAnalysis® Technical Specifications. Salt Lake City, UT. Myriad Genetic Laboratories. 2013. Accessed at https://s3.amazonaws.com/myriad-library/technical-specifications/BRCA+Tech+Specs_Integrated.pdf on. 26 November 2013.
66 Unger MA, Nathanson KL, Calzone KA, et al. Screening for genomic rearrangements in families with breast and ovarian cancer identifies BRCA1 mutations previously missed by conformation-sensitive gel electrophoresis or sequencing. Am J Hum Genet. 2000;67(4):841-50. [pmid: 10978226].
67 Dhingra K. Antiestrogens—tamoxifen, SERMs and beyond. Invest New Drugs. 1999;7(3):285-311. [pmid: 10665480].
68 Cuzick J, Powels T, Veronesi U, et al. Overview of the main outcomes in breast-cancer prevention trials. Lancet. 2003;361(9354):296-300. [pmid: 12559863].
69 IBIS Investigators. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002;360(9336):817-24. [pmid: 12243915].
70 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352(9122):98-101. [pmid: 9672274].
71 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90(18):1371-88. [pmid: 9747868].
72 Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Lancet. 1998;352(9122):93-7. [pmid: 9672273].
73 Grady D, Cauley JA, Geiger MJ, et al. Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. 2008;100(12):854-61. [pmid: 18544744].
74 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. JAMA. 1999;281(23):2189-97. [pmid: 10376571].
75 Braithwaite RS, Chlebowski RT, Lau J, et al. Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med. 2003;18(11):937-47. [pmid: 14687281].
76 Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Saf. 2001;24(14):1039-53. [pmid: 11735660].
77 Goss PE, Ingle JN, Ales-Martinez JE, et al. Exemestane for breast-cancer prevention in postmenopausal women. N Engl J Med. 2011;364(25):2381-91. [pmid: 21639806].
78 U.S. Preventive Services Task Force. Chemoprevention of breast cancer: recommendations and rationale. Ann Intern Med. 2002;137(1):56-8. [pmid: 12093249].
79 Kauff ND, Satagopan JM, Robson ME, et al. Risk-reducing salpingo-oophorectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2002;346(21):1609-15. [pmid: 12023992].
80 Meijers-Heijboer H, van Geel B, van Putten WL, et al. Breast cancer after prophylactic bilateral mastectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(3):159-64. [pmid: 11463009].
81 Rebbeck TR, Friebel T, Lynch HT, et al. Bilateral prophylactic mastectomy reduces breast cancer risk in BRCA1 and BRCA2 mutation carriers: the PROSE Study Group. J Clin Oncol. 2004;22(6):1055-62. [pmid: 14981104].
82 Rebbeck TR, Levin AM, Eisen A, et al. Breast cancer risk after bilateral prophylactic oophorectomy in BRCA1 mutation carriers. J Natl Cancer Inst. 1999;91(17):1475-9. [pmid: 10469748].
83 Wapnir IL, Rabinowitz B, Greco RS. A reappraisal of prophylactic mastectomy. Surg Gynecol Obstet. 1990;171(2):171-84. [pmid: 2200150].
84 Woods JE. Breast reconstruction: current state of the art. Mayo Clin Proc. 1986;61:579-85. [pmid: 3713262].
85 Goodnight JE, Quagliana JM, Morton DL. Failure of subcutaneous mastectomy to prevent the development of breast cancer. J Surg Oncol. 1984;26:198-201. [pmid: 6330460].
86 Pennisi VR, Capozzi A. Subcutaneous mastectomy data. Aesthetic Plast Surg. 1989;13:15-21. [pmid: 2728994].
87 Aziz S, Kuperstein G, Rosen B, et al. A genetic epidemiological study of carcinoma of the fallopian tube. Gynecol Oncol. 2001;80:341-5. [pmid: 11263928].
88 Paley PJ, Swisher EM, Garcia RL, et al. Occult cancer of the fallopian tube in BRCA-1 germline mutation carriers at prophylactic oophorectomy: a case for recommending hysterectomy at surgical prophylaxis. Gynecol Oncol. 2001;80:176-80. [pmid: 11161856].
89 Bandera CA, Muto MG, Schorge JO, et al. BRCA1 gene mutations in women with papillary serous carcinoma of the peritoneum. Obstet Gynecol. 1998;92(4):596-600. [pmid: 9764635].
90 Piver MS, Jishi MF, Tsukada Y, et al. Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry. Cancer. 1993;71(9):2751-5. [pmid: 8467455].
91 Tobacman JK, Tucker MA, Kase RG, et al. Intra-abdominal carcinomatosis after prophylactic oophorectomy in ovarian-cancer-prone families. Lancet. 1982;2(8302):795-7. [pmid: 6126666].
92 American Society of Clinical Oncology. Statement of the American Society of Clinical Oncology: genetic testing for cancer susceptibility. J Clin Oncol. 1996;14(5):1730-6. [pmid: 8622094].
93 Bellcross CA, Kolor K, Goddard KA, et al. Awareness and utilization of BRCA1/2 testing among U.S. primary care physicians. Am J Prev Med. 2011;40(1):61-6. [pmid: 21146769].
94 Cox SL, Zlot AI, Silvey K, et al. Patterns of cancer genetic testing: a randomized survey of Oregon clinicians. J Cancer Epidemiol. 2012;2012:294730. [pmid: 23150730].
95 Waters E, McNeel T, Stevens W, et al. Use of tamoxifen and raloxifene for breast cancer chemoprevention in 2010. Breast Cancer Res Treat. 2012;134:875-80. [pmid: 22622807].
96 Michigan Department of Community Health. BRCA 1/2 Surveillance in Michigan, 2008–2012. Lansing, MI. Michigan Department of Community Health. 2012. Accessed at http://www.michigan.gov/documents/mdch/11-12_BRCAsurveillance2012_FINAL_403992_7.pdf on. 26 November 2013.
97 Metcalfe KA, Birenbaum-Carmeli D, Lubinski J, et al. International variation in rates of uptake of preventive options in BRCA1 and BRCA2 mutation carriers. Int J Cancer. 2008;122(9):2017-22. [pmid: 18196574].
98 Beattie MS, Crawford B, Lin F, et al. Uptake, time course, and predictors of risk-reducing surgeries in BRCA carriers. Genet Test Mol Biomarkers. 2009;13(1):51-6. [pmid: 19309274].
99 Mannis G, Fehniger J, Creasman J, et al. Risk-reducing salpingo-oophorectomy and ovarian cancer screening in 1077 women after BRCA testing. JAMA. 2013;173(2):96-103. [pmid: 23247828].
100 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl 1):21-35. [pmid: 11306229].
101 Leeflang MM, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-97. [pmid: 19075208].
102 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
103 Sahai H, Khurshid A. Confidence intervals for the mean of a Poisson distribution: a review. Biom J. 1993;35:857-67.
104 Higgins J, Thompson S. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21:1539-58. [pmid: 12111919].
105 DerSimonian R, Laird NM. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
106 Stratton JF, Pharoah P, Smith SK, et al. A systematic review and meta-analysis of family history and risk of ovarian cancer. Br J Obstet Gynaecol. 1998;105(5):493-9. [pmid: 9637117].
107 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997;146(3):244-8. [pmid: 9247008].
108 Mai PL, Garceau AO, Graubard BI, et al. Confirmation of family cancer history reported in a population-based survey. J Natl Cancer Inst. 2011;103(10):788-97. [pmid: 21562245].
109 Mouchawar J, Valentine Goins K, Somkin C, et al. Guidelines for breast and ovarian cancer genetic counseling referral: adoption and implementation in HMOs. Genet Med. 2003;5(6):444-50. [pmid: 14614396].
110 de Silva D, Gilbert F, Needham G, et al. Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J Med Genet. 1995;32(11):862-6. [pmid: 8592328].
111 National Breast and Ovarian Cancer Centre. Advice About Familial Aspects of Breast Cancer and Epithelial Ovarian Cancer: A Guide for Health Professionals. New South Wales, Australia. National Breast and Ovarian Cancer Centre. 2010. Accessed at http://canceraustralia.gov.au/sites/default/files/publications/nbocc-bog-2010-web-a4-printable_504af02a673fd.pdf on. 26 November 2013.
112 de Bock GH, Vliet Vlieland TP, Hageman GC, et al. The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam Pract. 1999;16(1):71-7. [pmid: 10321400].
113 Pichert G, Stahel RA. Organizing cancer genetics programs: the Swiss model. J Clin Oncol. 2000;18(21 Suppl):65S-9. [pmid: 11060330].
114 Hampel H, Sweet K, Westman JA, et al. Referral for cancer genetics consultation: a review and compilation of risk assessment criteria. J Med Genet. 2004;41:81-91. [pmid: 14757853].
115 Nelson HD, Fu R, Griffin JC, et al. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009;151(10):703-15. [pmid: 19920271].
116 Nelson H, Smith M, Griffin J, et al. Use of medications to reduce risk for primary breast cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;158(8):604-14. [pmid: 23588749].
117 Adams-Campbell LL, Makambi KH, Palmer JR, et al. Diagnostic accuracy of the Gail model in the Black Women's Health Study. Breast J. 2007;13(4):332-6. [pmid: 17593036].
118 Amir E, Evans DG, Shenton A, et al. Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J Med Genet. 2003;40(11):807-14. [pmid: 14627668].
119 Barlow WE, White E, Ballard-Barbash R, et al. Prospective breast cancer risk prediction model for women undergoing screening mammography. J Natl Cancer Inst. 2006;98(17):1204-14. [pmid: 16954473].
120 Boughey JC, Hartmann LC, Anderson SS, et al. Evaluation of the Tyrer-Cuzick (International Breast Cancer Intervention Study) model for breast cancer risk prediction in women with atypical hyperplasia. J Clin Oncol. 2010;28(22):3591-6. [pmid: 20606088].
121 Boyle P, Mezzetti M, La Vecchia C, et al. Contribution of three components to individual cancer risk predicting breast cancer risk in Italy. Eur J Cancer Prev. 2004;13(3):183-91. [pmid: 15167217].
122 Chen J, Pee D, Ayyagari R, et al. Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J Natl Cancer Inst. 2006;98(17):1215-26. [pmid: 16954474].
123 Chlebowski RT, Anderson GL, Lane DS, et al. Predicting risk of breast cancer in postmenopausal women by hormone receptor status. J Natl Cancer Inst. 2007;99(22):1695-705. [pmid: 18000216].
124 Colditz GA, Rosner B. Cumulative risk of breast cancer to age 70 years according to risk factor status: data from the Nurses' Health Study. Am J Epidemiol. 2000;152(10):950-64. [pmid: 11092437].
125 Colditz GA, Rosner BA, Chen WY, et al. Risk factors for breast cancer according to estrogen and progesterone receptor status. J Natl Cancer Inst. 2004;96(3):218-28. [pmid: 14759989].
126 Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91(18):1541-8. [pmid: 10491430].
127 Decarli A, Calza S, Masala G, et al. Gail model for prediction of absolute risk of invasive breast cancer: independent evaluation in the Florence-European Prospective Investigation Into Cancer and Nutrition cohort. J Natl Cancer Inst. 2006;98(23):1686-93. [pmid: 17148770].
128 Gail M, Brinton L, Byar D, et al. Projecting individualized probablities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81(24):1879-86. [pmid: 2593165].
129 Gail MH, Costantino JP, Pee D, et al. Projecting individualized absolute invasive breast cancer risk in African American women. J Natl Cancer Inst. 2007;99(23):1782-92. [pmid: 18042936].
130 Lee EO, Ahn SH, You C, et al. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. 2004;27(5):400-6. [pmid: 15525868].
131 Petracci E, Decarli A, Schairer C, et al. Risk factor modification and projections of absolute breast cancer risk. J Natl Cancer Inst. 2011;103(13):1037-48. [pmid: 21705679].
132 Rockhill B, Spiegelman D, Byrne C, et al. Validation of the Gail, et al model of breast cancer risk prediction and implications for chemoprevention. J Natl Cancer Inst. 2001;93:358-66. [pmid: 11238697].
133 Rockhill B, Byrne C, Rosner B, et al. Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J Clin Epidemiol. 2003;56(9):856-61. [pmid: 14505770].
134 Tamimi RM, Rosner B, Colditz GA. Evaluation of a breast cancer risk prediction model expanded to include category of prior benign breast disease lesion. Cancer. 2010;116(21):4944-53. [pmid: 20645399].
135 Tice JA, Cummings SR, Smith-Bindman R, et al. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337-47. [pmid: 18316752].
136 Tyrer J, Duffy SW, Cuzick J. A breast cancer prediction model incorporating familial and personal risk factors. Stat Med. 2004;23(7):1111-30. [pmid: 15057881].
137 Vacek PM, Skelly JM, Geller BM. Breast cancer risk assessment in women aged 70 and older. Breast Cancer Res Treat. 2011;130(1):291-9. [pmid: 21604157].
138 Ashton-Prolla P, Giacomazzi J, Schmidt AV, et al. Development and validation of a simple questionnaire for the identification of hereditary breast cancer in primary care. BMC Cancer. 2009;9:283. [pmid: 19682358].
139 Barcenas CH, Hosain GM, Arun B, et al. Assessing BRCA carrier probabilities in extended families. J Clin Oncol. 2006;24(3):354-60. [pmid: 16421416].
140 Bellcross CA, Lemke AA, Pape LS, et al. Evaluation of a breast/ovarian cancer genetics referral screening tool in a mammography population. Genet Med. 2009;11(11):783-9. [pmid: 19752737].
141 Evans DG, Eccles DM, Rahman N, et al. A new scoring system for the chances of identifying a BRCA 1/2 mutation outperforms existing models including BRCAPRO. J Med Genet. 2004;41:474-80. [pmid: 15173236].
142 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin Genet. 2000;58(4):299-308. [pmid: 11076055].
143 Hoskins KF, Zwaagstra A, Ranz M. Validation of a tool for identifying women at high risk for hereditary breast cancer in population-based screening. Cancer. 2006;107(8):1769-76. [pmid: 16967460].
144 Oros KK, Ghadirian P, Maugard CM, et al. Application of BRCA1 and BRCA2 mutation carrier prediction models in breast and/or ovarian cancer families of French Canadian descent. Clin Genet. 2006;70(4):320-9. [pmid: 16965326].
145 Panchal SM, Ennis M, Canon S, et al. Selecting a BRCA risk assessment model for use in a familial cancer clinic. BMC Med Genet. 2008;9:116. [pmid: 19102775].
146 Parmigiani G, Chen S, Iversen ES Jr, et al. Validity of models for predicting BRCA1 and BRCA2 mutations. Ann Intern Med. 2007;147(7):441-50. [pmid: 17909205].
147 Bellcross C. Further development and evaluation of a breast/ovarian cancer genetics referral screening tool. Genet Med. 2010;12(4):240. [pmid: 20395744].
148 Armstrong K, Micco E, Carney A, et al. Racial differences in the use of BRCA1/2 testing among women with a family history of breast or ovarian cancer. JAMA. 2005;293(14):1729-36. [pmid: 15827311].
149 Bennett P, Wilkinson C, Turner J, et al. Factors associated with intrusive cancer-related worries in women undergoing cancer genetic risk assessment. Fam Cancer. 2009;8(2):159-65. [pmid: 19011994].
150 Bennett P, Wilkinson C, Turner J, et al. Psychological factors associated with emotional responses to receiving genetic risk information. J Genet Couns. 2008;17(3):234-41. [pmid: 18259848].
151 Bloom JR, Stewart SL, Chang S, et al. Effects of a telephone counseling intervention on sisters of young women with breast cancer. Prev Med. 2006;43(5):379-84. [pmid: 16916540].
152 Bowen DJ, Burke W, Culver JO, et al. Effects of counseling Ashkenazi Jewish women about breast cancer risk. Cultur Divers Ethni Minor Psychol. 2006;12(1):45-56. [pmid: 16594854].
153 Brain K, Parsons E, Bennett P, et al. The evolution of worry after breast cancer risk assessment: 6-year follow-up of the TRACE study cohort. Psychooncology. 2011;20(9):984-91. [pmid: 20677331].
154 Braithwaite D, Sutton S, Mackay J, et al. Development of a risk assessment tool for women with a family history of breast cancer. Cancer Detect Prev. 2005;29(5):433-9. [pmid: 16055276].
155 Fry A, Cull A, Appleton S, et al. A randomised controlled trial of breast cancer genetics services in South East Scotland: psychological impact. Br J Cancer. 2003;89(4):653-9. [pmid: 12915873].
156 Gurmankin AD, Domchek S, Stopfer J, et al. Patients' resistance to risk information in genetic counseling for BRCA1/2. Arch Intern Med. 2005;165(5):523-9. [pmid: 15767527].
157 Helmes AW, Culver JO, Bowen DJ. Results of a randomized study of telephone versus in-person breast cancer risk counseling. Patient Educ Couns. 2006;64(1-3):96-103. [pmid: 16427245].
158 Hopwood P, Wonderling D, Watson M, et al. A randomised comparison of UK genetic risk counselling services for familial cancer: psychosocial outcomes. Br J Cancer. 2004;91(5):884-92. [pmid: 15305197].
159 Kelly KM, Senter L, Leventhal H, et al. Subjective and objective risk of ovarian cancer in Ashkenazi Jewish women testing for BRCA1/2 mutations. Patient Educ Couns. 2008;70(1):135-42. [pmid: 17988821].
160 Matloff ET, Moyer A, Shannon KM, et al. Healthy women with a family history of breast cancer: impact of a tailored genetic counseling intervention on risk perception, knowledge, and menopausal therapy decision making. J Womens Health. 2006;15(7):843-56. [pmid: 16999640].
161 Mikkelsen EM, Sunde L, Johansen C, et al. Risk perception among women receiving genetic counseling: a population-based follow-up study. Cancer Epidemiol Biomarkers Prev. 2007;31(6):457-64. [pmid: 18061369].
162 Mikkelsen EM, Sunde L, Johansen C, et al. Psychosocial consequences of genetic counseling: a population-based follow-up study. Breast J. 2009;15(1):61-8. [pmid: 19120380].
163 Pieterse AH, Ausems MG, Spreeuwenberg P, et al. Longer-term influence of breast cancer genetic counseling on cognitions and distress: smaller benefits for affected versus unaffected women. Patient Educ Couns. 2011;85(3):425-31. [pmid: 21316181].
164 Roshanai AH, Rosenquist R, Lampic C, et al. Does enhanced information at cancer genetic counseling improve counselees' knowledge, risk perception, satisfaction and negotiation of information to at-risk relatives? A randomized study. Acta Oncol. 2009;48(7):999-1009. [pmid: 19636983].
165 Smerecnik CM, Mesters I, Verweij E, et al. A systematic review of the impact of genetic counseling on risk perception accuracy. J Genet Couns. 2009;18(3):217-28. [pmid: 19291376].
166 Brain K, Norman P, Gray J, et al. A randomized trial of specialist genetic assessment: psychological impact on women at different levels of familial breast cancer risk. Br J Cancer. 2002;86(2):233-8. [pmid: 11870512].
167 Hopwood P, Keeling F, Long A, et al. Psychological support needs for women at high genetic risk of breast cancer: some preliminary indicators. Psychooncology. 1998;7(5):402-12. [pmid: 9809331].
168 Lerman C, Schwartz MD, Miller SM, et al. A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style. Health Psychol. 1996;15(2):75-83. [pmid: 8681923].
169 Lobb EA, Butow PN, Barratt A, et al. Communication and information-giving in high-risk breast cancer consultations: influence on patient outcomes. Br J Cancer. 2004;90(2):321-7. [pmid: 14735171].
170 Watson M, Lloyd S, Davidson J, et al. The impact of genetic counselling on risk perception and mental health in women with a family history of breast cancer. Br J Ca. 1999;79(5-6):868-74. [pmid: 10070883].
171 Watson M, Duvivier V, Wade Walsh M, et al. Family history of breast cancer: what do women understand and recall about their genetic risk?. J Med Genet. 1998;35(9):731-8. [pmid: 9733031].
172 Al-Mulla F, Bland JM, Serratt D, et al. Age-dependent penetrance of different germline mutations in the BRCA1 gene. J Clin Pathol. 2009;62(4):350-6. [pmid: 19329713].
173 Antoniou AC, Durocher F, Smith P, et al. BRCA1 and BRCA2 mutation predictions using the BOADICEA and BRCAPRO models and penetrance estimation in high-risk French-Canadian families. Breast Cancer Res. 2006;8(1):R3. [pmid: 16417652].
174 Beristain E, Martinez-Bouzas C, Guerra I, et al. Differences in the frequency and distribution of BRCA1 and BRCA2 mutations in breast/ovarian cancer cases from the Basque country with respect to the Spanish population: implications for genetic counselling. Breast Cancer Res Treat. 2007;106(2):255-62. [pmid: 17262179].
175 Bernholtz S, Laitman Y, Kaufman B, et al. Phenocopy breast cancer rates in Israeli BRCA1 BRCA2 mutation carrier families: is the risk increased in non-carriers?. Breast Cancer Res Treat. 2012;132(2):669-73. [pmid: 22113258].
176 Chen S, Iversen ES, Friebel T, et al. Characterization of BRCA1 and BRCA2 mutations in a large United States sample. J Clin Oncol. 2006;24(6):863-71. [pmid: 16484695].
177 Domchek SM, Gaudet MM, Stopfer JE, et al. Breast cancer risks in individuals testing negative for a known family mutation in BRCA1 or BRCA2. Breast Cancer Res Treat. 2010;119(2):409-14. [pmid: 19885732].
178 Evans DG, Shenton A, Woodward E, et al. Penetrance estimates for BRCA1 and BRCA2 based on genetic testing in a clinical cancer genetics service setting: risks of breast/ovarian cancer quoted should reflect the cancer burden in the family. BMC Cancer. 2008;8:155. [pmid: 18513387].
179 Finkelman BS, Rubinstein WS, Friedman S, et al. Breast and ovarian cancer risk and risk reduction in Jewish BRCA1/2 mutation carriers. J Clin Oncol. 2012;30(12):1321-8. [pmid: 22430266].
180 Gronwald J, Cybulski C, Lubinski J, et al. Phenocopies in breast cancer 1 (BRCA1) families: implications for genetic counselling. J Med Genet. 2007;44(4):e76. [pmid: 17400795].
181 Harvey SL, Milne RL, McLachlan SA, et al. Prospective study of breast cancer risk for mutation negative women from BRCA1 or BRCA2 mutation positive families. Breast Cancer Res Treat. 2011;130(3):1057-61. [pmid: 21850394].
182 Kauff ND, Mitra N, Robson ME, et al. Risk of ovarian cancer in BRCA1 and BRCA2 mutation-negative hereditary breast cancer families. J Natl Cancer Inst. 2005;97(18):1382-4. [pmid: 16174860].
183 Konecny M, Milly M, Zavodna K, et al. Comprehensive genetic characterization of hereditary breast/ovarian cancer families from Slovakia. Breast Cancer Res Treat. 2011;126(1):119-30. [pmid: 21203900].
184 Korde LA, Mueller CM, Loud JT, et al. No evidence of excess breast cancer risk among mutation-negative women from BRCA mutation-positive families. Breast Cancer Res Treat. 2011;125(1):169-73. [pmid: 20458532].
185 Kramer JL, Velazquez IA, Chen BE, et al. Prophylactic oophorectomy reduces breast cancer penetrance during prospective, long-term follow-up of BRCA1 mutation carriers. J Clin Oncol. 2005;23(34):8629-35. [pmid: 16314625].
186 Kurian AW, Gong GD, John EM, et al. Breast cancer risk for noncarriers of family-specific BRCA1 and BRCA2 mutations: findings from the Breast Cancer Family Registry. J Clin Oncol. 2011;29(34):4505-9. [pmid: 22042950].
187 Lubinski J, Huzarski T, Byrski T, et al. The risk of breast cancer in women with a BRCA1 mutation from North America and Poland. Int J Cancer. 2012;131(1):229-34. [pmid: 21834074].
188 Marroni F, Aretini P, D'Andrea E, et al. Penetrances of breast and ovarian cancer in a large series of families tested for BRCA1/2 mutations. Eur J Hum Genet. 2004;12(11):899-906. [pmid: 15340362].
189 Metcalfe KA, Finch A, Poll A, et al. Breast cancer risks in women with a family history of breast or ovarian cancer who have tested negative for a BRCA1 or BRCA2 mutation. Br J Cancer. 2009;100(2):421-5. [pmid: 19088722].
190 Metcalfe K, Lubinski J, Lynch HT, et al. Family history of cancer and cancer risks in women with BRCA1 or BRCA2 mutations. J Natl Cancer Inst. 2010;102(24):1874-8. [pmid: 21098759].
191 Metcalfe KA, Poll A, Royer R, et al. Screening for founder mutations in BRCA1 and BRCA2 in unselected Jewish women. J Clin Oncol. 2010;28(3):387-91. [pmid: 20008623].
192 Milne RL, Osorio A, Cajal TR, et al. The average cumulative risks of breast and ovarian cancer for carriers of mutations in BRCA1 and BRCA2 attending genetic counseling units in Spain. Clin Cancer Res. 2008;14(9):2861-9. [pmid: 18451254].
193 Nanda R, Schumm LP, Cummings S, et al. Genetic testing in an ethnically diverse cohort of high-risk women: a comparative analysis of BRCA1 and BRCA2 mutations in American families of European and African ancestry. JAMA. 2005;294(15):1925-33. [pmid: 16234499].
194 Neuhausen SL, Ozcelik H, Southey MC, et al. BRCA1 and BRCA2 mutation carriers in the Breast Cancer Family Registry: an open resource for collaborative research. Breast Cancer Res Treat. 2009;116(2):379-86. [pmid: 18704680].
195 Risch HA, McLaughlin JR, Cole DE, et al. Population BRCA1 and BRCA2 mutation frequencies and cancer penetrances: a kin-cohort study in Ontario, Canada. J Natl Cancer Inst. 2006;98(23):1694-706. [pmid: 17148771].
196 Rowan E, Poll A, Narod SA. A prospective study of breast cancer risk in relatives of BRCA1/BRCA2 mutation carriers. J Med Genet. 2007;44(8):e89. [pmid: 17673443].
197 Seymour IJ, Casadei S, Zampiga V, et al. Results of a population-based screening for hereditary breast cancer in a region of North-Central Italy: contribution of BRCA1/2 germ-line mutations. Breast Cancer Res Treat. 2008;112(2):343-9. [pmid: 18092194].
198 Smith A, Moran A, Boyd MC, et al. Phenocopies in BRCA1 and BRCA2 families: evidence for modifier genes and implications for screening. J Med Genet. 2007;44:10-5. [pmid: 17079251].
199 Tamboom K, Kaasik K, Aršavskaja J, et al. BRCA1 mutations in women with familial or early-onset breast cancer and BRCA2 mutations in familial cancer in Estonia. Hered Cancer Clin Pract. 2010;8(1):4. [pmid: 20380699].
200 Tommasi S, Crapolicchio A, Lacalamita R, et al. BRCA1 mutations and polymorphisms in a hospital-based consecutive series of breast cancer patients from Apulia, Italy. Mutat Res. 2005;578(1-2):395-405. [pmid: 16026807].
201 van der Kolk DM, de Bock GH, Leegte BK, et al. Penetrance of breast cancer, ovarian cancer and contralateral breast cancer in BRCA1 and BRCA2 families: high cancer incidence at older age. Breast Cancer Res Treat. 2010;124(3):643-51. [pmid: 20204502].
202 Vaziri SA, Krumroy LM, Rostai M, et al. Frequency of BRCA1 and BRCA2 mutations in a clinic-based series of breast and ovarian cancer families. Hum Mutat. 2001;17(1):74. [pmid: 11139249].
203 Abeliovich D, Kaduri L, Lerer I, et al. The founder mutations 185delAG and 5382insC in BRCA1 and 6174delT in BRCA2 appear in 60% of ovarian cancer and 30% of early-onset breast cancer patients among Ashkenazi women. Am J Hum Genet. 1997;60(3):505-14. [pmid: 9042909].
204 Anton-Culver H, Cohen PF, Gildea ME, et al. Characteristics of BRCA1 mutations in a population-based case series of breast and ovarian cancer. Eur J Cancer. 2000;36(10):1200-8. [pmid: 10882857].
205 Boyd J, Sonoda Y, Federici MG, et al. Clinicopathologic features of BRCA-linked and sporadic ovarian cancer. JAMA. 2000;283(17):2260-5. [pmid: 10807385].
206 Brose MS, Rebbeck TR, Calzone KA, et al. Cancer risk estimates for BRCA1 mutation carriers identified in a risk evaluation program. J Natl Cancer Inst. 2002;94(18):1365-72. [pmid: 12237282].
207 Eccles DM, Englefield P, Soulby MA, et al. BRCA1 mutations in southern England. Br J Cancer. 1998;77(12):2199-203. [pmid: 9649133].
208 FitzGerald MG, MacDonald DJ, Krainer M, et al. Germ-line BRCA1 mutations in Jewish and non-Jewish women with early-onset breast cancer. N Engl J Med. 1996;334(3):143-9. [pmid: 8531968].
209 Fodor FH, Weston A, Bleiweiss IJ, et al. Frequency and carrier risk associated with common BRCA1 and BRCA2 mutations in Ashkenazi Jewish breast cancer patients. Am J Hum Genet. 1998;63(1):45-51. [pmid: 9634504].
210 Ford D, Easton DF, Stratton M, et al. Genetic heterogeneity and penetrance analysis of the BRCA1 and BRCA2 genes in breast cancer families. Am J Hum Genet. 1998;62(3):676-89. [pmid: 9497246].
211 Gayther SA, Mangion J, Russell P, et al. Variation of risks of breast and ovarian cancer associated with different germline mutations of the BRCA2 gene. Nat Genet. 1997;15(1):103-5. [pmid: 8988179].
212 Gayther SA, Russell P, Harrington P, et al. The contribution of germline BRCA1 and BRCA2 mutations to familial ovarian cancer: no evidence for other ovarian cancer-susceptibility genes. Am J Hum Genet. 1999;65(4):1021-9. [pmid: 10486320].
213 Gershoni-Baruch R, Dagan E, Fried G, et al. Significantly lower rates of BRCA1/BRCA2 founder mutations in Ashkenazi women with sporadic compared with familial early onset breast cancer. Eur J Cancer. 2000;36(8):983-6. [pmid: 10885601].
214 Hartge P, Struewing JP, Wacholder S, et al. The prevalence of common BRCA1 and BRCA2 mutations among Ashkenazi Jews. Am J Hum Genet. 1999;64(4):963-70. [pmid: 10090881].
215 Hopper JL, Southey MC, Dite GS, et al. Population-based estimate of the average age-specific cumulative risk of breast cancer for a defined set of protein-truncating mutations in BRCA1 and BRCA2: Australian Breast Cancer Family Study. Cancer Epidemiol Biomarkers Prev. 1999;8(9):741-7. [pmid: 10498392].
216 Janezic SA, Ziogas A, Krumroy LM, et al. Germline BRCA1 alterations in a population-based series of ovarian cancer cases. Hum Mol Genet. 1999;8(5):889-97. [pmid: 10196379].
217 King MC, Marks JH, Mandell JB. Breast and ovarian cancer risks due to inherited mutations in BRCA1 and BRCA2. Science. 2003;302(5645):643-6. [pmid: 14576434].
218 Langston AA, Malone KE, Thompson JD, et al. BRCA1 mutations in a population-based sample of young women with breast cancer. N Engl J Med. 1996;334:137-42. [pmid: 8531967].
219 Liede A, Karlan BY, Baldwin RL, et al. Cancer incidence in a population of Jewish women at risk of ovarian cancer. J Clin Oncol. 2002;20(6):1570-7. [pmid: 11896106].
220 Malone KE, Daling JR, Neal C, et al. Frequency of BRCA1/BRCA2 mutations in a population-based sample of young breast carcinoma cases. Cancer. 2000;88(6):1393-402. [pmid: 10717622].
221 Modan B, Hartge P, Hirsh-Yechezkel G, et al. Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(4):235-40. [pmid: 11474660].
222 Moslehi R, Chu W, Karlan B, et al. BRCA1 and BRCA2 mutation analysis of 208 Ashkenazi Jewish women with ovarian cancer. Am J Hum Genet. 2000;66(4):1259-72. [pmid: 10739756].
223 Newman B, Mu H, Butler LM, et al. Frequency of breast cancer attributable to BRCA1 in a population-based series of American women. JAMA. 1998;279(12):915-21. [pmid: 9544765].
224 Oddoux C, Struewing JP, Clayton CM, et al. The carrier frequency of the BRCA2 6174delT mutation among Ashkenazi Jewish individuals is approximately 1%. Nat Genet. 1996;14(2):188-90. [pmid: 8841192].
225 Risch HA, McLaughlin JR, Cole DE, et al. Prevalence and penetrance of germline BRCA1 and BRCA2 mutations in a population series of 649 women with ovarian cancer. Am J Hum Genet. 2001;68(3):700-10. [pmid: 11179017].
226 Robson M, Gilewski T, et al. BRCA-associated breast cancer in young women. J Clin Oncol. 1998;16:1642-9. [pmid: 9586873].
227 Satagopan JM, Offit K, Foulkes W, et al. The lifetime risks of breast cancer in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2001;10(5):467-73. [pmid: 11352856].
228 Stratton JF, Gayther SA, Russell P, et al. Contribution of BRCA1 mutations to ovarian cancer. N Engl J Med. 1997;336(16):1125-30. [pmid: 9099656].
229 Struewing JP, Watson P, Easton DF, et al. Prophylactic oophorectomy in inherited breast/ovarian cancer families. J Natl Cancer Inst Monogr. 1995;(17):33-5. [pmid: 8573450].
230 Sutcliffe S, Pharoah PD, Easton DF, et al. Ovarian and breast cancer risks to women in families with two or more cases of ovarian cancer. Int J Cancer. 2000;87:110-17. [pmid: 10861460].
231 Warner E, Foulkes W, Goodwin P, et al. Prevalence and penetrance of BRCA1 and BRCA2 gene mutations in unselected Ashkenazi Jewish women with breast cancer. J Natl Cancer Inst. 1999;91(14):1241-7. [pmid: 10413426].
232 Couch FJ, Sinilnikova O, Vierkant RA, et al. AURKA F31I polymorphism and breast cancer risk in BRCA1 and BRCA2 mutation carriers: a consortium of investigators of modifiers of BRCA1/2 study. Cancer Epidemiol Biomarkers Prev. 2007;16(7):1416-21. [pmid: 17627006].
233 Begg CB. On the use of familial aggregation in population-based case probands for calculating penetrance. J Natl Cancer Inst. 2002;94(16):1221-6. [pmid: 12189225].
234 Antoniou AC, Pharoah PD, Narod S, et al. Breast and ovarian cancer risks to carriers of the BRCA1 5382insC and 185delAG and BRCA2 6174delT mutations: a combined analysis of 22 population based studies. J Med Genet. 2005;42(7):602-3. [pmid: 15994883].
235 Arver B, Haegermark A, Platten U, et al. Evaluation of psychosocial effects of pre-symptomatic testing for breast/ovarian and colon cancer pre-disposing genes: a 12-month follow-up. Fam Cancer. 2004;3(2):109-16. [pmid: 15340261].
236 Dagan E, Shochat T. Quality of life in asymptomatic BRCA1/2 mutation carriers. Prev Med. 2009;48(2):193-6. [pmid: 19084553].
237 Ertmanski S, Metcalfe K, Trempala J, et al. Identification of patients at high risk of psychological distress after BRCA1 genetic testing. Genet Test Mol Biomarkers. 2009;13(3):325-30. [pmid: 19405874].
238 Foster C, Watson M, Eeles R, et al. Predictive genetic testing for BRCA1/2 in a UK clinical cohort: three-year follow-up. Br J Cancer. 2007;96(5):718-24. [pmid: 17285126].
239 Geirdal AO, Dahl AA. The relationship between coping strategies and anxiety in women from families with familial breast-ovarian cancer in the absence of demonstrated mutations. Psychooncology. 2008;17(1):49-57. [pmid: 17385192].
240 Geirdal AO, Reichelt JG, Dahl AA, et al. Psychological distress in women at risk of hereditary breast/ovarian or HNPCC cancers in the absence of demonstrated mutations. Fam Cancer. 2005;4(2):121-6. [pmid: 15951962].
241 Graves KD, Vegella P, Poggi EA, et al. Long-term psychosocial outcomes of BRCA1/BRCA2 testing: differences across affected status and risk-reducing surgery choice. Cancer Epidemiol Biomarkers Prev. 2012;21(3):445-55. [pmid: 22328347].
242 Julian-Reynier C, Mancini J, Mouret-Fourme E, et al. Cancer risk management strategies and perceptions of unaffected women 5 years after predictive genetic testing for BRCA1/2 mutations. Eur J Hum Genet. 2011;19(5):500-6. [pmid: 21267012].
243 Kinney AY, Bloor LE, Mandal D, et al. The impact of receiving genetic test results on general and cancer-specific psychologic distress among members of an African-American kindred with a BRCA1 mutation. Cancer. 2005;104(11):2508-16. [pmid: 16222692].
244 Low CA, Bower JE, Kwan L, et al. Benefit finding in response to BRCA1/2 testing. Ann Behav Med. 2008;35(1):61-9. [pmid: 18347905].
245 Reichelt JG, Heimdal K, Møller P, et al. BRCA1 testing with definitive results: a prospective study of psychological distress in a large clinic-based sample. Fam Cancer. 2004;3(1):21-8. [pmid: 15131402].
246 Reichelt JG, Moller P, Heimdal K, et al. Psychological and cancer-specific distress at 18 months post-testing in women with demonstrated BRCA1 mutations for hereditary breast/ovarian cancer. Fam Cancer. 2008;7(3):245-54. [pmid: 18219587].
247 Shochat T, Dagan E. Sleep disturbances in asymptomatic BRCA1/2 mutation carriers: women at high risk for breast-ovarian cancer. J Sleep Res. 2010;19(2):333-40. [pmid: 20337906].
248 van Dijk S, Timmermans DR, Meijers-Heijboer H, et al. Clinical characteristics affect the impact of an uninformative DNA test result: the course of worry and distress experienced by women who apply for genetic testing for breast cancer. J Clin Oncol. 2006;24(22):3672-7. [pmid: 16877736].
249 Metcalfe KA, Mian N, Enmore M, et al. Long-term follow-up of Jewish women with a BRCA1 and BRCA2 mutation who underwent population genetic screening. Breast Cancer Res Treat. 2012;133(2):735-40. [pmid: 22240989].
250 Meiser B, Butow P, Friedlander M, et al. Psychological impact of genetic testing in women from high-risk breast cancer families. Eur J Cancer. 2002;38(15):2025-31. [pmid: 12376208].
251 Bakos AD, Hutson SP, Loud JT, et al. BRCA mutation-negative women from hereditary breast and ovarian cancer families: a qualitative study of the BRCA-negative experience. Health Expect. 2008;11(3):220-31. [pmid: 18816319].
252 Hamilton R, Williams JK, Skirton H, et al. Living with genetic test results for hereditary breast and ovarian cancer. J Nurs Scholarsh. 2009;41(3):276-83. [pmid: 19723276].
253 Offit K, Groeger E, Turner S, et al. The “duty to warn” a patient's family members about hereditary disease risks. JAMA. 2004;292(12):1469-73. [pmid: 15383518].
254 DeMarco TA, McKinnon WC. Life after BRCA1/2 testing: family communication and support issues. Breast Dis. 2007;27:127-36. [pmid: 17917144].
255 Hamilton RJ, Bowers BJ, Williams JK. Disclosing genetic test results to family members. J Nurs Scholarsh. 2005;37(1):18-24. [pmid: 15813582].
256 Etchegary H, Miller F, deLaat S, et al. Decision-making about inherited cancer risk: exploring dimensions of genetic responsibility. J Genet Couns. 2009;18(3):252-64. [pmid: 19294336].
257 Dancyger C, Wiseman M, Jacobs C, et al. Communicating BRCA1/2 genetic test results within the family: a qualitative analysis. Psychol Health. 2011;26(8):1018-35. [pmid: 21797732].
258 Wagner Costalas J, Itzen M, Malick J, et al. Communication of BRCA1 and BRCA2 results to at-risk relatives: a cancer risk assessment program's experience. Am J Med Genet C Semin Med Genet. 2003;119C(1):11-8. [pmid: 12704633].
259 Finlay E, Stopfer JE, Burlingame E, et al. Factors determining dissemination of results and uptake of genetic testing in families with known BRCA1/2 mutations. Genet Test. 2008;12(1):81-91. [pmid: 18373407].
260 Clarke S, Butler K, Esplen MJ. The phases of disclosing BRCA1/2 genetic information to offspring. Psychooncology. 2008;17(8):797-803. [pmid: 18646247].
261 Segal J, Esplen MJ, Toner B, et al. An investigation of the disclosure process and support needs of BRCA1 and BRCA2 carriers. Am J Med Genet A. 2004;125A(3):267-72. [pmid: 14994235].
262 Bradbury AR, Patrick-Miller L, Pawlowski K, et al. Learning of your parent's BRCA mutation during adolescence or early adulthood: a study of offspring experiences. Psychooncology. 2009;18(2):200-8. [pmid: 18702049].
263 Tercyak KP, Peshkin BN, Streisand R, et al. Psychological issues among children of hereditary breast cancer gene (BRCA1/2) testing participants. Psychooncology. 2001;10(4):336-46. [pmid: 11462232].
264 ACLU and PUBPAT ask Supreme Court to rule that patents on breast cancer genes are invalid. [press release]. New York. American Civil Liberties Union. September. 25. 2012.
265 Association for Molecular Pathology v Myriad Genetics. 569 US 12-398. 2013.
266 Myriad Genetics Laboratory. BRACAnalysis®: Hereditary Cancer Testing for Hereditary Breast and Ovarian Cancer. Salt Lake City, UT. Myriad Genetics Laboratory. 2013. Accessed at https://www.myriad.com/products/bracanalysis/ on. 26 November 2013.
267 Cook-Deegan R, DeRienzo C, Carbone J, et al. Impact of gene patents and licensing practices on access to genetic testing for inherited susceptibility to cancer: comparing breast and ovarian cancers with colon cancers. Genet Med. 2010;12(4 Suppl):S15-38. [pmid: 20393305].
268 Centers for Disease Control and Prevention. Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing—Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. MMWR Morb Mortal Wkly Rep. 2004;53(27):603-6. [pmid: 15254451].
269 Myers MF, Chang MH, Jorgensen C, et al. Genetic testing for susceptibility to breast and ovarian cancer: evaluating the impact of a direct-to-consumer marketing campaign on physicians' knowledge and practices. Genet Med. 2006;8(6):361-70. [pmid: 16778598].
270 Lowery JT, Byers T, Axell L, et al. The impact of direct-to-consumer marketing of cancer genetic testing on women according to their genetic risk. Genet Med. 2008;10(12):888-94. [pmid: 19092441].
271 Mouchawar J, Laurion S, Ritzwoller DP, et al. Assessing controversial direct-to-consumer advertising for hereditary breast cancer testing: reactions from women and their physicians in a managed care organization. Am J Manag Care. 2005;11(10):601-8. [pmid: 16232001].
272 Mouchawar J, Hensley-Alford S, Laurion S, et al. Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005;7(3):191-7. [pmid: 15775755].
273 Cortesi L, Turchetti D, Marchi I, et al. Breast cancer screening in women at increased risk according to different family histories: an update of the Modena Study Group experience. BMC Cancer. 2006;6:210. [pmid: 16916448].
274 Leach MO. Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: a prospective multicentre cohort study (MARIBS). Lancet. 2005;365(9473):1769-78. [pmid: 15910949].
275 Rijnsburger AJ, Essink-Bot ML, Van Dooren S, et al. Impact of screening for breast cancer in high-risk women on health-related quality of life. Br J Cancer. 2004;91(1):69-76. [pmid: 15199386].
276 Le-Petross HT, Whitman GJ, Atchley DP, et al. Effectiveness of alternating mammography and magnetic resonance imaging for screening women with deleterious BRCA mutations at high risk of breast cancer. Cancer. 2011;117(17):3900-7. [pmid: 21365619].
277 Kriege M, Brekelmans CT, Boetes C, et al. Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med. 2004;351(5):427-37. [pmid: 15282350].
278 Rijnsburger AJ, Obdeijn IM, Kaas R, et al. BRCA1-associated breast cancers present differently from BRCA2-associated and familial cases: long-term follow-up of the Dutch MRISC screening study. J Clin Oncol. 2010;28(36):5265-73. [pmid: 21079137].
279 Bourne TH, Campell S, Reynolds KM, et al. Screening for early familial ovarian cancer with transvaginal ultrasonography and colour blood flow imaging. BMJ. 1993;306(3884):1025-9. [pmid: 8490496].
280 Buys SS, Partridge E, Black A, et al. Effect of screening on ovarian cancer mortality: the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening randomized controlled trial. JAMA. 2011;305(22):2295-302. [pmid: 21642681].
281 Hermsen BB, Olivier RI, Verheijen RH, et al. No efficacy of annual gynaecological screening in BRCA1/2 mutation carriers: an observational follow-up study. Br J Cancer. 2007;96:1335-42. [pmid: 17426707].
282 King MC, Wieand S, Hale K, et al. Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2 National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) breast cancer prevention trial. JAMA. 2001;286(18):2251-6. [pmid: 11710890].
283 Nelson HD, Fu R, Humphrey L, et al. Comparative Effectiveness of Medications to Reduce Risk of Primary Breast Cancer in Women. Rockville, MD. Agency for Healthcare Research and Quality. 2009. [pmid: 20704040].
284 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005;97(22):1652-62. [pmid: 16288118].
285 Powles TJ, Ashley S, Tidy A, et al. Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. 2007;99(4):283-90. [pmid: 17312305].
286 Veronesi U, Maisonneuve P, Rotmensz N, et al. Tamoxifen for the prevention of breast cancer: late results of the Italian randomized tamoxifen prevention trial among women with hysterectomy. J Natl Cancer Inst. 2007;99(9):727-37. [pmid: 17470740].
287 Cuzick J, Forbes JF, Sestak I, et al. Long-term results of tamoxifen prophylaxis for breast cancer—96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. 2007;99(4):272-82. [pmid: 17312304].
288 Lippman ME, Cummings SR, Disch DP, et al. Effect of raloxifene on the incidence of invasive breast cancer in postmenopausal women with osteoporosis categorized by breast cancer risk. Clin Cancer Res. 2006;12(17):5242-7. [pmid: 16951244].
289 Vogel VG, Costantino JP, Wickerham DL, et al. Update of the National Surgical Adjuvant Breast and Bowel Project Study of Tamoxifen and Raloxifene (STAR) P-2 Trial: preventing breast cancer. Cancer Prev Res (Phila). 2010;3(6):696-706. [pmid: 20404000].
290 Hartmann LC, Schaid DJ, Woods JE, et al. Efficacy of bilateral prophylactic mastectomy in women with a family history of breast cancer. N Engl J Med. 1999;340(2):77-84. [pmid: 9887158].
291 Hartmann LC, Sellers TA, Schaid DJ, et al. Efficacy of bilateral prophylactic mastectomy in BRCA1 and BRCA2 gene mutation carriers. J Natl Cancer Inst. 2001;93(21):1633-7. [pmid: 11698567].
292 Domchek SM, Friebel TM, Singer CF, et al. Association of risk-reducing surgery in BRCA1 or BRCA2 mutation carriers with cancer risk and mortality. JAMA. 2010;304(9):967-75. [pmid: 20810374].
293 Evans DG, Baildam AD, Anderson E, et al. Risk reducing mastectomy: outcomes in 10 European centres. J Med Genet. 2009;46(4):254-8. [pmid: 18996907].
294 Skytte AB, Cruger D, Gerster M, et al. Breast cancer after bilateral risk-reducing mastectomy. Clin Genet. 2011;79(5):431-7. [pmid: 21199491].
295 Hartmann JT, Von Vangerow A, Fels LM, et al. A randomized trial of amifostine in patients with high-dose VIC chemotherapy plus autologous blood stem cell transplanation. Br J Cancer. 2001;84(3):313-20. [pmid: 11161394].
296 Olson JE, Sellers TA, Iturria SJ, et al. Bilateral oophorectomy and breast cancer risk reduction among women with a family history. Cancer Epidemiol Biomarkers Prev. 2004;28(5):357-60. [pmid: 15542261].
297 Kriege M, Brekelmans CT, Boetes C, et al. Differences between first and subsequent rounds of the MRISC breast cancer screening program for women with a familial or genetic predisposition. Cancer. 2006;106(11):2318-26. [pmid: 16615112].
298 Spiegel TN, Esplen MJ, Hill KA, et al. Psychological impact of recall on women with BRCA mutations undergoing MRI surveillance. Breast. 2011;20(5):424-30. [pmid: 21612928].
299 Barrett-Connor E, Mosca L, Collins P, et al. Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125-37. [pmid: 16837676].
300 Contant CM, Menke-Pluijmers MB, Seynaeve C, et al. Clinical experience of prophylactic mastectomy followed by immediate breast reconstruction in women at hereditary risk of breast cancer (HB(O)C) or a proven BRCA1 and BRCA2 germ-line mutation. Eur J Surg Oncol. 2002;28(6):627-32. [pmid: 12359199].
301 Metcalfe KA, Esplen MJ, Goel V, et al. Psychosocial functioning in women who have undergone bilateral prophylactic mastectomy. Psychooncology. 2004;13(1):14-25. [pmid: 14745742].
302 Brandberg Y, Sandelin K, Erikson S, et al. Psychological reactions, quality of life, and body image after bilateral prophylactic mastectomy in women at high risk for breast cancer: a prospective 1-year follow-up study. J Clin Oncol. 2008;26(24):3943-9. [pmid: 18711183].
303 Gahm J, Wickman M, Brandberg Y. Bilateral prophylactic mastectomy in women with inherited risk of breast cancer—prevalence of pain and discomfort, impact on sexuality, quality of life and feelings of regret two years after surgery. Breast. 2010;19(6):462-9. [pmid: 20605453].
304 Brandberg Y, Arver B, Johansson H, et al. Less correspondence between expectations before and cosmetic results after risk-reducing mastectomy in women who are mutation carriers: a prospective study. Eur J Surg Oncol. 2012;38(1):38-43. [pmid: 22032910].
305 Wasteson E, Sandelin K, Brandberg Y, et al. High satisfaction rate ten years after bilateral prophylactic mastectomy: a longitudinal study. Eur J Cancer Care. 2011;20(4):508-13. [pmid: 20597955].
306 Finch A, Metcalfe KA, Chiang JK, et al. The impact of prophylactic salpingo-oophorectomy on menopausal symptoms and sexual function in women who carry a BRCA mutation. Gynecol Oncol. 2011;121(1):163-8. [pmid: 21216453].
307 Antoniou AC, Beesley J, McGuffog L, et al. Common breast cancer susceptibility alleles and the risk of breast cancer for BRCA1 and BRCA2 mutation carriers: implications for risk prediction. Cancer Res. 2010;70(23):9742-54. [pmid: 21118973].
308 Antoniou AC, Kartsonaki C, Sinilnikova OM, et al. Common alleles at 6q25.1 and 1p11.2 are associated with breast cancer risk for BRCA1 and BRCA2 mutation carriers. Hum Mol Genet. 2011;20(16):3304-21. [pmid: 21593217].
309 Milne RL, Antoniou AC. Genetic modifiers of cancer risk for BRCA1 and BRCA2 mutation carriers. Ann Oncol. 2011;22(Suppl 1):i11-7. [pmid: 21285145].
310 Osorio A, Milne RL, Alonso R, et al. Evaluation of the XRCC1 gene as a phenotypic modifier in BRCA1/2 mutation carriers. Results from the consortium of investigators of modifiers of BRCA1/BRCA2. Br J Cancer. 2011;104(8):1356-61. [pmid: 21427728].
311 Rebbeck TR, Mitra N, Domchek SM, et al. Modification of BRCA1-associated breast and ovarian cancer risk by BRCA1-interacting genes. Cancer Res. 2011;71(17):5792-805. [pmid: 21799032].
312 Fanale D, Amodeo V, Corsini LR, et al. Breast cancer genome-wide association studies: there is strength in numbers. Oncogene. 2012;31(17):2121-8. [pmid: 21996731].
313 Peng S, Lü B, Ruan W, et al. Genetic polymorphisms and breast cancer risk: evidence from meta-analyses, pooled analyses, and genome-wide association studies. Breast Cancer Res Treat. 2011;127(2):309-24. [pmid: 21445572].
314 Ripperger T, Gadzicki D, Meindl A, et al. Breast cancer susceptibility: current knowledge and implications for genetic counselling. Eur J Hum Genet. 2009;17(6):722-31. [pmid: 19092773].
315 van der Groep P, van der Wall E, van Diest PJ. Pathology of hereditary breast cancer. Cell Oncol (Dordr). 2011;34(2):71-88. [pmid: 21336636].
316 Graeser MK, Engel C, Rhiem K, et al. Contralateral breast cancer risk in BRCA1 and BRCA2 mutation carriers. J Clin Oncol. 2009;27(35):5887-92. [pmid: 19858402].
317 Kirova YM, Stoppa-Lyonnet D, Savignoni A, et al. Risk of breast cancer recurrence and contralateral breast cancer in relation to BRCA1 and BRCA2 mutation status following breast-conserving surgery and radiotherapy. Eur J Cancer. 2005;41(15):2304-11. [pmid: 16140006].
318 Metcalfe K, Lynch HT, Ghadirian P, et al. Contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. J Clin Oncol. 2004;22(12):2328-35. [pmid: 15197194].
319 Weitzel JN, Robson M, Pasini B, et al. A comparison of bilateral breast cancers in BRCA carriers. Cancer Epidemiol Biomarkers Prev. 2005;14(6):1534-8. [pmid: 15941968].
320 Robertson L, Hanson H, Seal S, et al. BRCA1 testing should be offered to individuals with triple-negative breast cancer diagnosed below 50 years. Br J Cancer. 2012;106(6):1234-8. [pmid: 22333603].
321 Evans D, Gareth R, Lennard F, et al. Eligibility for magnetic resonance imaging screening in the United Kingdom: effect of strict selection criteria and anonymous DNA testing on breast cancer incidence in the MARIBS study. Cancer Epidemiol Biomarkers Prev. 2009;18(7):2123-31. [pmid: 19567506].
322 Statement of the American Society of Human Genetics on genetic testing for breast and ovarian cancer predisposition. Am J Hum Genet. 1994;55(5):i-iv. [pmid: 7977337].
323 American College of Obstetricians and Gynecologists, ACOG Committee on Practice Bulletins–Gynecology, ACOG Committee on Genetics, Society of Gynecologic Oncologists. ACOG Practice Bulletin No. 103: hereditary breast and ovarian cancer syndrome. Obstet Gynecol. 2009;113(4):957-66. [pmid: 19305347].
324 Balmaña J, Díez O, Rubio IT, et al. BRCA in breast cancer: ESMO clinical practice guidelines. Ann Oncol. 2011;22(Suppl 6):vi31-4. [pmid: 21908500].
325 Lancaster JM, Powell CB, Kauff ND, et al. Society of Gynecologic Oncologists Education Committee statement on risk assessment for inherited gynecologic cancer predispositions. Gynecol Oncol. 2007;107(2):159-62. [pmid: 17950381].
326 Riley BD, Culver JO, Skrzynia C, et al. Essential elements of genetic cancer risk assessment, counseling, and testing: updated recommendations of the National Society of Genetic Counselors. J Genet Couns. 2012;21(2):151-61. [pmid: 22134580].
327 Robson ME, Storm CD, Weitzel J, et al. American Society of Clinical Oncology Policy Statement Update: genetic and genomic testing for cancer susceptibility. J Clin Oncol. 2010;28(5):893-901. [pmid: 20065170].
328 Cuzick J. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002;360(9336):817-24. [pmid: 12243915].
329 Vogel VG, Costantino JP, Wickerham DL, et al. Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. JAMA. 2006;295(23):2727-41. [pmid: 16754727].
330 Andresen EM, Catlin TK, Wyrwich KW, et al. Retest reliability of surveillance questions on health related quality of life. J Epidemiol Community Health. 2003;57(5):339-43. [pmid: 12700216].
331 Bados A, Gómez-Benito J, Balaguer G. The State-Trait Anxiety Inventory, trait version: does it really measure anxiety?. J Pers Assess. 2010;92(6):560-7. [pmid: 20954057].
332 Bates GW, Trajstman SE, Jackson CA. Internal consistency, test-retest reliability and sex differences on the posttraumatic growth inventory in an Australian sample with trauma. Psychol Rep. 2004;94(3):793-4. [pmid: 15217029].
333 Baxter NN, Goodwin PJ, McLeod RS, et al. Reliability and validity of the body image after breast cancer questionnaire. Breast J. 2006;12(3):221-32. [pmid: 16684320].
334 Beck AT, Steer RA, Garbin MG. Psychometric properties of the Beck Depression Inventory: twenty-five years of evaluation. Clin Psychol Rev. 1988;8(1):77-100.
335 Bjelland I, Dahl AA, Haug TT, et al. The validity of the Hospital Anxiety and Depression Scale: an updated literature review. J Psychosom Res. 2002;52(2):69-77. [pmid: 11832252].
336 Lerman C, Trock B, Rimer BK, et al. Psychological side effects of breast cancer screening. Health Psychol. 1991;10(4):259-67. [pmid: 1915212].
337 Brehaut JC, O'Connor AM, Wood TJ, et al. Validation of a decision regret scale. Med Decis Making. 2003;23(4):281-92. [pmid: 12926578].
338 Carver CS, Scheier MF, Weintraub JK. Assessing coping strategies: a theoretically based approach. J Pers Soc Psychol. 1989;56(2):267-83. [pmid: 2926629].
339 Derogatis LR, Melisaratos N. The Brief Symptom Inventory: an introductory report. Psychol Med. 1983;13(3):595-605. [pmid: 6622612].
340 Grandner MA, Kripke DF, Yoon IY, et al. Criterion validity of the Pittsburgh Sleep Quality Index: investigation in a non-clinical sample. Sleep Biol Rhythms. 2006;4(2):129-36. [pmid: 22822303].
341 Hopwood P, Fletcher I, Lee A, et al. A body image scale for use with cancer patients. Eur J Cancer. 2001;37(2):189-97. [pmid: 11166145].
342 Jackson C. The General Health Questionnaire. Occup Med. 2007;57(1):79.
343 Matalqah LM, Radaideh KM, Yusoff ZM, et al. Health-related quality of life using EQ- 5D among breast cancer survivors in comparison with age-matched peers from the general population in the state of Penang, Malaysia. J Pub Health. 2011;19(5):475-80.
344 McHorney CA, Ware JE Jr, Lu JF, et al. The MOS 36-Item Short-Form Health Survey (SF-36), III: tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care. 1994;32(1):40-66. [pmid: 8277801].
345 Parkerson GR, Broadhead WE, Tse CK. Original contributions. Validation of the Duke Social Support and Stress Scale. Fam Med. 1991;23(5):357-60. [pmid: 1884930].
346 Radtke JV, Terhorst L, Cohen SM. The Menopause-Specific Quality of Life Questionnaire: psychometric evaluation among breast cancer survivors. Menopause. 2011;18(3):289-95. [pmid: 20881889].
347 Schmitz N, Hartkamp N, Kiuse J, et al. The Symptom Check-List-90-R (SCL-90-R): a German validation study. Qual Life Res. 2000;9(2):185-93. [pmid: 10983482].
348 Schroevers MJ, Sanderman R, Van Sonderen E, et al. The evaluation of the Center for Epidemiologic Studies Depression (CES-D) scale: depressed and positive affect in cancer patients and healthy reference subjects. Qual Life Res. 2000;9(9):1015-29. [pmid: 11332223].
349 Shapiro DE, Rodrigue JR, Boggs SR, et al. Cluster analysis of the Medical Coping Modes Questionnaire: evidence for coping with cancer styles?. J Psychosom Res. 1994;38(2):151-9. [pmid: 8189404].
350 Stanton AL, Kirk SB, Cameron CL, et al. Coping through emotional approach: scale construction and validation. J Pers Soc Psychol. 2000;78(6):1150-69. [pmid: 10870915].
351 Steed L. Further validity and reliability evidence for Beck Hopelessness Scale scores in a nonclinical sample. Educ Psychol Meas. 2001;61(2):303-16.
352 Stein KD, Jacobsen PB, Blanchard CM, et al. Further validation of the multidimensional Fatigue Symptom Inventory-Short Form. J Pain Symptom Manage. 2004;27(1):14-23. [pmid: 14711465].
353 Sullivan M, Karlsson J, Ware JE Jr. The Swedish SF-36 Health Survey, I: evaluation of data quality, scaling assumptions, reliability and construct validity across general populations in Sweden. Soc Sci Med. 1995;41(10):1349-58. [pmid: 8560302].
354 Thirlaway K, Fallowfield L, Cuzick J. The Sexual Activity Questionnaire: a measure of women's sexual functioning. Qual Life Res. 1996;5(1):81-90. [pmid: 8901370].
355 Wewers ME, Lowe NK. A critical review of visual analogue scales in the measurement of clinical phenomena. Res Nurs Health. 1990;13(4):227-36. [pmid: 2197679].
356 Zilberg NJ, Weiss DS, Horowitz MJ. Impact of Event Scale: a cross-validation study and some empirical evidence supporting a conceptual model of stress response syndromes. J Consult Clin Psychol. 1982;50(3):407-14. [pmid: 7096742].