# DISCUSSION

## Summary of Review Findings

A summary of the findings of the systematic review and meta-analysis is provided in Table 24. No studies directly addressed the overarching question regarding the effectiveness of risk assessment, genetic counseling, and genetic testing in reducing cancer incidence and mortality (key question 1).

Table 24 Summary of Evidence

Studies, n | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Key Question 1. Does risk assessment, genetic counseling, and genetic testing lead to reduced incidence of BRCA-related cancer and reduced cause-specific and all cause mortality?
No studies | NA | NA | NA | NA | NA | NA
Key Question 2a. What is the accuracy of methods to assess familial cancer risk for BRCA-related cancer when performed by a nongenetics specialist in a clinical setting? Key Question 3a. What are the potential adverse effects of risk assessment?
Systematic review of 13 general risk models; 10 studies of 5 familial risk models; no studies of the accuracy of referral criteria or adverse effects of risk assessment. | Diagnostic accuracy; cohort; case-control | Reference standards and study designs varied across studies; risk was based on self-reported information. | Consistent | High | Good | General risk models that predict risk for breast cancer, such as the Gail, are modest predictors for individuals (c-statistic, 0.55 to 0.65). Familial risk models (FHAT, Manchester, RST, PAT, and FHS-7) predict risk for BRCA mutations, are intended to guide referrals to genetic counseling, and have high accuracy (c-statistic, >0.80).
Key Question 2b, 3b. What are the benefits and potential adverse effects of genetic counseling for determining eligibility for genetic testing for BRCA-related cancer?
16 studies of distress, accuracy of risk perception, and intention for genetic testing. | RCT, cohort, case-control, before-after | Noncomparable comparison groups; small studies; outcome measures varied. | Consistent | High | Fair | Counseling decreased cancer worry, anxiety, and depression; increased the accuracy of risk perception; and decreased intention for mutation testing.
Key Question 2c. What is the clinical validity of genetic testing for deleterious mutations in women with increased risk for BRCA-related cancer?
32 new and 38 earlier studies provided data for meta-analysis estimates to determine the likelihood of BRCA mutations in women in specific risk populations (prevalence) and their chances of developing breast or ovarian cancer based on results of genetic testing (penetrance). | Cohort, cross-sectional, descriptive studies | Studies are heterogeneous; laboratory techniques differed; no studies outside high-risk populations; bias in estimates; no studies in women with variants of uncertain significance. | Consistent | Moderate | Fair | Prevalence is 0.2%-0.3% in general populations: 3% women with breast cancer, 6% women with breast cancer onset age ≤40, 10% women with ovarian cancer, and 20% high-risk families; for Ashkenazi Jewish women, 2% in unselected populations and 10% high-risk families. Positive test results indicate risks for breast cancer to age 70 of 46%-70% for BRCA1 and 50%-71% for BRCA2; for ovarian cancer, 41%-46% for BRCA1 and 17%-23% for BRCA2; in Ashkenazi Jewish women, 34% for breast cancer and 21% for ovarian cancer. Uninformative negative test results are associated with increased risk for breast cancer (SIR, 3.81 [95% CI, 3.06 to 4.75]), while true negative results are not (SIR, 1.13 [95% CI, 0.81 to 1.58]); estimates for ovarian cancer were highly heterogeneous.
Key Question 3c. What are the potential adverse effects of genetic testing?
13 studies of distress measures and risk perception | Cohort; case-control; before-after | No studies of other outcomes; high loss to followup; comparison groups and measures varied. | Mixed | High | Fair | Breast cancer worry and anxiety increased for women with positive results and decreased for others, although results differed across studies. Risk perception improved after receiving test results.
Key Question 4. Do interventions reduce the incidence of BRCA-related cancer and mortality in women with increased risk?
Intensive screening: no effectiveness studies | NA | NA | NA | NA | NA | NA
Risk-reducing medications: systematic review; 6 placebo-controlled trials (4 tamoxifen, 2 raloxifene) and 1 head-to-head trial (STAR) | RCT | No results for BRCA mutation carriers; trials are heterogeneous and data are lacking on doses, duration, and timing of use. | Consistent | Moderate | Good | Tamoxifen and raloxifene reduced invasive breast cancer by 30%-68% compared with placebo; reduction was greater for women with family history of breast cancer, but confidence intervals were overlapping. Reduction was significant for ER+ but not ER- cancer. Noninvasive breast cancer and mortality were not significantly reduced.
Risk-reducing surgery: 4 studies of mastectomy and 3 of oophorectomy or salpingo-oophorectomy | Cohort | Comparison groups varied. | Consistent | High | Fair | For high-risk women and mutation carriers, mastectomy reduced breast cancer 85%-100% and breast cancer mortality 81%-100%; salpingo-oophorectomy reduced breast cancer 37%-100%, ovarian cancer 69%-100%, and all-cause mortality 55%-100%.
Key Question 5. What are the potential adverse effects of interventions to reduce risk for BRCA-related cancer?
Intensive screening: 3 studies of physical harms of breast cancer screening and 2 studies of anxiety; 1 study of physical harms of ovarian cancer screening | Cohort | No RCTs; screening intervals and false-positive calculations varied between studies; some studies lacked within-cohort comparison groups. | Consistent | High | Poor | False-positive rates, unnecessary imaging, and unneeded surgeries were higher for women undergoing intensive screening for breast and ovarian cancer. Most women experienced no anxiety after screening with MRI, mammography, or clinical breast examination, although women recalled had transient anxiety.
Risk-reducing medications: no studies provided results by mutation status; 1 systematic review; 6 placebo-controlled trials (4 tamoxifen, 2 raloxifene) and 1 head-to-head trial | RCT | No results for BRCA mutation carriers; trials are heterogeneous and data on long-term effects are incomplete. | Consistent | High | Good | Tamoxifen and raloxifene increased thromboembolic events compared with placebo. Tamoxifen increased endometrial cancer and cataracts compared with raloxifene. Both caused undesirable side effects for some women.
Risk-reducing surgery: 5 studies of complications, physical effects, or distress | Case-series; before-after studies | Lack of studies; small numbers of participants; no comparison groups. | NA | Low | Poor | Some women experienced physical complications of surgery, had postsurgical symptoms, or changes in body image. Some women had improved anxiety.

Abbreviations: BC = breast cancer; FHAT = Family History Assessment Tool; MRI = magnetic resonance imaging; NA = not applicable; OC = ovarian cancer; PAT = Pedigree Assessment Tool; RCT = randomized, controlled trial; RST = Referral Screening Tool; SIR = standardized incidence rate; STAR = Study of Tamoxifen and Raloxifene.

Several studies of the accuracy of methods to assess familial risk for BRCA-related cancer by nongenetics specialists met inclusion criteria for key question 2a, but no studies met criteria for key question 3a regarding potential adverse effects (Figure 7). Although various clinical criteria for referral to genetic counseling have been developed, their accuracy in predicting mutation or cancer risk has not been evaluated. A published systematic review of studies of 13 general breast cancer risk models, such as the Gail model, indicated that they are modest predictors of individual risk (c-statistic, 0.55 to 0.65). Ten studies evaluated the accuracy of five familial risk models that predict risk specifically for BRCA mutations and are intended to guide referrals to genetic counseling. These include the FHAT, Manchester Scoring System, RST, PAT, and FHS-7. Results indicated high accuracy (c-statistic, >0.80), although some models have only been evaluated in single studies. Reference standards and study designs varied across studies, limiting comparisons between models. Risk was most often based on self-reported information; thus, the accuracy of risk models was limited by the accuracy of reported family history in each study.

Figure 7 Summary of Key Questions 2a, 3a and 2b, 3b

Figure 7 is a summary of key questions 2a and 3a and 2b and 3b. A flow diagram shows a series of events. Women without cancer or known deleterious BRCA mutations undergo an assessment of their familial cancer risk per key questions 2a and 3a. They are determined to be either at no increased risk or increased risk for BRCA mutations. If they are at increased risk, they undergo genetic counseling per key questions 2b and 3b. They are determined to be either at no increased risk or increased risk for BRCA mutations. If they are at increased risk, they undergo genetic testing. A table shows key question 2a, which is about the accuracy of risk assessment. Risk models are shown alongside their discriminatory accuracy (c statistic). General risk models have a discriminatory accuracy rate of 0.55 to 0.65 for breast cancer risk, and models do predict mutation risk. Family history models have a >0.80 rate of discriminatory accuracy for mutation risk. For key question 3a on the adverse effects of risk assessments, no studies answered this question. For key questions 2b and 3b on the benefits and adverse effects of genetic counseling, for breast cancer worry, 0 studies showed an increase, 8 studies showed a decrease, and 9 showed so significant difference; for anxiety, 0 studies showed an increase, 5 studies showed a decrease, and 8 showed no significant difference; for depression, 0 studies showed an increase, 1 study showed a decrease, and 6 showed no significant difference; for risk perception accuracy, 15 studies showed an increase, 2 studies showed a decrease, and 5 showed no significant difference, and for intention to test, 1 study showed an increase, 4 studies showed a decrease, and 0 showed a significant difference.

KQ 2a. Accuracy of Risk Assessment
Risk Models | Discriminatory Accuracy (c statistic)
Referral criteria | No studies
General risk models | 0.55−0.65 for breast cancer risk; models do predict mutation risk
Family history models | >0.80 for mutation risk
KQ 3a. Adverse Effects of Risk Assessment
No studies

KQs 2b, 3b. Benefits and Adverse Effects of Genetic Counseling
Measure | Number of Studies
Measure | Increase | Decrease | NS
Breast cancer worry | 0 | 8 | 9
Anxiety | 0 | 5 | 8
Depression | 0 | 1 | 6
Risk accuracy | 15 | 2 | 5
Intention to test | 1 | 4 | 0

NS = differences between counseled/noncounseled groups or before/after counseling are not statistically significant

A new systematic review and several new RCTs and cohort, case-control, and before-after studies of distress, accuracy of risk perception, and intention for genetic testing evaluated benefits and harms of genetic counseling (key questions 2b and 3b). No studies reported increased measures of breast cancer worry after women received genetic counseling; seven studies reported decreased worry, while one study reported no changes. Also, no studies reported significant increases in anxiety or depression after receiving genetic counseling, while three studies reported significant decreases and three reported no changes. In most studies, anxiety and depression scores were below clinical thresholds.

Eight new studies reported that the accuracy of a woman's perception of her breast cancer risk improved after genetic counseling. Two new studies reported decreased intention to undergo genetic testing after genetic counseling. The new studies expand and support the results of 11 studies included in the previous evidence review (Figure 7). Studies were limited by differences in their designs and measures, use of dissimilar comparison groups, and enrollment of small numbers of women from specialty clinics.

Key question 2c concerns how consistently and accurately BRCA mutation status predicts risk for BRCA-related cancer (clinical validity). To address this question, 31 new cohort, cross-sectional, and descriptive studies were combined with 39 earlier studies for meta-analysis estimates of the prevalence and penetrance of BRCA mutations in various groups of women (Figure 8). Prevalence varied by population, including 0.2 to 0.3 percent in unselected women; 1.8 percent for BRCA1 and 1.3 percent for BRCA2 in women with breast cancer; 6 percent in women with breast cancer onset at age 40 years or younger; 4.4 percent for BRCA1 and 5.6 percent for BRCA2 in women with ovarian cancer; and 13.6 percent for BRCA1, 7.9 percent for BRCA2, and 19.8 percent for combined BRCA1 and BRCA2 in women with high-risk families. In Ashkenazi Jewish women, prevalence was 2.1 percent in unselected populations and 10.2 percent in those with high-risk families.

Figure 8 Summary of Key Questions 2c and 3c

Abbreviations: BC = breast cancer; OC = ovarian cancer.

Figure 8 is a summary of key questions 2c and 3c. A flow diagram shows a series of events. Women at increased risk for deleterious mutations are referred for genetic testing per key questions 2c and 3c. If genetic testing shows a BRCA mutation is detected, if they have a variant of uncertain significance, or if they are determined to be of uninformative negative status, they are referred for interventions. If they are determined to be of true negative status, no further tests or interventions occur. A table shows key question 2c and the clinical validity of genetic testing by population and mutation prevalence in two side-by-side columns. The table also shows, in two columns, the relationship between test results and the chance of cancer (mutation penetrance). The table also shows key question 3 and the adverse effects of genetic testing by measures used, and the number of studies using each measure.

KQ 2c. Clinical Validity of Genetic Testing
Population | Mutation Prevalence | | Test Result | Chance of Cancer (mutation penetrance)
Unselected | 0.2%−0.3% | | Positive | % to age 70 or 75 yrs
High-risk | | | 1 person tested | BRCA1:46% BC;41%OC BRCA2: 50% BC; 17% OC
Breast or ovarian cancer onset <40yrs | BRCA1:4.3% BRCA2:2.9% Combined: 6.0% | | >1 person tested | BRCA1: 70% BC; 46% OC BRCA2: 71 % BC; 23% OC
Breast cancer cohort | BRCA1: 1.8% BRCA2:1.3% | | Ashkenazi Jewish | Combined: 34% BC; 21% OC
Ovarian cancer cohort | BRCA1:4.4% BRCA2:5.6% | | Variant of Unknown Significance | No studies
Family history of breast or ovarian cancer | BRCA 1:13.6% BRCA2:7.9% Combined: 19.8% | | Negative | Standardized incidence rate
Ashkenazi Jewish | | | Uninformative | Breast: 3.81 (3.06−3.32) Ovarian: 0.85−11.6
Unselected | BRCA1:1% BRCA2:1% Combined: 2.1% | | True | Breast: 1.28(0.79−2.01) Ovarian: 0−4.6
Family history of breast or ovarian cancer | BRCA1:6.4% BRCA2:1.1% Combined: 10.2%

KQ 3c. Adverse Effects of Genetic Testing
Measure | Number of Studies
Measure | Increase | Decrease | NS
Breast cancer worry | 4 | 1 | 0
Anxiety | 5 | 3 | 4
Depression | 1 | 1 | 4

NS = Differences between counseled/noncounseled groups or before/after counseling are not statistically significant.

In high-risk women with positive test results, risk for breast cancer to age 70 years included 46 to 70 percent for BRCA1 and 50 to 71 percent for BRCA2; risk for ovarian cancer was 41 percent for BRCA1 and 17 percent for BRCA2 (Figure 8). In Ashkenazi Jewish women, risk to age 75 years was 34 percent for breast cancer and 21 percent for ovarian cancer. No estimates are available for women with variants of uncertain significance. In women with uninformative negative test results, the SIR for breast cancer was 3.81 (95% CI, 3.06 to 4.75). In women with true negative test results, the SIR for breast cancer was 1.13 (95% CI, 0.81 to 1.58). Estimates for ovarian cancer were highly heterogeneous. Limitations included differences between laboratory techniques for research and clinical care, lack of studies outside of high-risk populations, and bias in estimates from women or families with cancer.

Studies of potential adverse effects of genetic testing (key question 3c) reported that breast cancer worry and anxiety increased for women with positive results and decreased for others, although results differed (Figure 8). Risk perception improved after receiving test results. Studies were limited by high loss to followup and differences between comparison groups. Other relevant outcomes were not studied, including false-negative or false-positive results, genetic discrimination, and insurability.

Interventions to reduce the incidence of BRCA-related cancer and mortality in women with increased risk include intensive screening, risk-reducing medications, and risk-reducing surgery (key question 4). No trials evaluated the effectiveness of intensive screening. Although no trials of risk-reducing medications specifically in women who are BRCA mutation carriers were available, several RCTs that included women with various levels of risk are relevant. Tamoxifen and raloxifene reduced invasive breast cancer by 30 to 68 percent compared with placebo, and tamoxifen had a greater effect than raloxifene in a head-to-head trial (Figure 9). Results suggested that reduction was greater in women with more relatives with breast cancer, but CIs overlapped. Reduction was significant for ER-positive but not ER-negative breast cancer. Noninvasive breast cancer and mortality were not significantly reduced and did not differ between medications. Trials were limited by heterogeneity and data were lacking on doses, duration, and timing of use.

Figure 9 Summary of Key Questions 4 and 5

Abbreviations: CA-125 = cancer antigen-125; MRI = magnetic resonance imaging; RRM = risk-reducing mastectomy; RRSO = risk-reducing salpingo-oophorectomy; TVUS = transvaginal ultrasound.

Figure 9 summarizes the evidence for key questions 4 and 5. It shows the analytic framework starting at genetic testing with one arrow leading to a box that describes three possible results of testing: BRCA mutation detected, variant of uncertain significance, or uninformative negative. An arrow connects these possible genetic test results to a box that describes the clinical health outcomes of reduced incidence of BRCA-related cancer and reduced cancer-specific and all-cause mortality via the use of interventions, which are the subject of key questions 4 and 5. A second arrow from genetic testing leads to a fourth possible result of testing: true negative. There is no further action beyond that result. Below and to the left of the analytic framework is a table labeled “KQ 4: Benefits of Interventions.” Below and to the right of the analytic framework is a table labeled “KQ 5: Adverse Effects of Interventions.”

KQ 4. Benefits of Interventions
Intervention | Risk Reduction
Intensive Screening | No effectiveness studies
Risk-Reducing Medications
Invasive breast cancer | 30%−68%^*^
Ovarian cancer | No significant reduction
Mortality | No significant reduction
Risk-Reducing Surgery
Breast cancer | RRM: 85%−100%; RRSO:37%−100%^†^
Ovarian cancer | RRSO:S9%−100%
Mortality | RRM: 81%−100%breastcancer; RRSO: 55%−100% all-cause

KQ 5. Adverse Effects of Interventions
Intervention | Rates
Intensive Screening (per episode or year)
False-positive | 4.6%−15% mammogram; 8.2%−14% MRI;3.4%TVUS
Recall | 3.9% mammogram; 11%MRI
Unneeded biopsy | 27%−28% mammogram; 25%−43% MRI; 100%TVUS^‡^; 67%CA−125^‡^
Risk-Reducing Medication (over 5 years)
Venous thrombosis | 0.4%−0.7%
Endometrial cancer | Tamoxifen: 0.4%
Risk-Reducing Surgery
Complications | RRM: 3%−59%; RRSO: no studies
Symptoms | RRM: 64%−87%; RRSO: no studies
Quality of life | RM: decrease anxiety; sexual RRSO: decrease sexual

* Risk reduction for all women; analysis by family history was similar.

† Includes studies of oophorectomy alone.

‡ Includes some women with symptoms.

For high-risk women and women who are mutation carriers, observational studies indicated that risk-reducing bilateral mastectomy reduced breast cancer by 85 to 100 percent, and oophorectomy or salpingo-oophorectomy reduced breast cancer by 37 to 100 percent and ovarian cancer by 69 to 100 percent. Breast cancer–specific mortality was reduced by 81 to 100 percent after risk-reducing mastectomy in one study, and all-cause mortality was reduced by 55 to 100 percent after risk-reducing salpingo-oophorectomy in another. Comparison groups varied between studies, although results were consistent.

Studies of the potential adverse effects of intensive screening for breast cancer (key question 5) indicated that false-positive rates, unnecessary imaging, and unneeded surgery were higher in women undergoing intensive screening using MRI compared with mammography (Figure 9). In one study, most women experienced no anxiety after breast cancer screening with MRI, mammography, or clinical breast examination. Studies of ovarian cancer screening reported high unneeded diagnostic surgery rates after screening with TVUS and serum CA-125 testing.

Trials of risk-reducing medications indicated that tamoxifen and raloxifene increased thromboembolic events compared with placebo and tamoxifen had a greater effect than raloxifene. Tamoxifen increased endometrial cancer and cataracts. Both caused undesirable side effects for some women, such as vasomotor symptoms.

Case-series and before-after studies described surgical complications, physical effects, and distress measures related to risk-reducing surgery. Some women experienced physical complications of surgery, postsurgical symptoms, or changes in body image, while some women had improved anxiety. Studies lacked important outcomes, and the few available studies had small numbers of participants and no comparison groups.

## Limitations

Limitations of this review include using only English-language articles and studies applicable to the United States, although this focus improves its relevance to the USPSTF recommendation. Also, the number, quality, and applicability of studies evaluated in the evidence review varied widely. Limitations of studies specific to each key question are briefly described in Table 24.

Most studies in this review were conducted in highly-selected samples of women, many with preexisting breast or ovarian cancer, from high-risk groups, or from previously identified kindreds. How the results of studies based on these highly-selected women in research settings translate to a general screening population is unknown. In some cases, data to determine penetrance came exclusively from one study, and when multiple studies were available, they were heterogeneous. Estimates may therefore be unreliable. Most studies used research laboratory techniques to detect clinically significant mutations that differ from the DNA sequencing available clinically. The clinical significance of mutations was determined by each study, and was based on likely functional significance and/or previous evidence of increased cancer risk.

Data are not available to determine the optimal age at which to test and how age at testing influences benefits and harms. Whether testing for BRCA mutations reduces cause-specific or all-cause mortality and improves quality of life is unknown. The harms associated with receiving a false-negative test result or a result indicating mutations of unknown significance are not known.

The systematic review focused on five key questions that limited its scope. Several relevant issues were not addressed. These include the impact of modifier genes on estimates of penetrance307-311 and estimates for cancer susceptibility genes other than BRCA1 and BRCA2.^312-315^ The prevalence of BRCA1 and BRCA2 mutations outside of U.S. or European populations was also not evaluated. Indications for testing in women who have previously been diagnosed with breast or ovarian cancer, or estimation of their risk of contralateral breast cancer,201,316-319 were not considered because the review focused on women without cancer. For example, women with triple-negative (i.e., HER2-negative, ER-negative, and PR-negative) breast cancer may be more likely to carry BRCA1 mutations.320 Also, the review did not consider indications for use of the BRCA Rearrangement Test as an adjunct to standard clinical testing, an emerging practice in the United States. The clinical utility of genetic testing is determined by outcomes following testing. Clinical utility was not explicitly included in the key questions, although the review considered use of risk-reducing interventions after genetic testing. Most studies relating to clinical utility are descriptive case-series and important outcomes are lacking. Finally, men were not included in the scope of this review except as family members of the women under evaluation.

Evidence of harms often relied on observational studies with designs that lacked quality rating criteria. Existing studies show that most women do not experience adverse effects from BRCA risk assessment, counseling, and testing. However, the long-term impact is unknown because most studies followed patients for less than 1 year. Studies used several types of measures and scales that limited comparisons between studies and prohibited meta-analysis. Measures of anxiety or depression often lacked clinical thresholds, and when available, few studies reported results based on the number of individuals who met them. No studies measured genetic discrimination as a harm of testing.

Treatment effects are influenced by several factors that were not evaluated in studies. The effectiveness of salpingo-oophorectomy in reducing risk for breast cancer depends on the age at which the procedure is performed, and it becomes less effective when performed after menopause. However, it is not clear how and when the benefit/harm ratio shifts for individuals facing this decision. Also, the type of risk-reducing intervention selected by women who are mutation carriers may depend on the specific mutation; for example, women with BRCA1 mutations have a higher risk of ovarian cancer than those with BRCA2 mutations. Medications are most effective in reducing risk for ER-positive breast tumors, although they have not been specifically evaluated in women with BRCA mutations. The proportion of ER-positive tumors varies from 28 percent in women with BRCA1 mutations to 63 percent in women with BRCA2 mutations. How these factors influence patient decisionmaking and eventual clinical outcomes is unknown.

## Emerging and Future Research

In order to determine the appropriateness of risk assessment and testing for BRCA mutations in primary care, more information is needed about mutation prevalence and impact in the general population. Research has focused on highly-selected women in referral centers and generally reported short-term outcomes. Issues such as access to testing; effectiveness of screening approaches, including risk stratification; use of system supports; and patient acceptance and education require additional study. Who should perform risk assessment and genetic counseling services, how it should be done, and what skills are needed are unresolved questions. Trials comparing types of providers and protocols could address these issues. What happens after patients are identified as high-risk in clinical settings is also unknown. The consequences of genetic testing for individuals and their relatives require more study. Well-designed investigations that use standardized measures and enroll subjects who reflect the general population, including minority women, are needed.

An expanded database or registry of patients who receive genetic counseling and testing for BRCA mutations would provide essential information about predictors of cancer, response to interventions, and other modifying factors. Traditionally, all clinical testing through direct DNA sequencing in the United States was done by a single private laboratory, and patient data were inaccessible. Developing a centralized accessible database with key variables to address these issues as testing practices change in the wake of the recent U.S. Supreme Court decision on DNA patents265 would be a major advance in this field. Additional data from women of varying socioeconomic, racial, and ethnic groups are needed. Currently available risk prediction tools and interventions may not apply to these populations.

Additional research on interventions is needed. Without effectiveness trials of intensive screening, practice standards have preceded supporting evidence. For example, while intensive screening with annual TVUS and serum CA-125 testing is recommended for high-risk women, there are no trials of screening effectiveness, and a descriptive study of 3,532 European women who were at increased risk of ovarian cancer, receiving TVUS and serum CA-125 testing, and followed for up to 16 years indicated no stage shifts in disease incidence.321 Trials of risk-reducing medications in women who are mutation carriers that include aromatase inhibitors, evaluation of the effect of age at intervention on outcomes, and measurement of long-term outcomes are also needed. Comparisons of salpingo-oophorectomy versus more limited surgery would inform current practice. Studies of factors related to acceptance of risk-reducing interventions based on genetic information would be useful, such as determining if cancer incidence in relatives is reduced because they adopt risk-reducing interventions. This information could improve patient decisionmaking and lead to better health outcomes.

## Conclusions

Risk assessment by nongenetics specialists using familial risk models to determine individual risks for BRCA mutations can accurately guide referrals for genetic counseling. Comprehensive risk evaluations by genetic counselors provide estimates of individual risks for mutations and identify optimal candidates for genetic testing. Genetic counseling reduces distress, improves patients' risk perception, and reduces their intentions for genetic testing. Results of genetic testing provide estimates of an individual's chances of developing BRCA-related cancer depending on the specific test results. Women with positive test results have a 34 to 71 percent chance of developing breast cancer and 17 to 41 percent chance of developing ovarian cancer by age 70 years. Estimates for women with variants of uncertain significance are not available. Women with uninformative negative results have nearly a four-fold increase in risk for breast cancer; those with true negative results have no increased risk for breast cancer, while estimates for ovarian cancer are uncertain.

Although intensive screening for breast and ovarian cancer with MRI, TVUS, and serum CA-125 testing are recommended by experts for women who are mutation carriers, their effectiveness has not been evaluated. Intensive breast cancer screening with MRI increases sensitivity, but also causes more false-positive results and procedures; screening for ovarian cancer is not accurate and leads to more procedures. Tamoxifen and raloxifene reduce risk for breast cancer in women with varying levels of risk, but increase risk for thromboembolic events. Tamoxifen also increases risk for endometrial cancer. Risk-reducing mastectomy and salpingo-oophorectomy are effective in reducing breast and ovarian cancer in women who are mutation carriers and high-risk women.

The process of familial risk assessment by nongenetics specialists, referral and evaluation by genetic counselors, genetic testing, and use of intensive screening and risk-reducing medications and surgeries is complex. Each step of the pathway requires careful interpretation of information, consideration of future risks, and shared decisionmaking before moving on to the next step. Services must be well integrated and highly individualized in order to optimize benefits and minimize harms for patients as well as their families. Additional studies are necessary to better inform practice.