# RESULTS

We reviewed 5,268 references from electronic searches, reference lists, and manual searches of recently published studies. After applying inclusion and exclusion criteria, we reviewed 1,600 full-text papers. Of these, 140 provided data addressing one or more of the key questions and were included in the systematic review. Appendix B5 shows the results of our literature search and selection process and Appendix B6 lists the excluded full-text papers. Included studies and quality ratings are in Appendixes C1 to C4.

## Key Question 1 Does Risk Assessment, Genetic Counseling, and Genetic Testing Lead to Reduced Incidence of BRCA-Related Cancer and Reduced Cause-Specific and All-Cause Mortality?

No studies addressed the overarching issues of key question 1.

## Key Question 2a What Is the Accuracy of Methods to Assess Familial Cancer Risk for BRCA-Related Cancer When Performed by a Nongenetics Specialist in a Clinical Setting?

## Key Question 3a What Are the Potential Adverse Effects of Risk Assessment?

### Summary

Several studies of risk stratification methods for nongenetics specialists met inclusion criteria for key question 2a, but no studies met criteria for key question 3a regarding potential adverse effects. The sensitivity of self-reported family cancer history in first-degree relatives varied between 65 and 82 percent for breast cancer and was 50 percent for ovarian cancer in validation studies, although specificity was greater than 90 percent. Referral criteria have been developed by several groups, but their accuracy has not been evaluated. A published systematic review of studies of 13 general breast cancer risk models and 11 studies of five familial risk models provided accuracy measures. Reference standards varied across studies, limiting comparisons between methods. General breast cancer risk models, such as the Gail model, are modest predictors for individuals (c-statistic, 0.55 to 0.65). Familial risk models, including the Ontario Family History Assessment Tool (FHAT), Manchester Scoring System, Referral Screening Tool (RST), Pedigree Assessment Tool (PAT), and FHS-7, predict risk specifically for BRCA mutations and are intended to guide referrals to genetic counseling. Studies indicated high accuracy for these models (c-statistic, >0.80), although some models have only been evaluated in single studies.

### Evidence

This key question focuses on the evaluation of a patient's individual familial risk for BRCA-related cancer in a clinical setting by a nongenetics specialist for the purpose of initiating appropriate referrals for more comprehensive evaluations by genetic counselors and other specialists. These methods of risk stratification and referral differ from those intended for comprehensive evaluations. Risk models have been developed that predict the probability of developing breast cancer or the likelihood of having a mutation. Although the mutation probability is linked to family history, BRCA mutations explain only a small proportion of the familial aggregation of breast cancer, and even less of the hereditable variance in risk in a population.

#### Determination of Family History

Family history of BRCA-related cancer is important in estimating individual risk for a BRCA1 or BRCA2 mutation in women without cancer or known family mutations. Among women with first-degree relatives with cancer, the relative risk for cancer has been estimated in meta-analyses as 2.1 (95% CI, 2.0 to 2.2) for breast cancer43 and 3.1 (95% CI, 2.6 to 3.7) for ovarian cancer.106 Decisions about referral, testing, and risk-reducing interventions are often based on self-reports of family histories that include type of cancer, relationship within the family, and age of onset. Appropriate decisions rely on family histories that are accurately reported by women and correctly obtained by clinicians.

The accuracy of family cancer history information was determined in studies that validated self-reported family histories with medical records. In one study, a report of breast cancer in a first-degree relative of a healthy individual had a sensitivity of 82 percent, specificity of 91 percent, positive likelihood ratio of 8.9 (95% CI, 5.4 to 15.0), and negative likelihood ratio of 0.20 (95% CI, 0.08 to 0.49).107 A more recent population-based study in the United States indicated the accuracy of self-reported breast cancer history in a first-degree relative as 64.9 percent sensitivity and 99.0 percent specificity.108 In this study, the accuracy for first-degree relatives was higher than for second-degree relatives. For ovarian cancer, a report of ovarian cancer in a first-degree relative was less reliable than for breast cancer, and had a sensitivity of 50 percent, specificity of 99 percent, positive likelihood ratio of 34.0 (95% CI, 5.7 to 202.0), and negative likelihood ratio of 0.51 (95% CI, 0.13 to 2.10).107

#### Referral Guidelines

Referral guidelines have been developed by health maintenance organizations,109 professional organizations,51,92 cancer programs,50,110 State and national health programs,111-113 and investigators114 to assist nongenetics specialists in identifying women who are at potentially increased risk for BRCA mutations. Although specific items vary among the guidelines, most include questions about personal and family history of BRCA mutations, breast and ovarian cancer, age at diagnosis, bilateral breast cancer, and Ashkenazi Jewish ancestry. Most guidelines are intended to lead to a referral for more extensive genetic evaluations and counseling, not directly to testing. Although guidelines vary, practice and coverage standards in the United States generally follow the NCCN referral criteria for genetic counseling (described in Appendix A1).50 The effectiveness of this approach in improving breast cancer outcomes has not been evaluated.

#### General Risk Stratification Models to Predict Individual Risk for Breast Cancer in Primary Care Settings

Although used in clinical settings, general risk stratification models predicting individual risk for breast cancer were not developed to identify women with increased probabilities of BRCA mutations.

A recent systematic review115,116 included 19 studies117-137 evaluating 13 risk stratification models to identify women with increased risk for breast cancer (Table 3). Models specifically evaluating risk for BRCA1 and BRCA2 mutations were outside the scope of this review and were not included.

Table 3 Risk Stratification Models

Model | Included variables | | | | | | Calibration expected/observed cases (95% CI)^*^ | Discriminatory accuracy c-statistic (95% CI)^*^
Model | Age, y | Menarche age, y | Age at birth of first child, y | First-degree relatives with breast cancer, n | Previous breast biopsy, n | Other factors | Calibration expected/observed cases (95% CI)^*^ | Discriminatory accuracy c-statistic (95% CI)^*^
Gail Model Variations
Gail-2 5-year risk | <50; ≥50 | ≥14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; 1; ≥2 | Bx: 0; 1; ≥2 AH: 0; ≥1 | Not included | 1.03 (0.88 to 1.21);126 0.94 (0.89 to 0.99);132 0.96 (0.84 to 1.17);127 0.79;^123^ 1.12^121^ | 0.55 (0.51 to 0.60);117 0.60;^126^ 0.58 (0.56 to 0.60);119 0.58;^132^ 0.59 (0.54 to 0.63);127 0.60;^122^ 0.61 (0.60 to 0.62)135
Gail-2 10-year risk | <50; ≥50 | ≥14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; 1; ≥2 | Bx: 0; 1; ≥2 AH: 0; ≥1 | Not included | 0.69 (0.54 to 0.90)133 | 0.74 (0.67 to 0.80)118
African American Gail 5-year risk | <50; ≥50 | ≤13; >13 | Not included | 0; 1; ≥2 | Bx: 0; 1; ≥2 | African American race | 1.08 (0.97 to 1.20)129 | 0.56 (0.54 to 0.58);129 0.56 (0.51 to 0.60)117
Models with Breast Density
Chen 5-year risk | <50; ≥50 | ≥14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; 1; ≥2 | Bx: 0; 1; ≥2 | Breast density (%), BMI | Not reported | 0.64^122^
BCSC^†^ (premenopausal) 1-year risk | 45–84 by 5-year groups | Not included | Not included | 0; 1; ≥2; unknown | Bx: yes; no; unknown | Breast density (BIRADS)^‡^ | 1.00^119^ | 0.63 (0.60 to 0.66)119
BCSC^†^ (postmenopausal) 1-year risk | 45–84 by 5-year groups | Not included | <30; ≥30; none; unknown | 0; 1; ≥2; unknown | Bx: 0; ≥1; unknown | Breast density (BIRADS), prior false-positive mammogram, BMI, menopause type, HT, race/ethnicity | 1.01^119^ | 0.62 (0.62 to 0.63)119
BCSC 5-year risk | 45–84 by 5-year groups | Not included | Not included | Yes; no | Bx: yes; no | Breast density (BIRADS), race/ethnicity | 1.01 (0.99 to 1.03)135 | 0.66 (0.65 to 0.66)135
Other Models
Rosner-Colditz^†^ | <50; ≥50 | 14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | Yes; no | Not included | BMI, benign breast disease, menopause type, menopause age, HT use and duration, height, alcohol use, parity | 1.00 (0.93 to 1.07)133 | 0.57 (0.55 to 0.59);133 0.64 (0.63 to 0.66) (ER+/PR+);125 0.61 (0.58 to 0.64) (ER-/PR-)125
Rosner-Colditz-2^†^ | <50; ≥50 | 14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | Yes; no | AH: 0; ≥1 | Benign breast disease presence or type | 1.01 (0.94 to 1.09)133 | 0.63 (0.61 to 0.65);133 0.64 (type)133
Tyrer-Cuzick 10-year risk | <50; ≥50 | ≤12; >12 | ≤30; >30; none | 1; 2; ≥2 | Bx: 0; 1; ≥2 LCIS: 0; ≥1 | BMI, height, menopause age, family history of ovarian/other cancer, age of cancer onset, bilateral or male breast cancer | 1.09 (0.85 to 1.41)118 | 0.76 (0.70 to 0.82);118 0.54 (0.42 to 0.65)120
Italian-1^§^ 5-year risk | <50; ≥50 | ≥14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; 1; ≥2 | Not included | Age of relative at diagnosis, diet score, alcohol use, BMI, HT, physical activity | 1.04^121^ | 0.59 (vitamin);121 0.60 (diet)121
Italian-2^†^ 20-year risk | <50; ≥50 | 14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; 1; ≥2 | Bx: 0; 1; ≥2 | Occupational and leisure physical activity, education, alcohol use, BMI | Not reported | 0.62 (0.56 to 0.69) (age <50 years);131 0.57 (0.52 to 0.61) (age ≥50 y)131
Chlebowski 5-year risk | 50–59; 60–69; 70–79 | ≥14; 12–13; ≤12 | <20; 20–24; 25–29 or none; ≥30 | 0; ≥1 | Bx: 0; 1; ≥2 | BMI,menopause age, HT use and duration, race, alcohol use, parity, breastfeeding, smoking status, physical activity | Not reported | 0.61 (0.59 to 0.63);123 0.62 (0.60 to 0.64) (ER+);123 0.53 (0.47 to 0.58) (ER-)123
Chlebowski-simplified 5-year risk | <50; ≥50 | Not included | Not included | 0; ≥1 | Bx: 0; 1; ≥2 | Not included | Not reported | 0.58 (0.56 to 0.60) (ER+)123

* For invasive breast cancer, other outcomes are specifically indicated.

† Invasive and noninvasive breast cancer.

‡ BI-RADS categories include: 0 = unknown; 1 = entirely fat; 2 = scattered fibroglandular densities; 3 = heterogeneously dense; 4 = extremely dense.

§ Includes an Italian population and used incidence rates from the Italian Multicenter case-control study of Diet and Breast Cancer and from Italian cancer registries.

Abbreviations: AH = atypical hyperplasia; BCSC = Breast Cancer Surveillance Consortium; BI-RADS = Breast Imaging Reporting and Data System; BMI = body mass index; Bx = biopsy; CI = confidence interval; DCIS = ductal carcinoma in situ; ER- = estrogen receptor negative; ER+ = estrogen receptor positive; HT = hormone therapy; LCIS= lobular carcinoma in situ; PR- = progesterone receptor negative; PR+ = progesterone receptor positive.

Most general risk models are based on the Breast Cancer Risk Assessment Tool, also referred to as the Gail model. This model was derived from multivariate logistic regression analysis of identified risk factors for breast cancer,128 and subsequently modified with Surveillance Epidemiology and End Results data.126 Subsequent models use a similar approach, but vary in their use of reference standards and included variables. The original Gail model included age, age at menarche, age at first birth, family history of breast cancer in first-degree relatives, number of prior breast biopsies, and history of atypical hyperplasia.128 Subsequent models include one or more of these variables in addition to other factors (Table 3).

Most models accurately predict breast cancer incidence in populations of women. For most models in the studies, the expected numbers of cases of breast cancer closely matched the observed numbers (calibration: estimated/observed [E/O], 0.90 to 1.10).119,121-124,126,127,129,135,136 However, they are only modestly accurate in predicting breast cancer risk for individuals. In studies, discriminatory accuracy was expressed as concordance statistics, determined by the area under the receiver-operating characteristic curve (c-statistic). Values ranged from 0.55 to 0.65 across the studies,117-124,126,127,129,131-135 which is comparable to age alone as a predictor.

#### Familial Risk Stratification Models to Predict Individual Risk for BRCA Mutations in Primary Care Settings

Familial risk stratification models for BRCA-related cancer are primarily intended for use by nongenetics specialists to guide patient referrals to genetic counselors for more definitive evaluations. Several models have been developed and evaluated, including the FHAT, Manchester Scoring System, RST, PAT, and FHS-7. Ten studies describing performance characteristics of these models met inclusion criteria for this review (Table 4, Appendix C5).56, 138-146 Included studies met criteria for fair or good quality and compared the referral models to validated risk assessment models, including BRCAPRO, Claus, Myriad, BOADICEA, Tyrer-Cuzick, and Penn II. Studies of the RST, PAT, and FHS-7 were published after the previous USPSTF systematic review.

Table 4 Familial Risk Stratification Models to Predict Individual Risk for Deleterious BRCA Mutations in Primary Care Settings

Model | Data collection and calculation | Relatives with breast and ovarian cancer | Other factors | Reference standard | Performance characteristics for predicting risk for BRCA mutations
Ontario Family History Assessment Tool (FHAT)142,144-146 | Clinical scoring tool; referral threshold of 10 is equivalent to a 2-fold relative risk for breast or ovarian cancer | 1st-, 2nd-, 3rd- degree | Age at diagnosis; bilateral breast cancer; breast and ovarian cancer in same person; male breast cancer; colon and prostate cancer | BRCAPRO; Claus | Sensitivity 91%–94%; specificity 15%–51%; PPV 31%; c statistic 0.68–0.83
Manchester Scoring System56,139,141,144-146 | Clinical scoring tool; referral if ≥2 positive responses | 1st-, 2nd-, 3rd- degree | Type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, and age at diagnosis | BRCAPRO; Myriad II; BOADICEA; FHAT | Sensitivity 58%–93%; specificity 33%–71%; c statistic 0.75–0.80
Referral Screening Tool (RST)140 | Clinical scoring tool; referral if ≥2 positive responses | 1st-, 2nd- degree | Breast cancer at age ≤50 (self or relatives); ovarian cancer at any age (self or relatives); ≥2 breast cancer cases at age >50 on same side of family; male breast cancer; Jewish ancestry | BRCAPRO; Myriad II; BOADICEA; FHAT | Sensitivity 81%; specificity 92%; PPV 0.80; NPV 0.92; c statistic 0.87
Pedigree Assessment Tool (PAT)143 | Clinical scoring tool; score ≥8 was optimal threshold | 1st-, 2nd-, 3rd- degree | Breast cancer at age ≤50 or >50; ovarian cancer at any age; male breast cancer; Ashkenazi Jewish ancestry | Myriad II | Sensitivity 100%; specificity 93%; PPV 0.63; NPV 1.00; c statistic 0.96 (compared with Gail 5-year 0.39; Gail lifetime 0.59)
FHS-7^138^ | Clinical scoring tool; one positive response was threshold | 1st-degree with breast or ovarian cancer | Any relatives with breast cancer at age ≤50; bilateral breast cancer; breast and ovarian cancer in same person; male breast cancer; ≥2 relatives with breast and/or ovarian cancer; ≥2 relatives with breast and/or colon cancer | Claus; Gail; Tyrer-Cuzick; Penn II | Sensitivity 88%; specificity 56%; PPV 0.63; NPV 1.00; c statistic 0.96

Abbreviations: BOADICEA = Breast and Ovarian Analysis of Disease Incidence and Carrier Estimation Algorithm; NPV = negative predictive value; PPV = positive predictive value.

FHAT. The FHAT is a 17-question instrument developed to assist Canadian clinicians in selecting patients for referral to genetic counseling.142 The referral threshold is equivalent to doubling the general population lifetime risk for breast or ovarian cancer (22%). In the FHAT, points are assigned according to the number of relatives, third-degree or closer, who are diagnosed with breast, ovarian, colon, or prostate cancer; age at diagnosis; and type of primary cancer and number of primary cancer cases. Patients with scores of 10 or more points warrant referral. FHAT results were compared with Claus and BRCAPRO estimates for 184 women with incident familial and nonfamilial breast cancer.142 The sensitivity and specificity of the FHAT for a clinically significant BRCA1 or BRCA2 mutation were 94 and 51 percent, respectively. This compares with sensitivity and specificity of 74 and 79 percent for a 20 percent threshold for having a clinically significant BRCA1 or BRCA2 mutation using BRCAPRO, and 74 and 54 percent using Claus methods. Additional validation studies of the FHAT have replicated its accuracy,145 and its concordance statistics range from 0.68 to 0.83 across a wide variety of conditions.144,146

Manchester Scoring System. The Manchester Scoring System was developed in the United Kingdom to predict BRCA1 or BRCA2 mutations at the 10 percent likelihood level.141 Points are assigned depending on type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, and age at diagnosis. The model provides scores for BRCA1 and BRCA2 mutations separately. The scoring system was validated in three sample sets in other regions of the United Kingdom and compared with other existing models. In validation studies, the Manchester model (combined BRCA1 and BRCA2) had 58 to 93 percent sensitivity, 33 to 71 percent specificity, and concordance statistics of 0.75 to 0.80, comparing well with the other models tested.56,139,141,144,145

RST. The RST was developed to help primary care clinicians make appropriate referrals for genetic counseling in response to the USPSTF 2005 recommendation.140 The RST is a clinical scoring tool that uses a checklist of risk information, including breast cancer at age 50 years or younger in self or relatives, ovarian cancer at any age in self or relatives, two or more breast cancer cases after age 50 years on the same side of the family, male breast cancer, and Jewish ancestry. The referral threshold is reached with two or more positive responses. It was designed for simplicity, and is the least complicated model to administer for screening purposes. In an evaluation study, the RST was administered to 2,464 unselected women undergoing screening mammography in a U.S. health care system.140 Results were compared against validated risk assessment models, including BRCAPRO, Myriad II, BOADICEA, and FHAT. The RST demonstrated a sensitivity of 81 percent, specificity of 92 percent, and concordance statistic of 0.87. A revised model is also available online.147

PAT. The PAT was also designed to identify women at increased risk for BRCA-related cancer in U.S. primary care settings.143 The PAT uses a point scoring system based on information from first-, second-, and third-degree relatives regarding breast cancer onset at ages younger or older than 50 years; ovarian cancer at any age; male breast cancer; and Ashkenazi Jewish ancestry. Performance characteristics were determined in a study of 3,906 women without cancer undergoing screening mammography at a U.S. community hospital.143 Results were compared against the Myriad II and Gail models. The PAT had optimal sensitivity of 100 percent and specificity of 93 percent at scores of 8 or more. The PAT had a concordance statistic of 0.96, which was much higher than results using the Gail 5-year (0.39) or lifetime estimate (0.59).

FHS-7. The FHS-7 is a seven-question instrument about family history of breast, ovarian, and colorectal cancer.138 It was developed as a simple instrument for primary care settings for screening and referral purposes. The questions include first-degree relatives with breast or ovarian cancer, any relatives age 50 years and younger with breast cancer, bilateral breast cancer, breast and ovarian cancer in the same person, male breast cancer, two or more relatives with breast and/or ovarian cancer, and two or more relatives with breast and/or colon cancer. A single positive response is the threshold for referral. In an evaluation study in Brazil, the FHS-7 was administered to 9,218 women during routine visits to primary care clinics. Results were compared with Claus, Gail, Tyrer-Cuzick, and Penn II models. The FHS-7 had a sensitivity of 88 percent, specificity of 56 percent, and concordance statistic of 0.96.^138^

## Key Questions 2b, 3b What Are the Benefits and Potential Adverse Effects of Genetic Counseling in Determining Eligibility for Genetic Testing for BRCA-Related Cancer?

### Summary

Sixteen new studies evaluated the benefits and harms of genetic counseling, including a systematic review; RCTs; and cohort, case-control, and before-after studies of distress, accuracy of risk perception, and intention for testing. Results indicated that counseling decreases cancer worry, anxiety, and depression; increases the accuracy of risk perception; and decreases intention for mutation testing. Face-to-face counseling was preferred in some studies. Limitations of studies included dissimilar comparison groups and small sizes.

### Evidence

Twenty-seven studies met inclusion criteria, including 16 published since the prior review148-165 and 11 included previously57-60,62,166-171 (Table 5, Appendix C6). Studies provided data about distress due to genetic counseling for BRCA-related cancer measured as worry, anxiety, or depression. Additional outcomes included intention for genetic testing and accuracy of risk perception. Results for key questions 2b and 3b are both presented in this section of the review because studies generally provided measures for both benefits and harms.

Table 5 Studies of Genetic Counseling

Author, year | N | Provider of genetic counseling | Setting | Measures | Quality rating | Breast cancer worry | | Anxiety | | Depression | | Risk perception | | Intent to participate in testing
Author, year | N | Provider of genetic counseling | Setting | Measures | Quality rating | Increase | Decrease | Increase | Decrease | Increase | Decrease | More Accurate | Less Accurate | Increase | Decrease
Current report
Bennett et al, 2008^150^ | 128 | Genetic counselor | Cancer Genetics Service Center | DUKE-SSQ, HADS, IES, MCMQ,NSI | NA | 0 | X | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Bennett et al, 2009^149^ | 128 | Genetic counselor | Cancer Genetics Service Center | DUKE-SSQ, IES, MCMQ | NA | 0 | X | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Bloom, 2006^151^ | 163 | Master's level counselor | Telephone counseling | NSI | Poor | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bowen et al, 2006^152^ | 221 | Psychologist, genetic counselor | University | NSI, BSI | Fair | 0 | 0 | NR | NR | NR | NR | 0 | 0 | NR | NR
Brain et al, 2011^153^ | 263 | Clinician | NR | CWS-R | NA | 0 | X^*^ | NR | NR | NR | NR | X^†^ | 0 | 0 | X^†^
Braithwaite et al, 2005^154^ | 72 | Clinical nurse specialist | NR | NSI, STAI, HADS | Fair | 0 | X | NR | NR | NR | NR | NR | NR | NR | NR
Fry et al, 2003^155^ | 263 | Genetics consultant & specialist breast surgeon vs. geneticist & genetics nurse specialist | Familial Breast Cancer Clinic | CWS | Fair | 0 | X^‡^ | 0 | X^§^ | NR | NR | X║ | 0 | NR | NR
Gurmankin et al, 2005^156^ | 125 | Health care provider | University breast and ovarian cancer risk evaluation program | STAI, NSI | NA | 0 | X | NR | NR | NR | NR | X | 0 | NR | NR
Helmes et al, 2006^157^ | 340^¶^ | Board certified genetic counselor | NR | NSI | Fair | NR | NR | NR | NR | NR | NR | X^‡^ | 0 | NR | NR
Hopwood et al, 2004^158^ | 256 | Genetic counselor | Cancer genetic service centers | NSI, GHQ, CWS | NA | 0 | X^**^ | NR | NR | NR | NR | X^**^ | 0 | 0 | X^**^
Kelly et al, 2008^159^ | 78 | Genetic counselor | NR | NSI | NA | 0 | X | 0 | 0 | NR | NR | 0 | 0 | NR | NR
Matloff et al, 2006^160^ | 64^¶^ | Certified genetic counselor | NR | NSI | Fair | NR | NR | NR | NR | NR | NR | 0 | X^‡^ | NR | NR
Mikkelsen et al, 2007^161^ | 1971 | Physicians | Clinical department | IES | Fair | NR | NR | NR | NR | NR | NR | X^††^ | 0 | NR | NR
Mikkelsen et al, 2009^162^ | 1971 | Physicians | Clinical department | HADS | Fair | NR | NR | NR | NR | NR | NR | 0^‡‡^ | 0 | NR | NR
Pieterse et al, 2011^163^ | 77^¶^ | Clinical geneticists, residents in clinical genetics, genetic counselors | Department of medical genetics | VAS, NSI, PPC, STAI, IES | NA | 0 | X | 0 | 0 | 0 | 0 | NR | NR | NR | NR
Roshanai et al, 2009^164^ | 163 | Specialist nurse | Cancer genetics clinic | SPIKES, HADS | Fair | NR | NR | 0 | X | NR | NR | X | 0 | NR | NR
Prior Report
Bowen et al, 2002^57^ | 354 | Genetic counselor or trained health counselor | NR | NSI | Fair | NR | NR | NR | NR | NR | NR | NR | NR | 0 | X
Bowen et al, 2004^62^ | 354 | Genetic counselor or trained health counselor | NR | NSI | Fair | NR | NR | NR | NR | NR | NR | NR | NR | 0 | X
Brain et al, 2002^166^ | 740^¶^ | Clinical geneticist and genetic nurse specialist | NR | STAI, NSI | Good | 0 | 0 | 0 | X | 0 | 0 | X | 0 | NR | NR
Burke et al, 2000^58^ | 356 | Genetic counselor | Medical office | NSI | Fair | X | X | 0 | X | NR | NR | X | 0 | NR | NR
Cull et al, 1998^59^,║║ | 144^¶^ | Geneticist and breast surgeon | Breast cancer family clinic | NSI, STAI, GHQ | Good | 0 | 0 | NR | NR | NR | NR | X | 0 | NR | X
Hopwood et al, 1998^167^ | 174 | Family history clinics | Family history clinics | NSI, GHQ, PAS | Fair | NR | NR | 0 | 0 | 0 | 0 | X^¶¶^ | X^***^ | NR | NR
Lerman et al, 1996^168^ | 227 | Genetic counselor | Cancer centers | IES | Fair | 0 | 0 | 0 | 0 | NR | NR | X | 0 | NR | NR
Lerman et al, 1999^60^ | 364 | Oncology nurses or genetic counselor | Hospital cancer center | IES | Fair | 0 | 0 | NR | NR | NR | NR | X | 0 | NR | NR
Lobb et al, 2004^169^ | 193 | Clinical geneticists, oncologist, genetic counselors | NR | NSI, IES, HADS | Good | 0 | 0 | NR | NR | NR | NR | NR | NR | X^†††^ | 0
Watson et al, 1998^171^ | 115 | Clinical geneticist | Hospitals | GHQ-12, CWS, VAS | Good | NR | NR | 0 | 0 | 0 | 0 | 0 | 0 | NR | NR
Watson et al, 1999^170^ | 283 | Clinical geneticists | Genetic counseling centers | NSI, GHQ, IES, STAI | Good | 0 | 0 | 0 | 0 | 0 | 0 | X^‡‡‡^ | 0 | NR | NR

X=significant relationship; 0=studied, but not significant; NA=rating criteria not available; NR=not reported.

* Both interventions vs. control.

† Both treatment groups vs. control.

‡ Pre vs. post.

§ Pre vs. post and A vs. B.

║ Counseling vs. GRACE.

¶ Randomized.

** Both intervention groups.

†† Time effect-change from pre to post.

‡‡ Interventions vs. control.

§§ At 2-week followup; NS by 8 months.

║║ Study done in a country other than the United States (e.g. Scotland, Australia, or England).

¶¶ Both treatment groups at treatment end.

*** Video after counseling subjects at 1-month followup.

††† African American subjects only.

‡‡‡ Risk provided as odds ratio.

Abbreviations: BSI = Brief Symptom Inventory; CWS = Cancer Worry Scale; GHQ = General Health Questionnaire; HADS = Hospital Anxiety and Depression Scale; IES = Impact of Event Scale; NR = not reported; NSI = nonstandard instrument; PAS = Psychiatric Assessment Schedule; PPC = Perceived Personal Control; SPIKES = Setting, Patient's perception, Invitation, Knowledge, Exploring/Empathy, Strategy/Summary; STAI = State-Trait Anxiety Inventory; VAS = Visual Analog Scale.

Eleven studies included in the previous review indicated that breast cancer worry usually decreased after genetic counseling, and women preferred personal contact over computer software or telephone counseling.57-60,62,166-171 Also, studies showed that measures of anxiety and depression generally decreased or did not differ with counseling.59,62,166,167,169-171 Risk perception was not well reported in previous studies and results were inconclusive.57-59,166-171 Studies also showed that women's intention to pursue genetic testing decreased after counseling.57,58,60

The new studies include one fair-quality systematic review,165 seven RCTs (six fair-quality152,154, 155,157,160,164 and one poor-quality151), one fair-quality prospective cohort study,161,162 one good-quality case-control study,148 and six studies with before-after designs for which quality rating criteria were not available.149,150,153,156,158,159,163 Limitations of studies included inadequate reporting of randomization technique,151,152,154,157,160,164 noncomparable groups at baseline,151,161, 162 and no specified eligibility criteria.151

Studies enrolled from 64 to 1,971 women with family histories of breast and ovarian cancer who were seeking genetic counseling and were potentially interested in receiving genetic testing for BRCA mutations. Several studies compared different types of genetic counseling152,154,155,157,164 and genetic counseling versus no counseling,148,151,160-162 while others compared outcomes before and after genetic counseling.149,150,153,156,158,159,163 The types of genetic counseling services provided are summarized in Table 6.

Table 6 Types of Genetic Counseling Provided in Included Studies

Author, year | Setting | Provider of genetic counseling | Components of genetic counseling
Current report
Armstrong et al, 2005^148^ | Not reported | Not reported | Genetic counseling not specified.
Bennett et al, 2008^150^ | Cancer Genetics Service Center | Genetic counselor | Women with family history of breast/ovarian cancer referred by general practitioner or other medical specialists into the service. After assessment of information in family health questionnaire by genetic specialists, individual genetic risk of developing familial breast and ovarian cancer was calculated as a percentage of lifetime risk and stratified into high, moderate, and population risk levels. Women considered high risk for breast/ovarian cancer were offered counseling, genetic testing, and annual mammography; woman at moderate risk were offered annual mammography.
Bennett et al, 2009^149^ | Cancer Genetics Service Center | Genetic counselor | See Bennett 2008.
Bloom et al, 2006^151^ | Telephone counseling | Master's level counselor | Telephone counseling session included: establishment of rapport and determination of special concerns, emotional readiness, risk notification by providing modified Gail model lifetime risk estimate and discussing in terms of pretest self-assessment of risk, deescalation of tension regarding breast cancer checkup, evaluation of coping skills, reinforcement of problem solving and coping skills, information on health protective behaviors, early detection through American Cancer Society screening, and information on genetic testing when requested.
Bowen et al, 2006^152^ | University | Psychologist, genetic counselor | Group psychological counseling: Psychologist led four 2-hour, weekly sessions of 5 to 6 women per group, with each session including a 20-min group cohesion activity followed by 1 of 4 major intervention components: risk assessment and perception, education, stress management, and problem solving and social support. Individual genetic counseling: Genetic counselor provided 1-hour counseling sessions and sessions covered several topics, including participant's family background, breast cancer risk assessment, BRCA1 and BRCA2 mutations in the Ashkenazi Jewish population, nongenetic risk factors for breast cancer, and breast screening.
Brain et al, 2011^153^ | Not reported | Clinician | Women with a family history of breast cancer receive a specialist genetic assessment service. Control group received general risk level (low/population, moderate, or high) based on age, reproductive history, and minimal family history; intervention group received a specific percentage based on Claus model based on detailed family pedigree; genetic testing was available to women in intervention group at high risk (≥25% risk).
Braithwaite et al, 2005^154^ | Not reported | Clinical nurse specialist | Risk counseling: Received pedigree with information from family history and assessed risk as low, moderate, or high based on GRACE guidelines; participants were mailed letters summarizing content afterward. GRACE: Completed pedigrees in GRACE and assessed their risk, learning their risk assessment and how to manage their risk; received a numerical estimate of lifetime risk, a visual display of cumulative risk with general population as comparator, and a qualitative description; clinical nurse specialists then offered to book mammography and arrange meetings with geneticists, where appropriate.
Fry et al, 2003^155^ | Familial Breast Cancer Clinic | Genetics consultant and specialist breast surgeon; geneticist and genetics nurse specialist | Standard (regional) service: Self-report family history and baseline questionnaire completed by all women; genetics consultant and genetics nurse specialist assigned categorical risk via Cancer Research Campaign. Women at low risk received a letter; women at moderate or high risk were offered an appointment at familiar breast cancer clinic where a genetics consultant discussed risk status and breast surgeon discussed risk management. Where appropriate, clinical exams and mammography were included in the appointment. Patients' general practitioners received summary data, and patients received followup questionnaires 4 weeks and 6 months later. Novel (community-based) service: All women sent an appointment for a community-based clinic near their residence. Meetings run by genetics nurse specialist where family history collected and compared to published criteria (Cancer Research Campaign) to determine risk. Women at low risk offered information, reassurance, and discharged. Women at increased risk (moderate or high) were offered an appointment at a regional center with a geneticist and genetics nurse specialist, and asked to complete followup questionnaires at 4 weeks and 6 months.
Gurmankin et al, 2005^156^ | University breast and ovarian cancer risk evaluation program | Health care provider | Precounseling interview: Assessed patient's breast cancer risk perception, BRCA mutation risk perception, worry about breast cancer, family history of cancer, breast cancer risk reduction behaviors, and demographic information. Postcounseling interview: Assessed patient's breast cancer risk, BRCA mutation risk, recall of actual risk information, and worry about breast cancer.
Helmes et al, 2006^157^ | Not reported | Board certified genetic counselor | In-person counseling: Review of family history, discussion of breast cancer risk, and education about breast cancer genes; discussed genetic testing considerations, including implications of results, testing strategies, potential risks and benefits of test, costs and psychological effects of test; gave information packet with personal risk information comparing woman's risk with average woman's risk, personal computer-drawn 3-generation pedigree, brochures on self-breast exams, Pap test, and mammography; genetics visual aids, and list of community resources. Telephone counseling: Information packet was sent in the mail with instructions to open at the beginning of the telephone counseling, which was identical in content and structure to in-person counseling.
Hopwood et al, 2004^158^ | Cancer genetic service centers | Genetic counselor | Genetic counseling prior to testing varied by participating center, but offered or recommended some of the following: risk estimation (based on molecular genetic analysis or more often on family history), genetic risk counseling, clinical exam, screening/surveillance for early tumor detection (mammography, endoscopy), information on preventive strategies (surgery, diet), family planning advice, and referral for psychological assessment/support.
Kelly et al, 2008^159^ | Not reported | Genetic counselor | Review of family cancer history, personal risk factors for breast and ovarian cancer, mechanisms of cancer inheritance, meaning of a positive and negative test result, and risks and benefits associated with testing.
Matloff et al, 2006^160^ | Not reported | Certified genetic counselor | Personalized letter summarizing patient data.
Mikkelsen et al, 2007^161^ | University clinical departments | Physicians | Information on incidence of sporadic breast cancer, genetics, inheritance patterns, and estimated personal lifetime risk of inherited cancer.
Mikkelsen et al, 2009^162^ | University clinical departments | Physicians | Information on incidence of sporadic breast cancer, genetics, inheritance patterns, and estimated personal lifetime risk of inherited cancer.
Pieterse et al, 2011^163^ | Department of medical genetics | Clinical geneticists, residents in clinical genetics, genetic counselors | Session topics included family's occurrence of breast and other cancers, inheritance, and criteria on probability of inherited breast cancer, and the likelihood of hereditary breast cancer running in the family was estimated.
Roshanai et al, 2009^164^ | University cancer genetic clinic | Specialist nurse | Included pedigree explanation, Buckman's Breaking Bad News model to inform at-risk relatives, pamphlet, videotape, copies of pedigree, and medical records.
Prior report
Bowen et al, 2002^57^ | Not reported | Genetic counselor or trained health counselor | Individual genetic counseling: Telephone contact with genetic counselor to review pedigree information and one 2-hour session following protocol based on standard genetic practice, with a letter sent to participant within 2 weeks summarizing the session. Group psychosocial counseling: Group of 4–6 participants met for four 2-hour sessions with trained health counselor, participants received risk assessment sheet, personalizing the group discussion to her own risk status, main topics: risk assessment, perception, screening, stress management and problem solving, social support.
Bowen et al, 2004^62^ | Not reported | Genetic counselor or trained health counselor | Individual genetic counseling: Telephone contact with genetic counselor to review pedigree information and one 2-hour session following protocol based on standard genetic practice, with a letter sent to participant within 2 weeks summarizing the session. Group psychosocial counseling: Group of 4–6 participants met for four 2-hour sessions with trained health counselor, participants received risk assessment sheet, personalizing the group discussion to her own risk status, main topics: risk assessment, perception, screening, stress management and problem solving, social support.
Brain et al, 2002^166^ | Not reported | Clinical geneticist and genetic nurse specialist | Breast cancer surveillance, option to enter UK Tamoxifen Prevention Trial, annual surgical followup with surveillance and advice, genetic risk assessment and counseling.
Burke et al, 2000^58^ | Unclear | Genetic counselor | Adapted genetic counseling protocol for women with intermediate risk included precounseling telephone call gathering a complete family history, in-person genetic counseling session discussing breast cancer risk factors, focusing on issues relevant to the participant, reviewed pedigree information, communicated likelihood of mutation in participant's family, risk estimate sheet given to participant based on the Gail and Claus models and National Cancer Institute statistics for average risk, information about genetic testing, recommendations for breast cancer screening, and a followup letter summarizing the genetic counseling session.
Cull et al, 1998^59^ | Breast cancer family clinic | Geneticist and breast surgeon | Individual meeting with geneticist to discuss individual risk and with breast surgeon to discuss risk management, participants either received a copy of the educational video about 10 days before the clinic consultation or took the video home after the postclinic assessment.
Hopwood et al, 1998^167^ | Family history clinics | Unclear | Family history consultation, not otherwise described.
Lerman et al, 1996^168^ | Comprehensive cancer centers | Genetic counselor | Discussion of individual factors contributing to elevated risk, presentation of individualized risk data, recommendations for annual mammography and clinical breast exams, and instruction in breast self-exam.
Lerman et al, 1999^60^ | Hospital and cancer center | Oncology nurses or genetic counselor | Education only: Topics discussed included individual risk factors for breast and ovarian cancer and patterns of inheritance for breast and ovarian cancer susceptibility, subjects given qualitative estimates of risk of developing breast and ovarian cancer, and pedigrees reviewed, potential benefits, limitations, and risks of genetic testing for inherited breast and ovarian cancer susceptibility reviewed. Education plus counseling: Provided the same education and materials described above and subjects were guided through questions exploring personal issues related to cancer and genetic testing, discussed the emotional impact of having a family history of cancer, psychosocial implications of genetic testing for inherited breast and ovarian cancer susceptibility, anticipated reactions to positive and negative test result, and intentions to communicate test results to family members and friends.
Lobb et al, 2004^169^ | Not reported | Clinical geneticists, oncologist, genetic counselors | Counselors provided counseling at their discretion and study was to assess the different aspects of counseling, which included information giving concerning: breast cancer genetics, genetic testing, family history and risk, prophylactic surgery, breast cancer prevention, screening and management; communication style including: facilitating patient involvement, facilitating understanding, patient centeredness and partnership building, and supportive and counseling communications.
Watson et al, 1998^171^ | Hospitals | Clinical geneticist | Consultation provided information on pedigree based on risk calculation and information regarding management options based on risk level, with instructions offered on self-exam and clinical exam, with the intervention group also receiving an audiotape of the consultation to take home.
Watson et al, 1999^172^ | Genetic counseling centers | Clinical geneticists | Not described.

Studies used the Cancer Worry Scale (CWS) and the State-Trait Anxiety Inventory (STAI) to measure breast cancer worry; the Hospital Anxiety and Depression Scale (HADS), Impact of Events Scale (IES), General Health Questionnaire (GHQ), and Visual Analogue Scale to measure anxiety and depression; and general Likert scales to measure intention to undergo genetic testing and risk perception. These are described in Table 7.

Table 7 Standardized Measures Used to Assess Distress

Measure | Abbreviation | Description
Beck Depression Inventory334 | BDI | A 21-question, multiple choice, self-report inventory for measuring the severity of depression. Scores of 0 to 9 indicate minimal depression, 10 to 18 mild depression, 19 to 29 moderate depression, and 30 to 63 severe depression.
Beck Hopelessness Scale351 | BHS | A 20-item scale to quantify hopelessness, with scores ranging from 0 to 20 and a score above 9 indicating suicidal ideations.
Body Image after Breast Cancer333 | BIBC | A 53-item questionnaire to assess the long-term impact of breast cancer on body image in 6 key areas: vulnerability, body stigma, limitations, body concerns, transparency, arm concerns.
Body Image Scale341 | BIS | A 10-item questionnaire for assessing body image changes in patients with cancer.
Brief Symptom Inventory339 | BSI | A 53-item self-reported psychological symptom scale.
Center for Epidemiologic Studies-Depression348 | CES-D | Measures symptoms of depression on a 20-item scale with scores ranging from 0 to 60; scores above 15 indicating high levels of depressive symptoms.
Coping Orientation to Problems Experienced Scale338 | COPE | Covers 14 coping strategies as potential responses to stressors.
Decision Regret Scale337 | DRS | A 5-item questionnaire to measure dissatisfaction or misgiving after making a medical decision.
DUKE Social Support Questionnaire345 | DUKE-SSQ | Used to measure access to and satisfaction with social support on 8 items with scores ranging from 1 to 5. Affective subscale (DUKE-SSQ-A) includes items 1, 2, and 8; confident subscale (DUKE-SSQ-C) includes items 3-7.
Emotional Approach Coping Scale350 | None | A 52-item questionnaire to measure both problem solving (items 1-20) and emotion-based (items 21-32) coping strategies. An additional 4 questions pertain to alcohol and drug use.
EuroQoL-5 Dimensions343 | EQ-5D | A short, self-reported questionnaire designed to evaluate an individual's state of overall health in 5 areas: mobility, self-care, usual activities, pain/discomfort, anxiety/depression.
General Health Questionnaire342 | GHQ | A 60-item questionnaire to screen individuals for psychiatric disorders, scores are given as means and scores above 3 indicate disorders; a 30-item version of the same questionnaire uses a threshold of 6 to indicate general psychological distress.
Health-Related Quality of Life330 | HR-QOL | A 14-item self-report questionnaire to assess an individual's quality of life based on healthy days (items 1-4), activity limitations (items 5-9), and symptoms (items 10-14).
Hospital Anxiety and Depression Scale335 | HADS | A 14-item self-report scale for the detection of depression and anxiety in hospitalized patients. Scores range from 1 to 21, interpreted as normal (0 to 7), mild (8 to 10), moderate (11 to 14), and severe (15 to 21). Subscales for anxiety (HADS-A) and depression (HADS-D).
Impact of Events Scale356 | IES | A 17-item questionnaire to measure an individual's level of distress in relation to a specific event or condition. Scores range from 0 to 75; scores 9 to 25 indicate moderate difficulties and above 26 indicate clinical adaptation difficulties. Several variations are also used: Impact of Events Scale-Revised (IES-R) 22-items (items A-V); Impact of Events Subscale-Intrusive Events (IES-I) (items a, b, c, f, i, n, p, t); Impact of Events Subscale-Avoidance (IES-A) (items e, g, h, k, l, m, q, v); Impact of Events Subscale-Hyperarousal (IES-H) (items d, j, o, r, s, u).
Lerman Breast Cancer Worry Scale336 | CWS or LCWS | A 3-item questionnaire to measure how frequently an individual worries about getting breast cancer and the impact of worrying on mood and performance of daily activities. A 6-item version of the same questionnaire has scores ranging from 6 to 24; higher scores mean greater levels of worry.
Medical Coping Modes Questionnaire349 | MCMQ | A 19-item self-report questionnaire to quantify coping styles into 1 of 4 categories: confrontive, avoidant, resigned, nondominant.
Medical Outcomes Study 36-Item Short Form344 Swedish Short Term-36 Health Survey353 | SF-36 or MOS SF-36 | A 36-question health questionnaire for measuring health and well-being in 8 core areas: physical functioning, role limitations due to physical health, bodily pain, general health perceptions, vitality, social functioning, role limitations due to emotional problems, mental health. The Swedish Short Term-36 Health Survey is one of many variations.
Menopause-Specific Quality of Life Questionnaire346 | MENQOL | A 29-item self-administered questionnaire to assess health-related quality of life postmenopause.
Multidimensional Fatigue Symptom Inventory-Short Form352 | MFSI-SF | A 30-item questionnaire to measures perceived sleep disturbance.
Pittsburgh Sleep Quality Index340 | PSQI | A measure of subjective sleep disturbance in clinical populations.
Post-Traumatic Growth Inventory332 | PTGI | An instrument for assessing positive outcomes reported by persons who have experienced traumatic events.
Sexual Activity Questionnaire354 | SAQ | A 3-section self-reported questionnaire to assess sexual functioning, including hormonal status, reasons for sexual inactivity, sexual functioning.
State-Trait Anxiety Inventory331 | STAI | Measures an individual's current anxiety feelings. Scores range from 10 to 40. Scores above 22 indicate high anxiety.
Symptom Checklist-90^347^ | SCL-90 | A 90-question self-reported questionnaire to assess psychological status in the following categories somatization, obsessive-compulsive, interpersonal sensitivity, depression, anxiety, hostility, phobic anxiety, paranoid ideation, psychoticism.
Visual Analogue Scale355 | VAS | Any of a number of pain self-assessment tools where subjects indicate their level of pain in response to a continuous visual scale (no pain to worst pain ever experienced).

#### Breast Cancer Worry

No studies reported increases in measures of breast cancer worry after women received genetic counseling; eight studies reported decreases,150,152-155,157,158,162 while one study reported no changes.151

A fair-quality RCT measuring worry with the CWS reported that women who received either in-person or telephone counseling had significant decreases in worry after counseling compared with the control group who did not receive counseling (mean decrease from baseline, 0.90 in-person vs. 0.82 telephone vs. 0.38 none; p=0.002).157 More women in the in-person counseling group felt they could discuss their concerns during counseling sessions compared with women who received telephone counseling (77.4% vs. 67.3%, respectively; p<0.05). Fewer women in the in-person counseling group said they would have preferred another type of counseling (14.9% vs. 37.0%, respectively; p<0.001).

A fair-quality RCT reported decreases in worry after both group and individual genetic counseling compared with a noncounseling control group (mean change from baseline, -0.7 group vs. -0.9 individual vs. +0.1 none; p<0.001).152 Another study comparing a computer intervention with an in-person counseling session reported significant decreases in both groups after counseling, with no differences between groups.154 Only one poor-quality RCT reported no significant difference in cancer worry after telephone counseling compared with a control group not receiving counseling, as measured on a three-item, 4-point Likert scale.151

A fair-quality prospective cohort study reported that more women receiving counseling experienced decreases in cancer-specific distress, as measured by the IES.162 The cancer-specific distress of women with counseling decreased more from baseline to 1 year postcounseling (from 52% to 41%) compared with high-risk women referred for mammography with no genetic counseling (from 41% to 35%), or with a random sample from the general population (from 32% to 30%) with no counseling.162 Although more women who had genetic counseling experienced a decrease in cancer-specific distress, this difference was only statistically significant when compared with women in the general population (p=0.006).

Similarly, two before-after studies, using a modified CWS, reported reductions in cancer worry after genetic counseling compared with baseline.153,158 One reported a reduction after 1 month, which became statistically significant after 1 year of followup (mean, 11.6 at baseline vs. 10.9 at 1 month vs. 10.8 at 1 year; p<0.001 for change from baseline to 1 year).158 While the other reported reductions after 9 months that remained after 6 years, they were not statistically significant (mean, 11.54 at baseline vs. 10.37 at 9 months vs. 10.35 at 6 years; p=0.29), and no statistically significant difference was observed in those who did not receive counseling (mean, 11.29 at baseline vs. 10.39 at 9 months vs. 10.65 at 6 years; p=0.44).153

One before-after study (in two publications) using the IES reported that women's levels of worry decreased over time from initial levels, particularly after they were informed of their risks.149,150 One fair-quality RCT reported significant reductions in cancer worry in women who were at moderate or high risk 6 months after genetic counseling compared with baseline, based on CWS scores.155 Reductions were also significant when compared with women who only attended initial in-person precounseling sessions.

#### Anxiety and Depression

No studies reported significant increases in anxiety and depression after receiving genetic counseling; three studies reported significant decreases in anxiety and depression,154,163,164 while three studies reported no changes.150,158,162

A good-quality RCT compared women receiving genetic counseling from a nurse specialist in addition to resources about informing at-risk relatives, a pamphlet, and a videotape versus women receiving the standard care given at the clinic, which was genetic counseling from a specialist nurse with no additional resources.164 Both groups reported significant decreases in mean anxiety and depression scores, as measured by the HADS, at 2 weeks and 8 months after counseling (p<0.01 over time). However, there were no significant differences between groups at any time point and none of the mean scores reached the clinical threshold (score of ≥8).

Another study reported significant decreases in mean anxiety scores, as measured by the STAI, from before genetic counseling, when scores indicated high anxiety (score >22), to immediately and 6 months after genetic counseling, when scores fell below the threshold for high anxiety (22.22 vs. 18.77 vs. 16.98, respectively; p<0.001).163 However, in a fair-quality RCT, anxiety scores at baseline indicated high anxiety and significantly increased from baseline to 3 months following counseling (Genetic Risk Assessment in the Clinical Environment [GRACE], 40.00 to 56.28 to 52.15 vs. counseling, 35.73 to 47.78 to 51.19; p<0.01 over time), as measured by the STAI.154 While participants' scores in the GRACE group improved slightly at followup, they never returned to their baseline levels.

No significant differences in anxiety or depression scores were found in a fair-quality cohort study comparing women receiving genetic counseling with a high-risk reference sample and a random sample from the general population.162 The number of women meeting clinical thresholds for anxiety and depression, as measured by the HADS, was low (<12% anxiety and <2% depression). However, slightly more women in the counseling group had moderate levels of distress, as measured by the IES (12% vs. 8%). A before-after study reporting anxiety outcomes from baseline to 1 year after genetic counseling also reported no significant differences, though all mean scores were above the clinical threshold for psychiatric disorders.158 In another before-after study, no significant changes in women's anxiety or depression scores were detected over time, regardless of their levels of risk.150 In this study, only baseline scores indicated mild anxiety, and followup scores were below the clinical threshold for anxiety, as measured by the HADS.150

#### Risk Perception

A fair-quality systematic review of 19 studies published before February 2007 reported results of studies of risk perception after genetic counseling.165 In these studies, risk perception was measured by changes in the proportion of women who accurately perceived their own risk, and by the degree of overestimation or underestimation of risk. Overall, the accuracy of risk perception increased from an average of 42 percent accuracy before counseling to 58 percent after counseling. Women who continued to overestimate their risks did so by approximately 18 percent (range, 6% to 40%), which was an improvement of approximately 8 percent after counseling. Seven studies indicated that counseling that delivered information about family history, heredity, and personal risk estimates positively influenced risk perception accuracy. Three of five studies showed significant improvement in risk accuracy when education about heredity was included, and three of six studies showed an improvement in risk accuracy when facilitating informed decisionmaking and adaptation to personal risk was part of counseling.

Eight studies published since 2004,^152,156-158,160,161,163,169^ including four cited in the 2007 published systematic review,152,156,158,169 were consistent in reporting improved accuracy of breast cancer risk perception after genetic counseling. One study reported less accuracy.153 These findings differ from the prior USPSTF review, in which results were inconclusive.57-59,166-171 The recent studies measured risk perception using subjects' self-rated lifetime risk of breast cancer compared with the general population (0- to 100-point scale), lifetime likeliness of developing breast cancer on a 5-point Likert scale, and comparisons between risk estimates of subjects and counselors.

A fair-quality RCT measuring perceived breast cancer risk on a 5-point scale and rating chances of diagnosis from 0 to 100 percent reported that women overestimated their risks of breast cancer by an average of 25 percentage points.151 The proportion of women underestimating their risks was larger among women with perceived lower risks (40%) than in those who perceived it as the same (16%), higher (10%), or much higher (5%) than the risks of other women (p=0.009). Women with the highest overestimations were more likely to improve their accuracy with counseling (p<0.0001), although counseling was effective in improving accuracy only in women age 50 years or younger (p=0.0040).

A fair-quality RCT reported no differences in risk accuracy between telephone and in-person counseling.157 Accuracy significantly improved over time for both groups (p<0.001), and was better than in a control group that did not receive genetic counseling (p<0.001).

A before-after study measured risk perception using a 5-point scale ranging from 1 (chances of breast cancer much lower than the average woman) to 5 (chances much higher than the average woman). There was a significant decrease from baseline to 1 week (mean, 4.29 vs. 3.83; p=0.00) and at 1 week compared with a control group (mean, 3.83 vs. 3.97; p=0.01). However, perception of risk increased at 9 months (mean, 3.99) and after 6 years (mean, 4.08), without returning to baseline levels.153

Only one before-after study assessed the accuracy of risk perception for developing ovarian cancer.159 In this study, all women underestimated their risks of developing ovarian cancer by 5 percent 6 months after counseling.

#### Intent to Participate in Genetic Testing

Two studies reported decreased intention to undergo genetic testing after genetic counseling.152, 157 A study comparing telephone counseling versus in-person counseling versus no counseling used a four-question measure to determine women's intentions to pursue genetic testing.157 Participants' combined baseline scores for their intention to pursue genetic testing was 2.22 and there were no significant differences between groups at baseline. After counseling, the control group had increased intention scores, while the two counseling groups had decreased scores (mean change from baseline, +0.51 control vs. -0.61 in-person vs. -0.52 telephone; p<0.001).

A fair-quality RCT reported decreased interests in genetic testing 6 months after group and individual counseling.152 Interests in testing for both counseling groups decreased significantly more than in the control group (mean decrease from baseline, 0.7 group vs. 0.6 individual vs. 0.2 control; p<0.01).

## Key Question 2c What Is the Clinical Validity of Genetic Testing for Deleterious Mutations in Women With Increased Risk for BRCA-Related Cancer?

### Summary

In the context of this key question, clinical validity is how consistently and accurately BRCA mutation status predicts risk for BRCA-related cancer. This review describes clinical validity using the measures of prevalence and penetrance of BRCA mutations. Thirty-two new cohort, cross-sectional, and descriptive studies were combined with 38 earlier studies for meta-analysis estimates of the prevalence and penetrance of BRCA mutations in various groups of women. Limitations include heterogeneity of studies, differences between laboratory techniques for research and clinical care, lack of studies outside of high-risk populations, bias in estimates from women or families with cancer, and no studies of penetrance in women with test results indicating variants of uncertain significance.

Prevalence is the frequency of BRCA mutations in the population. Estimates of prevalence in high-risk populations overestimate assumptions of prevalence in unselected populations, but inform an individual's likelihood of carrying a BRCA mutation and candidacy for testing. Estimates of the prevalence of BRCA mutations vary by population: 0.2 to 0.3 percent in unselected women; 1.8 percent for BRCA1 and 1.3 percent for BRCA2 in women with breast cancer; 6 percent in women with breast cancer onset at age 40 years or younger; 4.4 percent for BRCA1 and 5.6 percent for BRCA2 in women with ovarian cancer; and 13.6 percent for BRCA1, 7.9 percent for BRCA2, and 19.8 percent for both combined in women with high-risk families. For Ashkenazi Jewish women, prevalence is 2.1 percent in unselected populations and 10.2 percent in those with high-risk families.

Penetrance is the likelihood of developing breast or ovarian cancer for a given BRCA genotype, and is age dependent. Estimates of the penetrance of BRCA mutations differ by test result. In high-risk women with positive test results, risks for breast cancer to age 70 years include 46 percent for BRCA1 and 50 percent for BRCA2 when a single family member is tested, and 70 percent for BRCA1 and 71 percent for BRCA2 when multiple family members are tested. Risks for ovarian cancer to age 70 years in high-risk women with positive test results are 41 percent for BRCA1 and 17 percent for BRCA2 when a single family member is tested, and 46 percent for BRCA1 and 23 percent for BRCA2 when multiple family members are tested. Risks for Ashkenazi Jewish women to age 75 years is 34 percent for breast cancer and 21 percent for ovarian cancer.

In women with uninformative negative test results, the SIR for breast cancer is 3.81 (95% CI, 3.06 to 4.75). In women with true negative test results, the SIR for breast cancer is 1.13 (95% CI, 0.81 to 1.58). Estimates for ovarian cancer are highly heterogeneous and cannot be combined in meta-analysis.

### Evidence

A total of 32 studies of prevalence and penetrance not included in the prior review met inclusion criteria,21,172-202 in addition to 38 studies included in the prior review13,15,16,19,20,46,47,122,188,203-231 (Appendixes C7 and C8). Studies estimated prevalence for high-risk and Ashkenazi Jewish populations and penetrance for BRCA-positive, uninformative negative, and true negative results (Figure 2). No studies provided risk estimates for women with variants of uncertain significance. Most studies used a variety of research laboratory techniques to detect clinically significant mutations that differ from the DNA sequencing that is clinically available.

Figure 2 Included Studies of Prevalence and Penetrance

Figure 2 is a flow diagram of included studies about prevalence and penetrance. The studies are of asymptomatic women. Studies of asymptomatic women and prevalence are divided into 3 categories: unselected population, with 4 studies; high-risk population, including early-onset cancer, selected cohorts, and high-risk families, with 26 studies; and Ashkenazi Jewish population, with 9 studies. Studies of asymptomatic women and penetrance are divided into 4 categories: BRCA-positive women, meaning they have detected deleterious BRCA1 or BRCA2 mutations, with 30 studies and 3 meta-analyses; variant of uncertain significance, meaning an abnormality of the BRCA1 or BRCA2 gene, but it is not known whether it is associated with an increased risk for cancer, no studies; uninformative negative, meaning no known deleterious genetic mutations in relatives, and none detected in the patient, with 3 studies; and true negative, meaning known confirmed deleterious genetic mutation in relatives and none detected in the patient, with 10 studies.

#### Prevalence

Unselected Populations. No direct measures of the prevalence of clinically significant BRCA1 or BRCA2 mutations in the general, nonJewish U.S. population have been published. Models estimate it to be about 0.2 to 0.3 percent.13-16

High-Risk Populations. Studies provide prevalence estimates for three different types of high-risk groups: 1) women with early-onset breast or ovarian cancer (e.g., before age 45 years), 2) women with breast or ovarian cancer from selected high-risk cohorts (e.g., consecutive cases from cancer registries or surgical units), and 3) women from high-risk families based on family history of breast and/or ovarian cancer (Table 8). Prevalence estimates based on high-risk groups overestimate prevalence in unselected or general populations.15 However, women from high-risk groups are the most likely candidates for BRCA testing and identifying them can guide testing decisions within a family.

Table 8 Prevalence of BRCA1 and BRCA2 Mutations in High-Risk Populations

Author, year | Population | Gene | Inclusion criteria | Early-onset | Population- based | High-risk | Ashkenazi Jewish
Breast cancer
Anglian BCSG, 2000^13^ | U.K. | BRCA1/2 | Population-based series of breast cancer from registry | | X | | NR
Newman et al, 1998^223^ | Caucasian North Carolina | BRCA1 | Women diagnosed as having first invasive breast cancer between 20 and 74 years | | X | | NR
Newman et al, 1998^223^ | African American North Carolina | BRCA1 | Women diagnosed as having first invasive breast cancer between 20 and 74 years | | X | | NR
Anton-Culver et al, 2000^204^ | Caucasian Orange County, CA | BRCA1 | Population-based sample of breast cancer cases | | X | | No
Anton-Culver et al, 2000^204^ | Hispanic Orange County, CA | BRCA1 | Population-based sample of breast cancer cases | | X | | No
Newman et al, 1998^223^ | African American and Caucasian North Carolina | BRCA1 | Women diagnosed as having first invasive breast cancer between 20 and 74 years; age 20-39 years | X | | | NR
Anton-Culver et al, 2000^204^ | Total Orange County, CA | BRCA1 | Population-based series of breast cancer cases; age <40 years | X | | | Yes/no
Anton-Culver et al, 2000^204^ | Total Orange County, CA | BRCA1 | Population-based series of breast cancer cases; age <40 years | X | | | Yes/no
Anglian BCSG, 2000^13^ | U.K. | BRCA1/2 | Population-based series of breast cancer from registry; age 35-44 years | X | | | NR
Anglian BCSG, 2000^13^ | U.K. | BRCA1/2 | Population-based series of breast cancer from registry; age <35 years | X | | | NR
FitzGerald et al, 1996^208^ | Boston, MA | BRCA1 | Breast cancer diagnosed <30 years | X | | | No
Peto et al, 1999^16^ | U.K. | BRCA1/2 | 1. Women diagnosed with breast cancer <36 years; 2. Women diagnosed with breast cancer 36-45 years | X | | | NR
Malone et al, 2000^220^ Same population as Langston et al, 1996^217^ | Washington | BRCA1/2 | 1. Women diagnosed with breast cancer <35 years; 2. Women diagnosed with breast cancer <45 years with first-degree family history of breast cancer | X | | | NR
Eccles et al, 1998^207^ | U.K. | BRCA1 | 1. Women diagnosed with breast cancer <40 years; 2. Women with bilateral breast cancer diagnosed after 39 years; 3. Women with a strong family history of breast/ovarian cancer | X | | | NR
Eccles et al, 1998^207^ | U.K. | BRCA1 | 1. Women diagnosed with breast cancer <40 years; 2. Women with bilateral breast cancer diagnosed after 39 years; 3. Women with a strong family history of breast/ovarian cancer | | | X | NR
Eccles et al, 1998^207^ | U.K. | BRCA1 | 1. Women diagnosed with breast cancer <40 years; 2. Women with bilateral breast cancer diagnosed after 39 years; 3. Women with a strong family history of breast/ovarian cancer | | | X | NR
Couch et al, 1997^46^ | U.S. | BRCA1 | 1. Women with breast cancer who had a “familial risk factor” for breast cancer | | | X | No
Tommasi et al, 2005^200^ | Italy | BRCA1 | Consecutive series of breast cancer patients plus a positive family history | | | X | NR
Ovarian cancer
Janezic et al, 1999^216^ | Orange County, CA | BRCA1 | Population-based series of consecutive ovarian cancer cases | | X | | No
Stratton et al, 1997^228^ | U.K. | BRCA1 | Women diagnosed with ovarian cancer before age 70 years | | X | | NR
Anton-Culver et al, 2000^204^ | Caucasian Orange County, CA | BRCA1 | Population-based sample of ovarian cancer cases | | X | | No
Anton-Culver et al, 2000^204^ | Hispanic Orange County, CA | BRCA1 | Population-based sample of ovarian cancer cases | | X | | No
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | Canada Hispanic | BRCA1/2 | Population-based series of consecutive ovarian cancer | | X | | No
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | Canada NonHispanic NonAshkenazi Jewish | BRCA1/2 | Population-based series of consecutive ovarian cancer | | X | | No
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | Total Canada | BRCA1/2 | Population-based series of consecutive ovarian cancer, age <41 years | X | | | Yes/no
Gayther et al, 1999^212^ | U.K. Familial Ovarian Cancer Registry | BRCA1/2 | Families with ≥2 cases of ovarian cancer | | | X | No
Breast and ovarian cancer
Beristain et al, 2007^174^ | Spain | BRCA1/2 | 1. Early-onset breast cancer <40 years; 2. Family history of breast and/or ovarian cancer | X | | | NR
Beristain et al, 2007^174^ | Spain | BRCA1/2 | 1. Early-onset breast cancer <40 years; 2. Family history of breast and/or ovarian cancer | | | X | NR
Gayther et al, 1997^211^ | UK | BRCA2 | 1. Families with multiple cases of breast cancer; 2. Families with multiple cases of ovarian cancer | | | X
Frank et al, 2002^47^ | Myriad | BRCA1/2 | Tested by Myriad for full gene | | | X | No
Weitzel et al, 2005^319^ | Hispanic | BRCA1/2 | Families presenting to the high-risk clinic for testing who were part of the Hereditary Cancer Registry. Had a calculated BRCA mutation probability >5% by any method. | | | X | No
Konecny et al, 2011^183^ | Slovakia | BRCA1/2 | Families presenting to high-risk clinic based on family history of breast and/or ovarian cancer | | | X | NR
Seymour et al, 2008^197^ | Italy | BRCA1/2 | Families presenting to high-risk clinic based on family history of breast and/or ovarian cancer | | | X | NR
Marroni et al, 2004^188^ | Italy | BRCA1/2 | High-risk families presenting for BRCA testing | | | X | NR
Nanda et al, 2005^193^ | Asian | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics who had ≥2 cases of breast or ovarian cancer among FDRs or SDRs | | | X | No
Nanda et al, 2005^193^ | Total NonAshkenazi Jewish | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics who had ≥2 cases of breast or ovarian cancer among FDRs or SDRs | | | X | No
Nanda et al, 2005^193^ | Caucasian | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics who had ≥2 cases of breast or ovarian cancer among FDRs or SDRs | | | X | No
Nanda et al, 2005^193^ | African American | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics who had ≥2 cases of breast or ovarian cancer among FDRs or SDRs | | | X | No
Nanda et al, 2005^193^ | Hispanic | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics who had ≥2 cases of breast or ovarian cancer among FDRs or SDRs | | | X | No
Vaziri et al, 2001^202^ | U.S. | BRCA1/2 | Families in the Familial Cancer Registry who had ≥2 cases of breast or ovarian cancer among FDRs | | | X | NR
Neuhausen et al, 2009^194^ | California, Ontario, Australia | BRCA1/2 | Population-based case probands from cancer registries | | X | | No
Neuhausen et al, 2009^194^ | Philadelphia, New York, Utah, California, Ontario Australia | BRCA1/2 | Population-based case probands from cancer registries and high-risk families | | X | X | No
Neuhausen et al, 2009^194^ | Philadelphia, New York, Utah | BRCA1/2 | Families who presented for BRCA testing in high-risk clinics with a family history of breast and/or ovarian cancer | | | X | No
Tamboom et al, 2010^199^ | Estonia | BRCA1/2 | Women diagnosed with breast cancer prior to age 45 years | X | | | NR
Tamboom et al, 2010^199^ | Estonia | BRCA1/2 | Families where the proband was diagnosed with breast or ovarian cancer and at least one relative was diagnosed with these cancers. | | | X | NR

Author, year | Women tested, N | BRCA1 positive, n | BRCA2 positive, n | BRCA1 or BRCA2 positive, n | BRCA1 mutation frequency | BRCA2 mutation frequency | BRCA1 or BRCA2 mutation frequency
Breast cancer
Anglian BCSG, 2000^13^ | 1220 | 8 | 16 | 24 | 0.6% | 1.3% | 2.0%
Newman et al, 1998^223^ | 120 | 3 | | | 2.5%
Newman et al, 1998^223^ | 88 | 0 | | | 0.0%
Anton-Culver et al, 2000^204^ | 562 | 9 | | | 1.6%
Anton-Culver et al, 2000^204^ | 42 | 0 | | | 0.0%
Newman et al, 1998^223^ | 43 | 0 | | | 0.0%
Anton-Culver et al, 2000^204^ | 41 | 2 | | | 4.8%
Anton-Culver et al, 2000^204^ | 17 | 0 | | | 0.0%
Anglian BCSG, 2000^13^ | 341 | 3 | 4 | 7 | 0.8% | 1.2% | 2.0%
Anglian BCSG, 2000^13^ | 57 | 2 | 4 | 6 | 3.5% | 7.0% | 11%
FitzGerald et al, 1996^208^ | 26 | 2 | | | 7.7%
Peto et al, 1999^16^ | 254 | 9 | 6 | 15 | 3.5% | 2.4% | 5.9%
Peto et al, 1999^16^ | 363 | 7 | 8 | 15 | 1.9% | 2.2% | 4.1%
Malone et al, 2000^220^ Same population as Langston et al, 1996^217^ | 203 | 12 | 7 | 19 | 5.9% | 3.4% | 9.3%
Malone et al, 2000^220^ Same population as Langston et al, 1996^217^ | 235 | 16 | 11 | 27 | 7.1% | 4.9% | 12%
Malone et al, 2000^220^ Same population as Langston et al, 1996^217^ | 155 | 10 | | | 6.5%
Eccles et al, 1998^207^ | 45 | 0 | | | 0.0%
Eccles et al, 1998^207^ | 30 | 8 | | | 27%
Couch et al, 1997^46^ | 146 | 21 | | | 14%
Tommasi et al, 2005^200^ | 100 | 7 | | | 7.0%
Ovarian cancer
Janezic et al, 1999^216^ | 104 | 2 | | | 1.9%
Stratton et al, 1997^228^ | 374 | 13 | | | 3.5%
Anton-Culver et al, 2000^204^ | 99 | 4 | | | 4.0%
Anton-Culver et al, 2000^204^ | 12 | 0 | | | 0.0%
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | 15 | 0 | 0 | 0 | 0.0% | 0.0% | 0.0%
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | 927 | 67 | 52 | 119 | 7.2% | 5.6% | 13%
Risch et al, 2006^195^ Same population as Risch, 2001^225^ | 157 | 9 | 1 | 10 | 5.7% | 0.6% | 6.4%
Gayther et al, 1999^212^ | 112 | 40 | 8 | 48 | 36% | 7.0% | 43%
Breast and ovarian cancer
Beristain et al, 2007^174^ | 72 | 0 | 0 | 0 | 0.0% | 0.0% | 0.0%
Beristain et al, 2007^174^ | 164 | 6 | 10 | 16 | 3.6% | 6.1% | 9.7%
Gayther et al, 1997^211^ | 290 | 64 | 25 | 89 | 22% | 8.6% | 31%
Frank et al, 2002^47^ | 6724 | | | 1055 | | | 16%
Weitzel et al, 2005^319^ | 110 | 25 | 9 | 34 | 23% | 8.1% | 31%
Konecny et al, 2011^183^ | 104 | | 12 | | | 12%
Konecny et al, 2011^183^ | 585 | 85 | | | 15%
Seymour et al, 2008^197^ | 247 | | | 21 | | | 8.5%
Marroni et al, 2004^188^ | 560 | 80 | | | 14%
Marroni et al, 2004^188^ | 464 | | 53 | | | 11%
Nanda et al, 2005^193^ | 2 | 0 | 0 | 0 | 0.0% | 0.0% | 0.0%
Nanda et al, 2005^193^ | 126 | 31 | 17 | 48 | 25% | 13% | 38%
Nanda et al, 2005^193^ | 78 | 24 | 12 | 36 | 31% | 15% | 46%
Nanda et al, 2005^193^ | 43 | 7 | 5 | 12 | 16% | 12% | 28%
Nanda et al, 2005^193^ | 3 | 0 | 0 | 0 | 0.0% | 0.0% | 0.0%
Vaziri et al, 2001^202^ | 104 | 18 | 2 | 20 | 17.30% | 1.9% | 19.2%
Neuhausen et al, 2009^194^ | NR | NR | NR | NR | 4.0% | 3.7% | NR
Neuhausen et al, 2009^194^ | 4084 | NR | 193 | NR | NR | 4.7% | NR
Neuhausen et al, 2009^194^ | 4531 | 233 | NR | NR | 5.2% | NR | NR
Neuhausen et al, 2009^194^ | NR | NR | NR | NR | 9.9% | 8.6% | NR
Tamboom et al, 2010^199^ | 64 | 4 | 0 | 4 | 6.3% | 0.0% | 6.3%
Tamboom et al, 2010^199^ | 47 | 6 | 1 | 7 | 12.8% | 2.1% | 14.9%

Abbreviations: FDR = first-degree relative; NR = not reported; SDR = second-degree relative.

Early-Onset Breast or Ovarian Cancer. Eleven studies reported prevalence estimates for women with early-onset breast or ovarian cancer.13,16,174,195,199,204,207,208,218,220,223

For BRCA1, the meta-analysis indicated a prevalence of 4.26 percent (95% CI, 2.61 to 6.87; 10 studies)13,16,174,195,204,207,208,218,220,223 in women diagnosed with breast cancer at age 40 years or younger, and 5.17 percent (95% CI, 2.39 to 9.59; 2 studies)13,195 in those diagnosed with ovarian cancer at age 40 years or younger (Table 1). For BRCA2, prevalence was 2.90 percent (95% CI, 1.35 to 6.14; 5 studies)13,16,174,195,220 in women diagnosed with breast cancer at age 40 years or younger, and 0.64 percent (95% CI, 0.02 to 3.50) in those diagnosed with ovarian cancer at age 40 years or younger, based on only one study.195 For BRCA1 or BRCA2, the combined prevalence estimate was 5.98 percent (95% CI, 1.87 to 17.47)16,208,220 in women diagnosed with breast cancer at age 40 years or younger. Additional estimates are described in Table 9 and suggest higher prevalence rates in women with younger ages of cancer onset. While subject selection for the youngest age group (≤35 years) in these studies was based primarily on age at diagnosis of breast or ovarian cancer, some studies used family history information to select subjects for the older age group (≤45 years).

Table 9 Summary of Meta-Analysis of Studies of Prevalence of BRCA1 and BRCA2 Mutations in High-Risk Populations

Population | Gene | Cancer type | Prevalence, % (95% CI) | I^2^ (p-value) | Studies, n (ref)
Early-onset breast or ovarian cancer
≤35 years | BRCA1 | B | 4.63 (2.47 to 8.52) | NA | 5^13, 16, 208, 218, 220^
≤40 years | BRCA1 | B | 4.26 (2.61 to 6.87) | NA | 10^13, 16, 174, 195, 204, 207, 208, 218, 220, 223^
≤40 years | BRCA1 | O | 5.17 (2.39 to 9.59) | NR | 2^13, 195^
≤45 years | BRCA1 | B | 3.25 (1.72 to 6.06) | NA | 11^13, 16, 174, 195, 199, 204, 207, 208, 218, 220, 223^
≤35 years | BRCA2 | B | 3.31 (1.17 to 9.00) | NA | 3^13, 16, 220^
≤40 years | BRCA2 | B | 2.90 (1.35 to6.14) | NA | 5^13, 16, 174, 195, 220^
≤40 years | BRCA2 | O | 0.64 (0.02 to 3.50) | NR | 1^195^
≤45 years | BRCA2 | B | 2.31 (1.11 to 4.77) | NA | 6^13, 16, 174, 195, 220^
≤35 years | BRCA1 & BRCA2 | B | 7.78 (3.99 to 14.63) | NA | 5^13, 16, 174, 195, 220^
≤40 years | BRCA1 & BRCA2 | B | 5.98 (1.87 to17.47) | NA | 3^13, 16, 220^
≤40 years | BRCA1 & BRCA2 | O | 6.37 (3.10 to 11.40) | NR | 1^195^
≤45 years | BRCA1 & BRCA2 | B | 4.63 (1.91 to 10.80 | NA | 5^13, 16, 195,199, 220^
Selected high-risk cohorts
| BRCA1 | B | 1.84 (0.72 to 4.63) | 91% (0.190) | 4^13, 194, 204, 223^
| BRCA2 | B | 1.31 (0.67 to 1.95) | NA | 1^13^
| BRCA1 | O | 4.41 (2.47 to 7.74) | 70% (0.006) | 4^194, 204, 216, 228^
| BRCA2 | O | 5.61 (4.13 to 7.09) | NA | 1^195^
High-risk families
| BRCA1 | B | 13.58 (10.09 to 17.07) | 86% (<0.001) | 11^46, 174, 183, 188, 193, 194, 199, 200, 202, 207, 211^
| BRCA1 | O | 35.71 (26.92 to 44.51) | NA | 1^212^
| BRCA2 | B | 7.90 (5.30 to 10.50) | 73% (0.117) | 8^174, 183, 188, 193,194, 199, 202, 211^
| BRCA2 | O | 7.14 (2.13 to 12.15) | NA | 1^212^
| BRCA1 & BRCA2 | B | 19.78 (12.98 to 26.57) | 94% (<0.001) | 6^47, 174, 193, 197, 199, 211^
| BRCA1 & BRCA2 | O | 42.86 (33.79 to 51.92) | NA | 1^212^
Ashkenazi Jewish
| BRCA1 & BRCA2 | NA | 2.08 (1.28 to 2.88) | 89% (<0.001) | 4^20, 191, 214, 209^
| BRCA1 | NA | 1.01 (0.64 to 1.37) | 74% (0.004) | 5^20, 191, 209, 214, 229^
| BRCA2 | NA | 1.02 (0.72 to 1.33) | 60% (0.028) | 5^20, 191, 209, 214, 224^

Abbreviations: B = breast; CI = confidence interval; NA = not applicable; NR = not reported; O = ovarian.

High-Risk Cohorts. Results of a meta-analysis of four studies based on data from breast cancer case series indicated a combined prevalence estimate for BRCA1 of 1.84 percent (95% CI, 0.72 to 4.63).13,194,204,223 The prevalence of BRCA2 was 1.31 percent (95% CI, 0.67 to 1.95), based on one study.13

Results of a meta-analysis of four studies based on data from ovarian cancer case series indicated a combined prevalence estimate for BRCA1 of 4.41 percent (95% CI, 2.47 to 7.74),195,204,216, 228 with substantial heterogeneity among studies (I^2^=70%; p=0.006). The prevalence of BRCA2 was 5.61 percent (95% CI, 4.13 to 7.09), based on one study.195

Prevalence was also reported for racial and ethnic minorities in three studies;195,204,223 however, the studies were small, few mutations were detected, and results were not conclusive.

High-Risk Families. Additional prevalence estimates for women from referral populations with various levels of family history range from 3.66 percent174 to 30.8 percent193 for BRCA1 and from 6.1 percent174 to 15.4 percent193 for BRCA2 in white, nonHispanic, nonAshkenazi Jewish women.

In 11 studies in which recruitment was based on family history of breast and/or ovarian cancer, results of the meta-analysis indicated BRCA1 prevalence of 13.58 percent (95% CI, 10.09 to 17.07),174,183,188,193,194,199,200,202,207,211,232 with significant heterogeneity among studies (I^2^=86%; p<0.001). Heterogeneity remained high in a sensitivity analysis that excluded an outlier193 (I^2^=89%; p<0.001). Estimates were similar in sensitivity analyses that excluded two studies with mixed populations of race/ethnicity.46,194 One study reported a BRCA1 prevalence of 35.71 percent (95% CI, 26.92 to 44.51) in families with two or more cases of ovarian cancer.212

For BRCA2, meta-analysis results of eight studies in which recruitment was based on family history of breast and/or ovarian cancer indicated a prevalence of 7.90 percent (95% CI, 5.30 to 10.50).174,183,188,193,194,199,202,211 One study reported a prevalence estimate of 7.14 percent (95% CI, 2.13 to 12.15) in families with histories of two or more cases of ovarian cancer.212

For BRCA1 and BRCA2 combined, the prevalence was 19.78 percent (95% CI, 12.98 to 26.57).46, 174,183,188,193,199,200,207,211 In a study in which subjects were ascertained based on family histories of two or more cases of ovarian cancer, the estimate was 42.86 percent (95% CI, 33.79 to 51.92).212 In a sensitivity analysis excluding an outlier,193 prevalence decreased to 15.93 percent (95% CI, 9.21 to 22.66), although there was significant heterogeneity (I^2^=94%; p<0.001). Estimates were similar in sensitivity analyses that excluded one study with mixed populations of race/ethnicity.47

Prevalence was also reported for racial and ethnic groups from referral populations with various levels of family history risk. One study reported a prevalence of 22.7 percent for BRCA1 and 8.1 percent for BRCA2 in 110 Hispanic individuals in a hereditary cancer registry.21 No BRCA1 or BRCA2 mutations were detected in three Hispanic individuals tested in another study.193 Black individuals presenting for BRCA testing in high-risk clinics had a prevalence of 16.3 percent for BRCA1 and 11.6 percent for BRCA2.^193^

Ashkenazi Jewish. Five studies provided estimates of BRCA1 prevalence in Ashkenazi Jewish populations unselected by personal or family history of breast cancer,19,20,191,209,214 and six studies provided estimates for BRCA2 prevalence19,20,191,209,214,224 (Table 10). These studies reported the prevalence of the three founder mutations, including mutations 5382insC and 185delAG in BRCA1 and 6174delT in BRCA2.

Table 10 Prevalence of BRCA1 and BRCA2 Mutations in Ashkenazi Jewish Populations

Author, year | Population | Women tested, N | BRCA1 positive, n | BRCA2 positive, n | BRCA1 or BRCA2 positive, n | BRCA1 mutation frequency | BRCA2 mutation frequency | BRCA1 or BRCA2 mutation frequency
Fodor et al, 1998^209^ | Population based (U.S.) | 1715 | 20 | 18 | 38 | 1.2% | 1.0% | 2.2%
Hartge et al, 1999^214^ Struewing et al, 1997^19^ | Population based (U.S.) | 3742 | 48 | 41 | 89 | 1.3% | 1.1% | 2.4%
Metcalfe et al, 2010^191^ | Population based (Canada) | 2080 | 10 | 12 | 22 | 0.5% | 0.6% | 1.1%
Oddoux et al, 1996^224^ | Population based (U.S.) | 1255 | | 12 | | | 0.9%
Roa et al, 1996^20^ | Population based (U.S.) | 2717 | 35 | | | 1.3%
Roa et al, 1996^20^ | Population based (U.S.) | 2687 | | 37 | | | 1.4%
Roa et al, 1996^20^ | Population based (Israel) | 403 | 3 | | | 0.7%
Roa et al, 1996^20^ | Population based (Israel) | 398 | | 10 | | | 2.5%
Struewing et al, 1995^229^ | Population based (U.S.) | 327 | 3 | | | 0.9%
Struewing et al, 1995^229^ | Population based (Israel) | 369 | 3 | | | 0.8%

Based on the meta-analysis, prevalence for BRCA1 was 1.2 percent (95% CI, 0.98 to 1.42)20,209, 214 and for BRCA2 was 1.17 percent (95% CI, 0.95 to 1.38)20,209,214,224 (Table 11). For BRCA1 and BRCA2 combined, prevalence was 2.08 percent (95% CI, 1.28 to 2.88).20,191,209, 214 There was significant heterogeneity among studies (I^2^=89%; p<0.001), with the most recent publication191 estimating prevalence at about half the rates of previous studies for both BRCA1 and BRCA2. The new study included fewer women with family or personal histories of breast or ovarian cancer compared with other studies (e.g., personal history, 0.8% vs. 8%).214 Also, secular trends may have influenced prevalence estimates over time. For example, high-risk families who have already been tested may not have responded to advertisements recruiting participants to more recent studies. In a sensitivity analysis that excluded results from the most recent study, prevalence for the founder mutations was 2.46 percent (95% CI, 2.13 to 2.78),20,209,214 without significant heterogeneity among studies (I^2^=0%; p=0.496).

Table 11 Penetrance of BRCA-Related Cancer in BRCA-Positive Women: Single Individual Tested

Author, year | Population or risk group | N | Breast cancer risk | | | Ovarian cancer risk
Author, year | Population or risk group | N | BRCA1 % (95% CI | BRCA2 % (95% CI) | BRCA1 and BRCA2 % (95% CI) | BRCA1 % (95% CI) | BRCA2 % (95% CI) | BRCA1 and BRCA2 % (95% CI)
Risk to age 50 years
Anglian Breast Cancer Study Group, 2000^13^ | Cancer registry (U.K.) | 8 | 32 (2 to 62) | | | 11 (1 to74)
Anglian Breast Cancer Study Group, 2000^13^ | Cancer registry (U.K.) | 16 | | 18 (2 to 32) | | | 3 (0 to 19)
Chen et al, 2006^122^ | High-risk (U.S.) | 283 | 28 (24 to 34) | | | 13 (9.7 to 17)
Chen et al, 2006^122^ | High-risk (U.S.) | 143 | | 23 (19 to29) | | | 4 (2.2 to 6.2)
Hopper et al, 1999^215^ | Cancer registry <40 years (Australia) | 18 | | | 10 (0 to 24)
Marroni et al, 2004^188^ | High-risk (Italy) | 80 | 27 (20 to 34) | | | 14 (7 to 22)
Marroni et al, 2004^188^ | High-risk (Italy) | 53 | | 26 (18 to 34) | | | 3 (0 to 7)
Risk to age 70 years
Anglian Breast Cancer Study Group, 2000^13^ | Cancer registry (U.K.) | 8 | 47 (7 to 82) | | | 36 (4 to 99)
Anglian Breast Cancer Study Group, 2000^13^ | Cancer registry (U.K.) | 16 | | 56 (5 to 80) | | | 10 (1 to 55)
Antoniou et al, 2002^15^ | Cancer registry (U.K.) | Unclear | 35.3 | 50.3 | | 25.9 | 9.1
Chen et al, 2006^122^ | High-risk (U.S.) | 283 | 46 (39 to 54) | | | 39 (30 to 50)
Chen et al, 2006^122^ | High-risk (U.S.) | 143 | | 45 (36 to 51) | | | 22 (14 to 32)
Hopper et al, 1999^215^ | Cancer registry <40 years (Australia) | 18 | | | 36 (15 to 65)
Lubinski et al, 2012^187^ | Known mutation carriers (26 centers in Canada, U.S., and Poland)—U.S. Results | 614 | | | 76 (NR)
Lubinski et al, 2012^187^ | Known mutation carriers (26 centers in Canada, U.S., and Poland)—Polish Results | 863 | | | 57 (NR)
Marroni et al, 2004^188^ | High-risk (Italy) | 80 | 39 (27 to 52) | | | 43 (21 to 66)
Marroni et al, 2004^188^ | High-risk (Italy) | 53 | | 44 (29 to 58) | | | 15 (4 to 26)
Metcalfe et al, 2010^190^ | Known mutation carriers (6 countries) 0 FDRs | 3011 | 56 | 38 | | 39
Metcalfe et al, 2010^190^ | Known mutation carriers (6 countries) 1 FDR | 3011 | 57 | 46 | | 55
Metcalfe et al, 2010^190^ | Known mutation carriers (6 countries) ≥2 FDRs | 3011 | 72 | 85 | | 68
Risk to age 80 years
Risch et al, 2001^225^ | Ovarian cancer registry (Canada) | 39 | 39.1 | | | 19.4
Risch et al, 2001^225^ | Ovarian cancer registry (Canada) | 21 | | 11.9 | | | 6.1
Risch et al, 2006^195^ | Ovarian cancer registry (Canada) | 75 | 90 (77 to 97) | | | 24 (15 to 38)
Risch et al, 2006^195^ | Ovarian cancer registry (Canada) | 54 | | 41 (26 to 60) | | | 8.4 (3.9 to 17)

Abbreviations: BCLC= Breast Cancer Linkage Consortium; CI = confidence interval; FDR = first-degree relative; LoD = logarithm (base 10) of odds; NR = not reported.

No new studies provided prevalence estimates for Ashkenazi Jews selected for personal or family histories of breast cancer. From the previous review,1,2 results of the meta-analysis indicated an estimated prevalence of founder mutations of 10.2 percent (95% CI, 4.2 to 22.9), including 6.4 percent (95% CI, 1.1 to 29) for BRCA1 and 1.1 percent (95% CI, 0.6 to 2.0) for BRCA2 in women with family histories of breast or ovarian cancer.19,47,219

#### Penetrance

Penetrance is the probability of developing BRCA-related cancer in women who have a given BRCA1 or BRCA2 genotype, and is reported as the cumulative risk to a specified age. The meta-analysis results reflect the age parameters and cancer outcomes provided by the studies for positive, true negative, and uninformative negative test results. There were no studies of penetrance in women with variants of uncertain significance.

BRCA-Positive Results in High-Risk Populations. There were significant methodological differences across studies that reported penetrance in women who were BRCA1 or BRCA2 mutation carriers. Results are reported separately depending on whether a single person (Table 11) or multiple individuals (Table 12) in a family were tested.

Table 12 Penetrance of BRCA-Related Cancer in BRCA-Positive Women: Multiple Individuals Tested

Author, year | Population or risk group | N | Breast cancer risk | | | Ovarian cancer risk
Author, year | Population or risk group | N | BRCA1 % (95% CI) | BRCA2 % (95% CI) | BRCA1 and BRCA2 % (95% CI) | BRCA1 % (95% CI) | BRCA2 % (95% CI) | BRCA1 and BRCA2 % (95% CI)
Risk to age 50 years
Al-Mulla et al, 2009^172^ | U.K. Exon 2 | 30 | 30
Al-Mulla et al, 2009^172^ | U.K. Exon 11 | 58 | 80
Al-Mulla et al, 2009^172^ | U.K. Other exons | 28 | 85
Al-Mulla et al, 2009^172^ | U.K. Exon 13 | 20 | 92
Antoniou et al, 2006^173^ | French Canadian | 25 | 20 (0 to 45) | | | 1 (0 to 10)
Antoniou et al, 2006^173^ | French Canadian | 27 | | 21 (0 to 55) | | | 0.4 (0 to 2)
Evans et al, 2008^178^ | U.K. | 223 | 48 (SE, 0.023) | | | 21 (SE, 0.02)
Evans et al, 2008^178^ | U.K. | 162 | | 42 (SE, 0.027) | | | 4 (SE, 0.012)
Ford et al, 1998^210^ | High-risk (BCLC) | 32 | | 28 (9 to 44) | | | 0.4 (0 to 1.1)
Kramer et al, 2005^185^ | U.S. Overall | 23 | 0.44 (SE, 0.07)
Kramer et al, 2005^185^ | U.S. With ovaries | 23 | 0.49 (SE, 0.09)
Milne et al, 2008^192^ | Spain | 155 | 35 (15 to 47) | | | 10 (0 to 25)
Milne et al, 2008^192^ | Spain | 164 | | 32 (17 to 44) | | | 2 (0 to 9)
Sutcliffe et al, 2000^230^ | Ovarian cancer registry (U.K.) BRCA 1/2 combined | 319 | | | 700% | | | 400%
van der Kolk et al, 2010^201^ | Netherlands Positive index | 111 | 51 (47 to 54) | | | 21 (18 to 24)
van der Kolk et al, 2010^201^ | Netherlands Positive index | 74 | | 46 (41 to 51) | | | 7 (4 to 9)
Risk to age 70 years
Antoniou et al, 2006^173^ | French Canadian | 25 | 72 (0 to 93) | | | 38 (0 to 78)
Antoniou et al, 2006^173^ | French Canadian | 27 | | 75 (0 to 97) | | | 49 (0 to 81)
Brose et al, 2002^206^ | U.S. Age-adjusted risk | 147 | 73 (68 to 78) | | | 41 (36 to 46)
Evans et al, 2008^178^ | U.K. | 223 | 68 (SE, 0.033) | | | 60 (SE, 0.037)
Evans et al, 2008^178^ | U.K. | 162 | | 75 (SE, 0.033) | | | 30 (SE, 0.046)
Ford et al, 1998^210^ | High-risk (BCLC) | 32 | | 84 (43 to 95) | | | 27 (0 to 47)
Kramer et al, 2005^185^ | U.S. Overall | 23 | 0.76 (SE, 0.08)
Kramer et al, 2005^185^ | U.S. With ovaries | 23 | 0.92 (SE, 0.08)
Milne et al, 2008^192^ | Spain | 155 | 52 (26 to 69) | | | 22 (0 to 40)
Milne et al, 2008^192^ | Spain | 164 | | 47 (29 to 60) | | | 18 (0 to 35)
Sutcliffe et al, 2000^230^ | Ovarian cancer registry (U.K.) BRCA 1/2 combined | 319 | | | 11% | | | 12%
van der Kolk et al, 2010^201^ | Netherlands Negative index | 111 | 60 (54 to 65) | | | 52 (45 to 58)
van der Kolk et al, 2010^201^ | Netherlands Positive index | 111 | 71 (67 to 76) | | | 59 (53 to 64)
van der Kolk et al, 2010^201^ | Netherlands Negative index | 74 | | 78 (69 to 88) | | | 13 (7 to19)
van der Kolk et al, 2010^201^ | Netherlands Positive index | 74 | | 87 (82 to 93) | | | 34 (25 to 44)

Abbreviations: BCLC = Breast Cancer Linkage Consortium; CI = confidence interval; SE = standard error.

Eight studies reported breast cancer penetrance based on testing a single individual per family.13, 15,176,187,188,190,195,225 For BRCA1 mutations, breast cancer penetrance was 46 percent (95% CI, 40 to 51) to age 70 years13,15,176,188,190 (Table 13); for BRCA2, penetrance was 50 percent (95% CI, 40 to 60) to age 70 years.13,15,176,188,190

Table 13 Summary of Meta-Analysis of Studies of Breast and Ovarian Cancer Penetrance in BRCA-Positive Women in High-Risk Populations

Outcome | Risk age, y | Multiple individuals tested | | | Single individual tested | | | All studies combined
Outcome | Risk age, y | Penetrance, % (95% CI) | I^2^ (p-value) | Studies, n (ref) | Penetrance, % (95% CI) | I^2^ (p-value) | Studies, n (ref) | Penetrance, % (95% CI) | I^2^ (p-value) | Studies, n (ref)
BRCA1
Breast cancer | 50 | 47 (40 to 53) | 60% (0.032) | 6^172,173,178,185,192,201^ | 28 (24 to 32) | 0% (0.94) | 3^13,122,188^ | | | NA
Breast cancer | 70 | 70 (61 to 79) | 83% (<0.001) | 6^173,178,185,192,201,206^ | 46 (40 to 52) | 0% (0.60) | 5^13,15,122,188,191^ | | | NA
Ovarian cancer | 50 | 14 (3.8 to 23) | 94% (<0.001) | 4^173,178,192,201^ | 13 (10 to 16) | 0% (0.99) | 3^13,122,188^ | 14 (7 to 20) | 89% (<0.001) | 7^13,122,173,178,188,192,201^
Ovarian cancer | 70 | 46 (35 to 57) | 85% (<0.001) | 5^173,178,192,201,206^ | 41 (32 to 49) | 0% (0.81) | 5^13,15,122,188,191^ | 45 (37 to 52) | 65% (0.001) | 10^13,15,122,173,178,188,191,192,201,206^
BRCA2
Breast cancer | 50 | 40 (33 to 46) | 57% (0.056) | 5^173,178,192,201,210^ | 23 (19 to 27) | 0% (0.63) | 3^13,122,188^ | | | NA
Breast cancer | 70 | 71 (59 to 83) | 69% (0.012) | 5^173,178,192,201,210^ | 50 (40 to 60) | 33% (0.17) | 5^13,15,122,188,191^ | | | NA
Ovarian cancer | 50 | 3 (1 to 4) | 88% (<0.001) | 5^173,178,192,201,210^ | 4 (2 to 5) | 0% (0.88) | 3^13,122,188^ | 3 (1 to 4) | 84% (<0.001) | 8^13,122,173,178,188,192, 201,210^
Ovarian cancer | 70 | 23 (12 to 34) | 67% (0.016) | 5^173,178,192,201,210^ | 17 (11 to 24) | 0% (0.52) | 4^13,15,122,188^ | 19 (13 to 25) | 45% (0.068) | 9^13,15,122,173,178,188, 192,201,210^

Abbreviations: CI = confidence interval; NA = not applicable.

Eight studies reported estimates based on testing multiple individuals per family.172,173,178,185,192, 201,206,210 For BRCA1 mutations, breast cancer penetrance was 70 percent (95% CI, 61 to 79) to age 70 years;173,178,185,192,201,206 for BRCA2, penetrance was 71 percent (95% CI, 59 to 83) to age 70 years.173,178,192,201,210 Between-study heterogeneity was significant.

Estimates were not combined across the two types of studies because of significant heterogeneity and large differences between estimates with nonoverlapping CIs. A published meta-analysis that combined all types of studies reported breast cancer penetrance in BRCA-positive women to age 70 years as 57 percent (95% CI, 47 to 66) for BRCA1 and 49 percent (95% CI, 40 to 57) for BRCA2.^12^ A second meta-analysis that included 22 studies based on case-series unselected for family history reported estimates of 65 percent (95% CI, 44 to 78) for BRCA1 and 45 percent (95% CI, 31 to 56) for BRCA2.^11^ This meta-analysis also reported significant between-study heterogeneity. The results of published meta-analyses differ from the results of this review because they included studies of women with Ashkenazi Jewish ancestry or studies in which only Ashkenazi Jewish founder mutations were tested. These populations were excluded from the meta-analysis reported in this review.

Seven studies reported ovarian cancer penetrance based on testing a single individual per family.13,15,176,188,190,195,225 For BRCA1 mutations, ovarian cancer penetrance was 41 percent (95% CI, 32 to 49) to age 70 years;13,15,176,188,190 for BRCA2, penetrance was 17 percent (95% CI, 11 to 24) to age 70 years.13,15,176,188 There was no significant heterogeneity between studies.

Six studies reported estimates based on testing multiple individuals per family.173,178,192,201,206,210 For BRCA1 mutations, ovarian cancer penetrance was 46 percent (95% CI, 35 to 57) to age 70 years;173,178,192,201,206 for BRCA2, penetrance was 23 percent (95% CI, 12 to 34) to age 70 years.173,178,192,201,210 There was significant heterogeneity between studies.

Estimates for ovarian cancer from studies of testing a single person or multiple individuals per family were very similar and all studies were combined in additional meta-analyses. Combined measures for BRCA1 mutations include penetrance of 45 percent (95% CI, 37 to 52) to age 70 years and for BRCA2, 19 percent (95% CI, 13 to 25) to age 70 years. These estimates are similar to a published meta-analysis that reported penetrance in BRCA-positive women to age 70 years as 49 percent (95% CI, 40 to 57) for BRCA1 and 18 percent (95% CI, 13 to 23) for BRCA2.^12^ A second meta-analysis that included 22 studies based on case-series unselected for family history reported estimates of 39 percent (95% CI, 18 to 54) for BRCA1 and 11 percent (95% CI, 2.4 to 19) for BRCA2.^11^

Studies had several limitations and biases. Many studies selected families for analysis based on personal histories of breast or ovarian cancer (probands). Probands and their family members are more likely to have other risk factors for breast or ovarian cancer that may affect penetrance,233 and breast or ovarian cancer survivors may have a different spectrum of mutations compared with women with newly diagnosed cancer. Penetrance may also depend on the specific mutation within the gene, and only one study reported penetrance estimates stratified by exons.172

BRCA-Positive Results in Ashkenazi Jewish Populations. Several studies described in previous sections of this review provided estimates that included Ashkenazi Jewish along with nonAshkenazi Jewish families. Only one new study reported penetrance in Ashkenazi Jewish families specifically, and these estimates combined women who were BRCA1 and BRCA2 mutation carriers.187 Estimates specifically for BRCA1 and BRCA2 were provided in the prior review1,2 and are similar to a published meta-analysis.234

In the previous meta-analysis of 10 studies,203,204,208,209,213,214,217,226,227,231 breast cancer penetrance was 33.7 percent (95% CI, 24.1 to 44.9) to age 75 years in Ashkenazi Jewish women without family histories of breast or ovarian cancer. In those with family histories, penetrance was 34.7 percent (95% CI, 17.6 to 57.0) to age 75 years, based on nine studies.47,203,208,209,213,214,217,224,226

From the previous meta-analysis of five studies,203,205,221,222,225 ovarian cancer penetrance was 21.4 percent (95% CI, 14.9 to 29.7) to age 75 years in Ashkenazi Jewish women without family histories of breast or ovarian cancer. In those with family histories, penetrance was 18.1 percent (95% CI, 7.6 to 37.3) to age 75 years, based on two studies.47,222

#### Uninformative Negative Results

An uninformative negative result can occur for several reasons, including other family members have not been tested; the family carries a BRCA mutation, but it was not detected because of limitations of the test; the family carries a high-risk mutation in another gene; or no high-risk mutation is segregating in the family.

Three studies provided data to estimate the SIR for the development of breast cancer in women with uninformative negative results compared with estimates for the general population (Table 15).182,189,230 Estimates across studies were very similar, ranging from 3.25 to 3.32. The overall estimate for the SIR for breast cancer was 3.81 (95% CI, 3.06 to 4.75) (Figure 3).

Table 15 Penetrance of BRCA-Related Cancer in Women With True Negative Results

Author, year | Population or risk group | N | Breast cancer | | | Ovarian cancer | | | Genotype | Prospective | Oophorectomy adjustment | Invasive only
Author, year | Population or risk group | N | Cases observed, n | Cases expected, n | Relative risk (95% CI) | Cases observed, n | Cases expected, n | Relative risk (95% CI) | Genotype | Prospective | Oophorectomy adjustment | Invasive only
Bernholtz, 2012^175^ | True negatives Total | 307 | 20 | 23.8 | 0.84 (0.51 to 1.30) | | | | Known | Yes | Unknown | Unknown
Domchek, 2010^177^ | True negatives FDRs or SDRs | 378 | 2 | 3.8 | 0.52 (0.13 to 2.09) | 0 | 0.4 | NR | Known | Yes | No | Yes
Domchek, 2010^177^ | True negatives FDRs or SDRs | 378 | 2 | 0.9 | 2.3 (0.57 to 9.19) | | | | Known | Yes | No | No
Gronwald, 2007^180^ | True negatives FDRs | 131 | 2.5 | 1.2 | 2 (not given) | | | | 54% known; remainder probabilistically assigned | No | No | Unknown
Harvey, 2011^181^ | True negatives Total | 722 | 6 | | 1.14 (0.51 to 2.53) | | | | Known | Yes | Yes | Yes
Harvey, 2011^181^ | True negatives FDRs and SDRs | 442 | | | 1.29 (0.58 to 2.88) | | | | Known | Yes | Yes | Yes
Harvey, 2011^181^ | True negatives^*^ | 424 | | | 0.48 (0.12 to 1.93) | | | | Known | Yes | Yes | Yes
Korde, 2011^184^ | True negatives FDRs | 102 | | | 0.66 (0.13 to 1.94) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives FDRs | 102 | | | 1.33 (0.49 to 2.91) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives SDRs | 182 | | | 0.97 (0.35 to 2.11) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives TDRs | 111 | | | 0.69 (0.01 to 3.83) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives Total | 395 | 10 | 12 | 0.75 (0.34 to 1.41) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives Total | 395 | 10 | 12 | 0.82 (0.39 to 1.51) | | | | Known or inferred | Yes | Yes | No
Korde, 2011^184^ | True negatives Total | 395 | 10 | | 0.95 (0.45 to 1.74) | | | | Known or inferred | Yes | Yes | No
Kramer, 2005^185^ | True negatives Total | 353 | 5 | | 0.65 (0.21 to1.52) | | | | Known or inferred | Yes | Yes | Unknown
Kurian, 2011^186^ | True negatives FDRs | NR | | | 0.39 (0.04 to 3.81) | | | | Untested were probabilistically assigned | Unknown | Unknown | No
Rowan, 2007^196^ | True negatives FDRs or SDRs | 101 | 3 | 1 | 2.9 (1.0 to 8.6) | 0 | 1.7 | NR | Known | Yes | Unknown | Yes
Smith, 2007^198^ | True negatives Total | 258 | 28 | 5.3 | 5.3 (3.5 to 7.7) | 4 | 0.9 | 4.6 (1.2 to 11.7) | Known | No | No | No
Smith, 2007^198^ | True negatives FDRs | 184 | 18 | 3.6 | 5 (2.9 to 7.8) | | | | Known | No | No | No
Smith, 2007^198^ | True negatives FDRs | 166 | 13 | 3.2 | 4 (2.1 to 6.9) | | | | Known | No | No | No
Smith, 2007^198^ | True negatives FDRs | 153 | 3 | 1.4 | 2.1 (0.4 to 6.2) | | | | Known | Yes | No | No
van der Kolk, 2010^201^ | True negatives FDRs | 128 | 5 | 2.5 | 2 (0.7 to 4.7) | 0 | 0.3 | 0 (0 to 12) | Known | Yes | Yes | No
van der Kolk, 2010^201^ | True negatives FDRs | 74 | 4 | 1.6 | 2.5 (0.7 to 6.3) | 0 | 0.2 | 0 (0 to 20.4) | Known | Yes | Yes | No

* No family history in the nonmutation carrying parental line.

Abbreviations: FDR = first-degree relative; NR = not reported; SDR = second-degree relative; TDR = third-degree relative.

Figure 3 Meta-Analysis of Studies of Breast and Ovarian Cancer Incidence in Women With Uninformative Negative Results

* Per 10,000 person-years.

Abbreviations: CI = confidence interval; SIR = standardized incidence ratio.

Figure 3 shows a forest plot diagram of breast and ovarian cancer incidence for women with uninformative negative results. Three studies on breast cancer are shown: one by Sutcliffe, published in 2000, had 435 participants and an observed rate of 36.8 (per 10,000 person-years), an expected rate of 11.1 (per 10,000 person-years), and a SIR of 3.32; one by Kauff, published in 2005, had 321 participants and an observed rate of 73.6, expected rate of 22.6, and a SIR of 3.25; and one by Metcalfe, published in 2009, had 1,492 participants and an observed rate of 71.4, expected rate of 18.1, and a SIR of 3.94. Heterogeneity for the three studies was 0% and p equaled 0.825. Three studies on ovarian cancer are shown: one by Sutcliffe, published in 2000, had 382 participants and an observed rate of 18.8, expected rate of 1.6, and a SIR of 11.60; one by Kauff, published in 2005, had 321 participants and an observed rate of 9.2, expected rate of 2.4, and a SIR of 3.88; and one by Metcalfe, published in 2009, had 1,492 participants and an observed rate of 2.2, expected rate of 2.6, and a SIR of 0.85. Heterogeneity for the three ovarian cancer studies was 77.4% and p equaled 0.012.

The same three studies provided data for SIRs for the development of ovarian cancer in women with uninformative negative results compared with estimates for the general population (Figure 3, Table 14).182,189,230 However, these estimates varied widely across studies (0.85 to 11.6), and could not be combined because of significant heterogeneity (I^2^=77.4%; p=0.012). This heterogeneity likely reflects the differing ascertainment criteria for study recruitment. The study with the lowest SIR (0.85 [95% CI, 0.23 to 3.12]) included only first-degree relatives of breast cancer cases.189 The other studies included families with breast cancer (SIR, 3.88 [95% CI, 0.05 to 21.6])182 and families with at least two first-degree relatives with ovarian cancer (SIR, 11.6 [95% CI, 3.12 to 29.7]).230

Table 14 Penetrance of BRCA-Related Cancer in Women With Uninformative Negative Results

Author, year | Population or risk group | Ascertainment | N | Risk to age, y | Breast cancer | | | Ovarian cancer
Author, year | Population or risk group | Ascertainment | N | Risk to age, y | Cases observed, n | Cases expected, n | Relative risk (95% CI) | Cases observed, n | Cases expected, n | Relative risk (95% CI)
Kauff et al, 2005^182^ | FDRs in high-risk families who test negative for BRCA | Families with breast cancer but no ovarian cancer | 165 families 321 FDRs | 85 | 8 | 2.46 | 3.25 (1.4 to 6.4) | 1 | 0.26 | 3.88 (0.05 to 21.6)
Kauff et al, 2005^182^ | SDRs in high-risk families who test negative for BRCA | Families with breast cancer but no ovarian cancer | 165 families 262 SDRs | 85 | 4 | 2.18 | 1.83 (0.49 to 4.69) | 0 | 0.26 | 0 (NA to 14.3)
Kauff et al, 2005^182^ | Probands in high-risk families who test negative for BRCA | Families with breast cancer but no ovarian cancer | 165 families 165 probands | 85 | 7 | 1.43 | 4.9 (1.96 to 10.11) | 0 | 0.14 | 0 (NA to 25.6)
Metcalfe et al, 2009^189^ | FDRs in high-risk families who test negative for BRCA | FDRs of breast cancer cases | 365 families 1492 women | 75 | 65 | 16.49 | 3.94 (3.09 to 5.02) | 2 | 2.34 | 0.85 (0.23 to 3.12)
Sutcliffe et al, 2000^230^ | FDRs and SDRs in high-risk families who test negative for BRCA | Families with ≥2 FDRs with ovarian cancer | 56 families 382 relatives | 85 | | | | 4 | 0.35 | 11.6 (3.12 to 29.7)
Sutcliffe et al, 2000^230^ | FDRs and SDRs in high-risk families who test negative for BRCA | Families with ≥2 FDRs with ovarian cancer | 57 families 435 relatives | 85 | 9 | 2.71 | 3.32 (1.52 to 6.31)

Abbreviations: CI = confidence interval; FDR = first-degree relative; NA = not applicable; SDR = second-degree relative.

#### True Negative Results

A true negative result is possible for individuals who have relatives with cancer and a known BRCA mutation segregating in the family, but their own results are negative.

Ten studies provided data for the meta-analysis of SIRs for the development of breast cancer in women with true negative results compared with estimates for the general population (Table 15).175,177,180,181,184-186,196,198,201 Although SIR estimates ranged from 0.39 to 2.9 across studies, the CI for all studies included the value 1.0, indicating that the estimated risk was not statistically significantly different from that in the general population. The overall combined SIR estimate for breast cancer is 1.13 (95% CI, 0.81 to 1.58) (Figure 4).

Figure 4 Meta-Analysis of Studies of Breast Cancer Incidence in Women With True Negative Results

* Per 10,000 person-years.

Abbreviations: CI = confidence interval; NA = not applicable; SIR = standardized incidence ratio.

Figure 4 shows a forest plot diagram of breast cancer incidence for women with true negative results. Ten studies are shown. The overall data for the 10 studies in this table were: heterogeneity of 24.3%, p of 0.219, and a SIR of 1.13.

Most studies included women as true negatives only if their genotype was known by direct testing or could be inferred from the known genotypes of their relatives (e.g., descendants of an individual who tested negative were inferred to also be mutation negative). However, two studies probabilistically assigned genotypes for a portion of women who were untested and whose genotypes were unknown.180,186 This approach would bias the results toward the null hypothesis of no difference between groups because of misassignment of genotypes. Also, all studies except one180 used a prospective design that included only newly diagnosed cancer cases after the identification of the family. A study design that includes cancer diagnoses known prior to the identification of the family could falsely increase the risk estimate in relatives because the family may be more likely to seek testing. Bias could also be introduced in studies that did not control for risk-reducing salpingo-oophorectomy in the analysis.175,177,180,198

Two studies provided data for the SIR for the development of ovarian cancer in women with true negative results compared with estimates for the general population, although results differed (Figure 4, Table 15).198,201 One study reported an SIR of 0 (95% CI, 0 to 12) for BRCA1 and 0 (95% CI, 0 to 24) for BRCA2.^201^ A second study reported an increased risk of ovarian cancer with a SIR of 4.6 (95% CI, 1.2 to 11.7).198 However, this analysis was not conducted prospectively, and its ascertainment of families with strong family histories of breast and ovarian cancer could bias results. For this same study, the SIR estimate for breast cancer decreased from 5.3 (95% CI, 3.5 to 7.7) to 2.1 (95% CI, 0.4 to 6.2) after accounting for prospectively identified breast cancer cases only.

## Key Question 3c What Are the Potential Adverse Effects of Genetic Testing?

### Summary

Thirteen cohort, case-control, and before-after studies reported distress measures and risk perception related to BRCA testing. Limitations of studies included high loss to followup and differences between comparison groups. In these studies, breast cancer worry and anxiety increased for women with positive results and decreased for others, although results differed across studies. Risk perception improved after receiving test results.

### Evidence

Thirteen new observational studies met inclusion criteria,235-249 as well as one included previously.250 Studies provided data about distress due to BRCA testing measured as worry, anxiety, depression, or other psychosocial outcomes (Table 16, Appendix C9). No studies described other adverse effects of testing, such as false-positive or false-negative results or unnecessary risk-reducing interventions.

Table 16 Studies of Distress After Genetic Testing

Author, year, quality rating | N, study design | Mutation status | Genetic counseling | Comparison | Measures of distress | Breast cancer worry | Anxiety | Depression
Current report
Arver et al, 2004^235^ NA | 63; pre-post | Positive or negative | Genetically trained oncologist and oncology nurse | A. Pretest; B. 2 months post results; C. 1 year post results | HADS, SF-36 | NR | X decrease C & B vs. A | 0
Dagan and Shochat, 2009^236^ Fair | 73; case-control | Positive or negative | Unknown | A. Carriers (n=17); B. Noncarriers (n=20); C. Age-matched controls (n=36) | HR-QOL, CRW, BSI | X higher A & B vs. C | 0 | 0
Ertmanski et al, 2009^237^ NA | 56; pre-post | Positive | Unknown | A. Pretest; B. 1 month post results; C. 1 year post results | STAI, IES | NR | 0 | NR
Foster et al, 2007^238^ Fair | 154; prospective cohort | Positive or negative | Unknown | A. Carriers (n=53); B. Noncarriers (n=101) | GHQ, CWS-R | X decrease over time for A & B | X increase over time for A & B | NR
Geirdal et al, 2005^240^ Good | 10,244; prospective cohort | Positive or unknown | Unknown | A. Positive (n=68); B. Not tested but FBOC (n=176); C. Not tested, age-matched controls (n=10,000) | HADS, GHQ, BHS, IES | NR | X higher B vs. A | X higher B vs. A
Geirdal and Dahl, 2008^239^ Good | 242; prospective cohort | Positive or unknown | Unknown | A. Positive (n=68); B. Not tested, but FBOC (n=174) | HADS, COPE | NR | X higher B vs. A | NR
Kinney et al, 2005^243^ Poor | 52; prospective cohort | Positive or negative | Certified genetic professional | A. Carriers (n=NR); B. Noncarriers (n=NR) | STAI, IES, CES-D | NR | X decrease B only over time | NR
Low et al, 2008^244^ Fair | 47; prospective cohort | Positive, true negative, or uncertain (grouped with true negative) | Genetic counselor | A. Positive (n=7); B. True negative + uncertain (n=40) | IES-R, COPE, PTGI | NR | X higher A vs. B | NR
Metcalfe et al, 2012^249^ NA | 17; pre-post | Positive | Unknown | A. Pretest; B. 1 year post results; C. 2 years post results | IES | X increase B vs. A & C | NR | NR
Reichelt et al, 2004^245^ Good | 209; prospective cohort | Positive, negative, or unknown | Medical geneticist or experienced genetic counselor | A. Carriers (n=141); B. Noncarriers (68) | HADS, GHQ, BHS, IES | NR | 0 | 0
Reichelt et al, 2008^246^ NA | 181; pre-post | Positive or true negative | Genetic counselor | A. Pretest; B. 6 weeks post results; C. 18 months post results | HADS, IES | NR | 0 | 0
van Dijk et al, 2006^248^ Good | 132; prospective cohort | Positive, true negative, or uninformative | Unknown | A. Positive (n=22); B. True negative (n=41); C. Uninformative (n=69) | IES, NSI | X higher A vs. B & C | X higher A vs. B & C | NR
Prior report
Meiser et al, 2002^250^ Good | 143; prospective cohort | Positive or negative | Unknown | A. Carriers (n=30); B. Noncarriers (n=59); C. Not tested (n=51) | BDI, IES, MBSS, STAI, NSI | X higher A vs. C | X lower B vs. A & C | X lower B vs. A & C

X = statistically significant; 0 = studied but not significant.

Abbreviations: BDI = Beck Depression Inventory; BHS = Beck Hopelessness Scale; BSI = Brief Symptom Inventory; CES-D = Center for Epidemiologic Studies-Depression Scale; COPE = Emotional Approach Coping Scale; CRW = Cancer-Related Worry Scale; CWS-R = Cancer Worry Scale-Revised; FBOC = familial breast and/or ovarian cancer; GHQ = General Health Questionnaire; HADS = Hospital Anxiety and Depression Scale; HR-QOL = Health Related-Quality of Life; IES = Impact of Events Scale; IES-R = Impact of Events Scale-Revised; MBSS = Miller Behavioral Style Scale; NA = not applicable; NR = not reported; NSI = not standardized instrument; PTGI = Post-Traumatic Growth Inventory; SF-36 = Swedish SF-36 Health Survey; STAI = State-Trait Anxiety Inventory.

Of eight included cohort studies, five met criteria for good-quality,239,240,242,245,248,250 two for fair-quality,238,244 and one for poor-quality.243 The remaining studies included a fair-quality case-control study236,247 and five studies with before-after designs for which quality rating criteria were not available.235,237,241,246,249 Limitations of studies included unclear enrollment of the cohort,238,243,244 high loss to followup,244 and significant differences between groups at baseline or lack of reporting of baseline participant characteristics.238,243,244

The studies varied in size from 17 to 10,244 women; however, the largest study was dominated by the control group (n=10,000).240 Studies enrolled women with family histories of breast and ovarian cancer seeking genetic testing for BRCA1 or BRCA2 mutations. Several studies reported outcomes by mutation status,236,238-240,242-245,247,248,250 while others compared outcomes before and after genetic testing.235,237,241,246,249

Descriptions of the outcome measures are provided in Table 7. The studies used the IES, Cancer-Related Worry scale, and CWS-R to measure breast cancer worry; the STAI, IES, Post-Traumatic Growth Inventory, HADS, GHQ, Swedish Short-Form 36-Item Health Survey, Emotional Approach Coping Scale, Multidimensional Fatigue Symptom Inventory-Short Form, Beck Hopelessness Scale, Brief Symptom Inventory, Beck Depression Inventory, and Center for Epidemiologic Studies-Depression Scale to measure anxiety and depression; and the Pittsburgh Sleep Quality Index to measure sleep disturbances.

#### Breast Cancer Worry

Five studies reported significant increases in breast cancer worry after receiving BRCA test results.236,241,248-250 A good-quality prospective cohort study used a single question to measure worry on a four-item Likert scale: “During the last 2 weeks, how often did you worry about developing breast cancer?”248 Women who were mutation carriers had a significant increase in worry compared with women with true negative or uninformative results 1 and 7 months after disclosure of genetic testing results (p<0.05). A fair-quality case-control study found no differences in worry between women who were carriers and women who were noncarriers with high-risk family history, as reported by the Cancer-Related Worry scale.236 However, when results were combined for both groups, their levels of worry were significantly higher than that of low-risk women who were not tested (p=0.022).

A decrease in breast cancer worry for both women who were carriers and women who were noncarriers from baseline to 3 years after disclosure of genetic test results was reported in one study (mean decrease of 1.3 and 2.2, respectively), as measured by the CWS-R.238 This decrease was significant for women who were mutation carriers (p=0.03) and did not differ between groups. A study of 17 women who were mutation carriers reported an increase in breast cancer worry from baseline to 1 year after disclosure of genetic test results and a decrease at 2 years, though scores remained in the mild distress range, as measured by the IES (5.2 vs. 23.8 vs. 17.2; p=0.05).249 In a good-quality cohort study, women who were carriers had higher breast cancer worry, as measured by the IES, compared with women who did not get tested (mean, 16.1 vs. 12.3, respectively; p=0.045).250 One cohort study included a logistic regression bivariate analysis of responses of women undergoing genetic testing. In women without cancer, a positive genetic test result was associated with distress (p=0.03), while a negative result was associated with pleasant experiences with the testing process (p=0.008).241

#### Anxiety

Two studies reported significant decreases in anxiety scores after women received genetic test results compared with pretest evaluations, based on HADS and IES scores.235,243 One study reported a significant decrease regardless of mutation status (mean, 5.6 pretest vs. 4.2 at 1 year posttest; p<0.001),235 while the other reported a significant decrease only in women who were noncarriers (p=0.001).243 A fair-quality prospective cohort study reported an increase in anxiety scores over time on the GHQ.238 In this study, 18 percent of women who were carriers and 17 percent of women who were noncarriers were identified as having anxiety, based on the GHQ 3 years after receiving genetic test results.

Two prospective cohort studies, one good-quality248 and one fair-quality,244 reported significantly higher anxiety scores (p<0.05 in both studies), as measured by the IES or IES-R, in women receiving a positive genetic test result compared with women receiving a true negative or uninformative test result. Only one of these studies reported results in the moderate distress range on the IES at baseline for all groups; women with a true negative or uninformative test result had scores decreasing to below case threshold by 7 months.248 One good-quality prospective cohort study reported higher anxiety scores, as measured by the HADS, in women who did not get genetic testing, but had a family history of breast cancer, compared with women who received a positive genetic test result (mean, 5.3 vs. 4.2, respectively; p<0.05).239,240 However, there were no differences between groups in the prevalence of HADS-defined anxiety (24% in both groups).

In a good-quality cohort study, women who were noncarriers had lower anxiety scores on the STAI at 7 to 10 days followup (mean, 31.6 vs. 38.5 vs. 36.8, respectively; p=0.024) compared with women who were carriers and women who did not get tested, though all scores indicated high anxiety.250 Four studies reported no differences in anxiety either over time237,246 or between women who were carriers, noncarriers, and age-matched controls,236,245 with all below the case cutoff threshold.

#### Depression

Only one good-quality prospective cohort study reported higher depression scores, as measured by the HADS, in women who did not get genetic testing, but had a family history of breast cancer, compared with women receiving positive BRCA test results (mean, 2.9 vs. 1.7, respectively; p<0.05), though scores did not reach the threshold for clinical depression.240 Four studies reported no differences in depression either over time235,246 or between women who were carriers, noncarriers, and age-matched controls,236,245 with all scores below the case cutoff threshold. In a good-quality cohort study, women who were noncarriers had lower depression scores, as measured by the Beck Depression Inventory, at 4 months followup (mean, 3.6 vs. 6.2 vs. 6.4, respectively; p=0.024) compared with women who were carriers and women who did not get tested, though scores did not reach the threshold for clinical depression.250

#### Sleep Disturbances

A fair-quality case-control study reported more subjective sleep problems, as measured by the Pittsburgh Sleep Quality Index, in women who were carriers compared with women who were noncarriers and age-matched controls (mean, 7.29 vs. 3.94 vs. 4.21, respectively; p=0.013).247 However, actual sleep duration, latency, and wakefulness, as measured by a wrist monitor, showed no differences between groups.

#### Other Outcomes

Two small (n=13 and n=7) descriptive case-series studies did not meet eligibility criteria, but provided outcomes relevant to harms to familial relationships.251,252

A study of women with true negative test results reported that they were relieved to find out they were not carriers, and several women described feeling particularly reassured that their children would also not have the mutation.251 Most women (10/13 [67%]) believed their risk of developing breast or ovarian cancer continued to be slightly higher than that of the general population and therefore chose to undergo intensive screening. These women also decreased their communication about mutation status with other family members, especially those who were BRCA-positive.

A study of women with test results indicating the presence of BRCA mutations indicated that women were still grappling with how to live with their carrier status 3 years after disclosure of test results.252 Some women felt comforted by other mutation carriers in the family, but felt less comforted by the noncarriers. Several women had undergone risk-reducing mastectomy, oophorectomy, or both, and although they felt assured knowing they had done everything they could to reduce their risks of developing cancer, they also felt a loss of their natural breasts and ovarian hormones. This study also described that women struggled with what to tell their daughters, and how and when to tell them about their mutation status.

#### Risk Perception

A good-quality prospective cohort study reported an 18 percent increase in the number of women who perceived their risk of breast cancer to be high or very high 5 years after receiving a positive test result for a BRCA mutation versus before receiving results (p=0.016).242 Women who were noncarriers had a corresponding 47 percent decrease (p<0.001). Also, 20 percent more women who were mutation carriers perceived their risk of ovarian cancer to be high or very high (p=0.007), while 27 percent of women who were noncarriers perceived their risk to be low (p<0.001).

### Supplemental Information on the Impact of Genetic Testing on Family Members

Testing for BRCA mutations and disclosure of mutation status can have an impact beyond the patient in the clinician's office. While there are conflicting opinions and rulings on a clinician's ethical and legal duty to warn a patient's family about hereditary disease risk,253 patients may want to inform family members themselves.254,255 Studies indicate that most patients feel a responsibility to share their BRCA test results with family members in order to benefit them.256,257

A descriptive study of 162 women who were tested for BRCA mutations and 444 relatives indicated that 69.4 percent of tested women shared their test results with at-risk relatives, but more often with female (sisters or daughters) rather than male relatives (brothers and sons) (79.9% vs. 60.4%; p<0.001).258 More women who tested positive for a BRCA mutation indicated that they had a difficult time explaining the results compared with those with true negative or indeterminate results (14.6% vs. 0% vs. 1.4%, respectively; p<0.001). In addition, women who tested positive were more likely to indicate that they and their relatives were upset when communicating the results compared with women who had true negative or indeterminate results (upset relatives, 52.4% vs. 10.0% vs. 7.4%, respectively; p<0.001; upset patient, 19.5% vs. 0% vs. 1.9%, respectively; p<0.001).

A descriptive study of 115 women who were BRCA mutation carriers reported that all participants disclosed test results to some at-risk relatives, and 88 percent disclosed to all at-risk relatives.259 However, only 56.8 percent of at-risk relatives subsequently underwent testing, although female relatives were more likely to have testing compared with male relatives (73% vs. 49%, respectively; p<0.01).

Four descriptive studies focused on disclosure of BRCA test results to children. Two small studies indicated that women who were mutation carriers who disclosed their positive test results to their children did so because of their concern about passing along the gene.260,261 In a study of 13 tested parents and 22 adult children, 77 percent of children felt the disclosure had no significant impact on their emotional health, while 18 percent reported a negative impact.262 Only 31.8 percent of children had undergone BRCA testing by the time of the survey, but 87 percent of those who had not undergone testing indicated intention to do so. A small study of children ages 11 to 17 years who had mothers with BRCA mutations reported normal scores on anxiety and depression measures (STAI) after hearing of their mother's test results.263 However, 70 percent of children had mothers with breast cancer, and 57 percent of them had worrisome thoughts about their mother's cancer that affected their feelings at least some of the time. Children who worried about their own cancer risk were more likely to be withdrawn (p=0.02) and have somatic problems (p=0.003), and children who worried about a family member's cancer risk were more likely to have thought problems (p=0.02).

### Supplemental Information on the Effects of Direct-to-Consumer Marketing of BRCA Mutation Testing

Until the U.S. Supreme Court decision against DNA patents in June 2013,^264,265^ Myriad Genetics held patents on the direct DNA sequencing of BRCA1 and BRCA2 mutations and was the exclusive provider of clinical testing in the United States.266 Myriad allowed other laboratories to conduct direct DNA sequencing for research purposes under strict constraints. Testing for specific known mutations, including previously identified familial types and Ashkenazi Jewish founder mutations, does not require full sequence testing and has been provided by other laboratories. Although other types of genetic tests were patented in the United States, they were nonexclusively licensed. For example, genetic testing for familial colorectal cancer has been available from multiple laboratories.267

Myriad launched its initial direct-to-consumer advertising campaign in 2002, targeting potential patients in specific U.S. markets. Advertising included print and electronic media to raise awareness of breast cancer susceptibility genes and encourage women to speak to their physicians about testing. A study to determine the impact of the marketing campaign on patients and physicians was conducted by the Centers for Disease Control and Prevention.268 This study surveyed randomly selected women from the community as well as family physicians, internists, obstetrician/gynecologists, and oncologists in 2003, comparing two pilot cities with marketing campaigns (Atlanta and Denver) with two control cities that had no marketing (Seattle and Raleigh-Durham).

In pilot cities, women reported increased awareness of the BRCA test (p<0.05) and seeing an advertisement for the test (p<0.05).268 Cities did not differ by women's interests in having the test, overall knowledge about genetic testing for breast and ovarian cancer, and if they had ever talked to health care providers or friends/family about the test.268 Physicians' knowledge did not differ between sites.269 In pilot cities, there were increases in patients asking about testing (adjusted odds ratio [AOR], 2.1 [95% CI, 1.6 to 2.9]), asking for referrals (AOR, 1.6 [95% CI, 1.1 to 2.4]), and asking directly for testing (AOR, 2.1 [95% CI, 1.5 to 3.0]).269 In pilot cities, 14 percent of physicians reported an increase in the number of times they ordered BRCA testing in the previous 6 months compared with 7 percent of physicians in control cities (AOR, 1.9 [95% CI, 1.2 to 3.1]).269

A telephone survey to assess the impact of direct-to-consumer marketing among women of varying genetic risk was conducted in 315 women enrolled in a registry of families with cancer in Denver, a Myriad marketing site.270 In this study, high-risk women were more knowledgeable about the test and more likely to recall media advertisements than low-risk women (60% vs. 39%; p<0.01). Approximately 40 percent of women were interested in testing and 10 percent had increased worry about cancer after viewing the advertisements. However, women across all risk groups overstated the benefits of testing, and equal numbers of high- and low-risk women thought they would benefit from testing (51% vs. 60%).

Another study in Denver surveyed 750 low-risk women, 100 high-risk women, and 180 primary care providers in a managed care organization.271 Sixty-two percent of patient respondents described exposure to the Myriad advertisements, and 63 percent with exposure reported that the advertisements caused no anxiety. However, some women reported anxiety from the advertisements, including women with high levels of perceived breast cancer risk (AOR, 3.23 [95% CI, 1.35 to 7.73]) and Hispanic women (AOR, 4.19 [95% CI, 1.48 to 11.83]). Women who viewed the advertisements had greater knowledge about testing. Eighty-four percent of physicians reported that the advertisements caused no strain on the doctor-patient relationship, and 80 percent reported no effect on daily clinical practice.

A study of referrals to genetic counseling in the same managed care organization in Denver was compared with a similar organization in a nonmarketed city.272 Results indicated a 244 percent increase in referrals during the marketing campaign compared with the previous year (p<0.001), although the proportion of referrals of high-risk women declined from 69 percent to 48 percent (p<0.001) during the campaign. No changes in practice were detected in the nonmarketed organization.

Myriad has recently launched a new campaign directly targeting mammography imaging centers and primary care, obstetrician/gynecology, and surgery practices. This strategy involves risk stratification using a simple checklist administered by a physician or nonphysician (e.g., mammography technician), patient consent, and specimen collection with subsequent testing by Myriad. Results are then sent to the ordering physician who follows up as needed. The impact of this approach has not yet been evaluated.

## Key Question 4 Do Interventions Reduce the Incidence of BRCA-Related Cancer and Mortality in Women With Increased Risk?

### Summary

No trials of the effectiveness of intensive screening for breast or ovarian cancer in women who are BRCA mutation carriers with cancer or mortality outcomes have been published. Six observational studies that reported test characteristics of breast and ovarian cancer screening are described. Overall, the sensitivity of screening for breast cancer with MRI was higher than with mammography (71% vs. 41%), while specificity was comparable (90% vs. 95%). Sensitivity of screening for ovarian cancer was 43 percent for TVUS and 71 percent for serum CA-125 testing, and specificity was 99 percent.

There are no trials of risk-reducing medications specifically in women who are BRCA mutation carriers. A systematic review and meta-analysis of four tamoxifen and two raloxifene placebo-controlled RCTs and one head-to-head trial (Study of Tamoxifen and Raloxifen Trial [STAR]) provided efficacy outcomes for women who had various risk levels. Trials were limited by heterogeneity, and data on doses, duration, and timing of use were lacking. Tamoxifen and raloxifene reduced invasive breast cancer by 30 to 68 percent compared with placebo (7 to 9/1,000 women over 5 years); tamoxifen had a greater effect than raloxifene in the STAR trial (5/1,000 women over 5 years). Reduction was greater in women with family history of breast cancer, but CIs were overlapping. Reduction was significant for ER-positive but not ER-negative breast cancer. Noninvasive breast cancer and mortality were not significantly reduced and did not differ between medications.

Four studies reported descriptive outcomes of risk-reducing mastectomy, one study reported outcomes after salpingo-oophorectomy, and three studies reported outcomes after oophorectomy. Comparison groups varied between studies, although results were consistent. Risk-reducing bilateral mastectomy reduced breast cancer by 85 to 100 percent in high-risk women and women who were mutation carriers; oophorectomy or salpingo-oophorectomy reduced breast cancer 37 to 100 percent and ovarian cancer 69 to 100 percent in high-risk women and women who were mutation carriers. Breast cancer–specific mortality was reduced by 81 to 100 percent after risk-reducing mastectomy in one study and all-cause mortality was reduced by 55 to 100 percent after risk-reducing salpingo-oophorectomy in another study.

### Evidence

#### Intensive Screening

Breast Cancer. No studies from the previous review met inclusion criteria for the updated review. No RCTs of the effectiveness of intensive screening to reduce breast cancer incidence or mortality in women who are at increased risk were identified by searches. Four observational studies, including three prospective studies273-275 and one retrospective analysis of a prospective study,276 provided descriptive information about test characteristics of screening modalities (Table 17, Appendix C10). In these studies, prevalent cases were defined as women with cancer detected on the first round of screening and incident cases were those detected on subsequent rounds.273,277,278

Table 17 Studies of Test Characteristics of Mammography vs. MRI for Breast Cancer Screening^*^

Author, year | Risk categories, n | Inclusion criteria | Mean age at entry, y (range) | Screening interval | Followup, mo | Mammography vs. MRI
Author, year | Risk categories, n | Inclusion criteria | Mean age at entry, y (range) | Screening interval | Followup, mo | | Sensitivity, % | Specificity, %
Cortesi et al, 2006^273^ | Mutation carrier: 48 High: 674 Intermediate: 257 Slight increase: 346 | BRCA carrier Positive FH Male breast cancer Suspected positive FH | 42 (20-75) 42 (15-75) 43 (19-67) 40 (18-75) | Varied by risk category and age | Median, 55 | Mutation carrier^†^ | 50 vs. 100 | NR
Leach et al, 2005^274^ MARIBS study | BRCA1: 39 BRCA2: 86 High: 424 | BRCA1 carrier/relative BRCA2 carrier/relative FH positive/other mutation/syndrome | Median, 40 (31-55) | Annual | Variable, ≥2 scans per woman | BRCA1 BRCA2 All women | 23 vs. 92^‡^; C=92 50 vs. 58; C=92 40 vs. 77^‡^; C=94 | 92 vs. 79^‡^; C=74 94 vs. 82^‡^; C=78 93 vs. 81^‡^; C=77
Le-Petross et al, 2011^276^ | BRCA1: 37 BRCA2: 36 | BRCA1 carrier/relative BRCA2 carrier/relative | Median 44 (23-75) | Bi-annual, alternating | Median, 24 | BRCA1/2 | Unable to report^§^ vs. 92 | 82 vs. 87
Rijnsburger et al, 2010^278^ Dutch MRISC study | BRCA1: 422 BRCA2: 172 High: 1069 Moderate: 489 Other: 5 | BRCA1 carrier BRCA2 carrier 30%-50% lifetime risk for BC║ (high-risk) 15%-30% lifetime risk for BC║ (moderate-risk) Other mutation carrier | BRCA1: 39 BRCA2: 40 High risk: 41 Moderate risk: 40 | Annual | 48 | BRCA1 BRCA2 High Moderate | 25 vs. 67^‡^ 62 vs. 69 46 vs. 77 47 vs. 67 | 95 vs. 91 94 vs. 92 95 vs. 89 95 vs. 90

* Includes women from families with known mutations or breast cancer.

† MRI was not used to screen other risk categories.

‡ p<0.05.

§ All screen-detected cancers were detected by MRI only; mammography was not performed after detection with MRI to calculate sensitivity.

║ Based on modified Claus tables.

Abbreviations: BC = breast cancer; C = mammography plus MRI; FH = family history; MARIBS = Magnetic Resonance Imaging Breast Screening; MRI = magnetic resonance imaging; MRISC = Magnetic Resonance Imaging Screening Study; NA = not applicable; NR = not reported.

The Dutch MRI Screening Study (MRISC), a prospective study, evaluated performance characteristics of breast cancer screening in 2,157 women with 15 percent or higher cumulative lifetime risks of breast cancer, including 594 women who were BRCA mutation carriers.278 Screening included biannual clinical breast examinations and annual concurrent contrast enhanced MRI and mammography. Digital mammography replaced film during the study period. In this study, women were categorized by mutation status or as high- or moderate-risk based on their family histories and risk factors as applied to modified Claus tables. The average age of participants at study entry was 40 years, and they were followed for a mean of 4 years. There were 97 breast cancer cases (78 invasive, 19 ductal carcinoma in situ [DCIS]) detected in 94 women, including 78 screen-detected cancer cases (15 prevalent, 63 incident), six of which were detected at risk-reducing mastectomy, and 13 interval cancer cases detected by the woman between screening rounds after initial negative results.

Analysis of results of 75 women with breast cancer indicated significantly higher sensitivity of MRI versus mammography (71% vs. 41%; p=0.0016). Both modalities had high specificity (MRI, 90%; mammography, 95%). Including only women with invasive cancer increased the sensitivity of MRI to 77 percent and decreased that of mammography to 36 percent (MRI vs. mammography, p=0.00005). In women who were BRCA1 carriers, the sensitivity of MRI was 67 percent versus 25 percent for mammography (p=0.0129), and for BRCA2, 69 percent versus 62 percent (p=1.0). Additional comparisons of the sensitivity of modalities between risk groups and by carrier status were not statistically significant. At diagnosis, 80 percent of invasive tumors were 2 cm or less in size, 39 percent were grade 3, and 31 percent were node positive. Women who were BRCA1 carriers were more likely to experience interval cancer, were younger at diagnosis, and had larger, higher grade tumors at diagnosis compared with other risk groups (p<0.05 for comparisons between all subgroups).

The Magnetic Resonance Imaging Breast Screening study was a prospective multicenter study conducted in the United Kingdom that evaluated screening of high-risk women using annual contrast enhanced MRI and mammography.274 The study enrolled 649 women, including 120 who were BRCA mutation carriers, with a median age at entry of 40 years. The duration of followup varied, but each woman completed at least two annual screenings. Thirty-five cancer cases (29 invasive, six DCIS) were detected, including two interval cancer cases.

The sensitivity of screening all women using mammography plus MRI (94%) was higher than that of using either method alone (MRI, 77%; mammography, 40%), though specificity was reduced when the methods were combined (77%) compared with either MRI alone (81%) or mammography (93%) alone. Including only invasive cancer cases increased MRI sensitivity to 86 percent, reduced mammography sensitivity to 31 percent, and increased the sensitivity of combined methods to 97 percent.

In women who were BRCA1 mutation carriers or were related to carriers, the sensitivity of screening with MRI alone (92%) or combined with mammography (92%) was higher than that of mammography alone (23%). However, the specificity of MRI alone (79%) or MRI plus mammography (74%) was less than that of mammography alone (92%). In women who were BRCA2 mutation carriers or were related to carriers, the sensitivity of screening with MRI plus mammography (92%) was higher than that of either method alone (MRI, 58%; mammography, 50%). The specificity of mammography alone (94%) was higher than that of MRI alone (82%) or MRI plus mammography (78%). At diagnosis, invasive cancer cases were an average 15 mm in size, 66 percent were grade 3, and 19 percent were node positive.

A prospective study of 1,325 high-risk Italian women, including 48 who were BRCA mutation carriers, evaluated a breast cancer screening program of mammography, ultrasound, and clinical breast examinations.273 MRI screening was introduced later in the study for women who were mutation carriers. Screening intervals varied by risk category, age, and modality and ranged between 6 months and 2 years. After a median followup of 55 months, 44 breast cancer cases (28 invasive, 16 DCIS) were detected, including 36 screen-detected cases and eight interval cases. In four women who were mutation carriers with screen-detected breast cancer, the sensitivity of screening with mammography was 50 percent, ultrasound 75 percent, ultrasound plus mammography 75 percent, and MRI 100 percent. At diagnosis, 61 percent of invasive breast cancer cases were stage I, 64 percent were less than 15 mm in size, and 36 percent were node positive.

A retrospective chart review of a prospective study of 73 women at a single institution in the United States evaluated outcomes after screening using MRI alternating with mammography every 6 months in addition to six monthly clinical breast examinations.276 Participants were mutation carriers or first-degree relatives at a high-risk cancer clinic with a median age of 44 years who had two screening cycles and were followed for a median of 2 years. Thirteen breast cancer cases (10 invasive, three DCIS) were detected in 11 patients. The sensitivity and specificity of MRI was 92 and 87 percent respectively.

Ovarian Cancer. The previous review included a descriptive study of TVUS screening in 1,610 women with family histories of ovarian cancer and reported that only six of 61 women with abnormal scans had ovarian cancer.279 A recently published large U.S. screening RCT, the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial, reported no mortality benefit of screening average-risk women ages 55 to 74 years with TVUS and serum CA-125 testing compared with usual care after a median followup of 12.4 years.280 This trial did not report outcomes specifically for high-risk women, including those who were BRCA mutation carriers.

One new descriptive study identified in updated searches reported test characteristics of TVUS and serum CA-125 testing (Appendix C10).281 A European prospective descriptive study evaluated the use of annual CA-125 measurement and TVUS from ages 30 to 35 years in women who were at increased risk. In 459 women who were BRCA carriers with complete data amounting to 1,116 annual screening visits, the sensitivity of serum CA-125 testing alone was 71 percent, TVUS alone was 43 percent, and combined modalities was 71 percent. Corresponding specificities were 99 percent for each modality alone and combined.281 The positive predictive value was 33 percent for serum CA-125 testing alone, 20 percent for TVUS alone, and 23 percent for combined modalities. Three percent of women had abnormalities detected by one or both screening modalities, and seven ovarian cancer cases were diagnosed.

#### Risk-Reducing Medications

The previous review identified no trials that evaluated the use of risk-reducing medications specifically in women who are mutation carriers, although the National Surgical Adjuvant Breast and Bowel Project (NSABP P-1) trial of tamoxifen described results for 288 women who were mutation carriers and who developed breast cancer during the trial.282 Of the eight women with breast cancer who had BRCA1 mutations, five received tamoxifen and three received placebo (RR, 1.67 [95% CI, 0.32 to 10.70]). Of 11 women with breast cancer and BRCA2 mutations, three received tamoxifen and eight received placebo (RR, 0.38 [95% CI, 0.06 to 1.56]). Also, 86 percent (6/7) of women with BRCA1 mutations had ER-negative breast cancer, and 67 percent (6/9) with BRCA2 mutations had ER-positive breast cancer.

The updated review identified no RCTs that evaluated use of risk-reducing medications specifically in women who are BRCA mutation carriers, although several RCTs of women who had various levels of risk have been published and summarized in meta-analyses.116,283 Four placebo-controlled trials of tamoxifen include the NSABP P-1 trial,284 Royal Marsden trial,285 Italian Randomized Tamoxifen Prevention Trial,286 and the International Breast Cancer Intervention Study (IBIS-I).287 Placebo-controlled trials of raloxifene include the Raloxifene Use for the Heart Trial (RUTH)73 and the Multiple Outcomes of Raloxifene Evaluation trial, with its followup study, Continuing Outcomes Relevant to Evista.288 The STAR289 trial was a head-to-head trial that compared raloxifene with tamoxifen. Inclusion criteria varied between trials, duration of active treatment ranged from 4 to 8 years, and followup ranged from 6 to 13 years. Additional details of the trials are provided in Appendix C11. Trials meeting fair-quality criteria were limited by incomplete reporting of followup,284,285,287 inadequate maintenance of comparable groups,284,285,287 high (>30%) crossover between groups,284 and low (<65%) numbers of participants completing all treatment years.285,286

Results of a published meta-analysis indicate that women randomized to either tamoxifen (RR, 0.70 [95% CI, 0.59 to 0.82]; 4 trials; 7 cases/1,000 women over 5 years) or raloxifene (RR, 0.44 [95% CI, 0.27 to 0.71]; 2 trials; 9/1,000 women) had reduced risks for invasive breast cancer compared with women randomized to placebo (Table 18).116,283 Updated results of the head-to-head trial indicated greater risk reduction with tamoxifen compared with raloxifene (RR for raloxifene, 1.24 [95% CI, 1.05 to 1.47]; 5/1,000 women).289 Tamoxifen and raloxifene reduced ER-positive but not ER-negative or noninvasive cancer in placebo-controlled trials, and had similar effects in the STAR trial. All-cause mortality was not reduced in placebo trials and was similar in the STAR trial.

Table 18 Results of Trials of Risk-Reducing Medications: Cancer and Mortality Benefits115,116

Outcome | Raloxifene vs. tamoxifen | | Tamoxifen vs. placebo | | | Raloxifene vs. placebo
Outcome | Risk ratio (95% CI) | Events reduced/increased, n (95% CI)^*^ | Risk ratio (95% CI) (Trials, n)^†^ | Placebo rate (SE)^‡^ | Events reduced/increased, n (95% CI)^*^ | Risk ratio (95% CI) (Trials, n)^†^ | Placebo rate (SE)^‡^ | Events reduced/increased, n (95% CI)^*^
Invasive breast cancer | 1.24 (1.05 to 1.47)^§^ | 5 (1 to 9) fewer tamoxifen | 0.70 (0.59 to 0.82) (4) | 4.70 (1.02) | 7 (4 to 12) fewer tamoxifen | 0.44 (0.27 to 0.71) (2) | 3.19 (0.59) | 9 (4 to 4) fewer raloxifene
ER+ invasive breast cancer | 0.93 (0.72 to 1.24)║ | | 0.58 (0.42 to 0.79) (4) | 3.67 (0.78) | 8 (3 to 13) fewer tamoxifen | 0.33 (0.18 to 0.61) (2) | 2.45 (0.42) | 8 (4 to 12) fewer raloxifene
ER- invasive breast cancer | 1.15 (0.75 to 1.77)║ | | 1.19 (0.92 to 1.55) (4) | | | 1.25 (0.67 to 2.31) (2)
Noninvasive breast cancer | 1.22 (0.95 to 1.59)^§^ | | 0.85 (0.54 to 1.35)^¶^ (4) | | | 1.47 (0.75 to 2.91) (2)
All-cause mortality | 0.84 (0.70 to 1.02)^§^ | | 1.07 (0.90 to 1.27) (4) | | | 0.84 (0.64 to 1.10)^**^ (2)

* Numbers of events reduced for benefits or increased for harms compared with placebo or other comparator per 1,000 women, assuming 5 years of use.

† If meta-analysis.

‡ Per 1,000 women. Estimated from a meta-analysis of rates from the placebo groups from the same trials included in the risk ratios.

§ Updated results from the Study of Tamoxifen and Raloxifene (STAR), 2010.

║ Initial results from STAR, 2006.

¶ Risk ratio for noninvasive breast cancer was significantly reduced in the 2005 National Surgical Adjuvant Breast and Bowel Project P-1 (60 vs. 93 events; RR, 0.63 [95% CI, 0.45-0.89]).

** Updated meta-analysis.

Abbreviations: CI = confidence interval; ER- = estrogen receptor negative; ER+ = estrogen receptor positive; SE = standard error.

Although no trials evaluated breast cancer incidence specifically in women who were BRCA mutation carriers, all trials evaluated breast cancer incidence by family history, except IBIS-I, in which 97 percent of participants reported some degree of family history.287 No trials evaluated breast cancer or all-cause mortality outcomes based on familial risk. Trials defined a positive family history as breast cancer in any first-degree relative, except the Royal Marsden trial, which also included second-degree relatives.285

In women randomized to tamoxifen, invasive breast cancer risk was further reduced for those with the highest numbers of affected relatives in the NSABP P-1 (RR for no relatives, 0.54 [95% CI, 0.34 to 0.83]; RR for ≥3 relatives, 0.49 [95% CI, 0.16 to 1.34]), although CIs were overlapping284 (Figure 5). The Royal Marsden trial reported similar findings (RR for 0–2 relatives, 0.51 [95% CI, 0.27 to 0.96]; RR for ≥3 relatives, 0.43 [95% CI, 0.19 to 0.95]).285 The Italian trial reported increased breast cancer risk in women with familial risk using tamoxifen, but the risk estimate was not statistically significant (RR, 1.43 [95% CI, 0.65 to 3.15]).286

Figure 5 Invasive Breast Cancer Risk Reduction With Tamoxifen Use, by Family History

* Per 1,000 women-years.

† Analysis restricted to ER-positive tumors.

‡ Type of breast cancer not reported.

§ Results not presented by family history (97% of participants had some family history).

Abbreviations: CI = confidence interval; IBIS-I = International Breast Cancer Intervention Study; Italian = Italian Randomized Tamoxifen Prevention Trial; NSABP P-1 = National Surgical Adjuvant Breast and Bowel Project P-1 Trial.

Figure 5 shows a forest plot diagram of the reduction in risk for invasive breast cancer with tamoxifen use, stratified by family history of breast cancer. Four trials are shown; the National Surgical Adjuvant Breast and Bowel Project (NSABP) P-1 Trial, the Royal Marsden Trial, the Italian Randomized Tamoxifen Prevention (Italian) Trial, and the International Breast Cancer Intervention (IBIS-I) Study. The forest plot visually displays risk estimates that all favor tamoxifen, aside from one, with overlapping confidence intervals.

In women randomized to raloxifene, the Multiple Outcomes of Raloxifene Evaluation and Continuing Outcomes Relevant to Evista trials indicated a greater reduction in breast cancer risk in women with at least one affected first-degree relative (adjusted hazard ratio [HR] for no relatives, 0.55 [95% CI, 0.36 to 0.84]; HR for ≥1 relative, 0.16 [95% CI, 0.06 to 0.42])288 (Figure 6). RUTH indicated no significant effect of family history.73 The raloxifene trials were primarily designed to determine its effect on osteoporosis and heart disease outcomes and only a minority of participants reported family histories of breast cancer. In the STAR trial comparing tamoxifen and raloxifene, the effect of family history was not statistically significant.289

Figure 6 Invasive Breast Cancer Risk Reduction With Raloxifene Use, by Family History

* Per 10,000 women-years.

† Adjusted for age, estradiol level.

‡ Per 1,000 women-years.

Abbreviations: CI = confidence interval; CORE = Continuing Outcomes Relevant to Evista Trial; FH = family history; MORE = Multiple Outcomes for Raloxifene Evaluation Trial; NR = not reported; RUTH = Raloxifene Use for the Heart Trial; STAR = Study of Tamoxifen and Raloxifene Trial.

Figure 6 shows two forest plot diagrams of the reduction in risk for invasive breast cancer with raloxifene use, stratified by family history of breast cancer. The first diagram depicts the risk reduction using raloxifene compared with placebo. Two trials are shown; the Raloxifene Use for the Heart (RUTH) trial and the Multiple Outcomes for Raloxifene Evaluation (MORE) trial, with its followup study, the Continuing Outcomes Relevant to Evista (CORE) trial. The forest plot visually displays risk ratios favoring raloxifene, with overlapping confidence intervals. The second diagram depicts reduction in risk for invasive breast cancer using raloxifene compared with tamoxifen, stratified by family history. One trial is shown, the Study of Tamoxifen and Raloxifene (STAR). The forest plot visually displays risk ratios favoring tamoxifen, with overlapping confidence intervals.

#### Risk-Reducing Surgery

Mastectomy. Four studies met inclusion criteria; one from the previous review290,291 and three from updated searches.292-294 The prior evidence review included a retrospective descriptive study based on data from patients' medical records.290,291 In women who underwent risk-reducing mastectomy, breast cancer was reduced by 92 percent in high-risk women compared with sister controls, and by 89.5 percent in moderate-risk women compared with Gail model-based expected incidence.291 Postmastectomy breast cancer–related deaths were reduced by 81 percent in high-risk women compared with sister controls, and by 100 percent in moderate-risk women compared with expected rates.290 When the high-risk group was evaluated for BRCA status, none of the 18 women who were mutation carriers developed postmastectomy breast cancer compared with the 4.5 (low-penetrance model) and 6.1 (high-penetrance model) cases that were expected.295

Since the prior review, three new prospective studies reported breast cancer outcomes after risk-reducing bilateral mastectomy292-294 (Table 19, Appendix C12). Cohort studies met criteria for good-quality294 or fair-quality,292 and one descriptive study could not be rated for quality.293 The fair-quality study was limited by a lack of information about groups at baseline, attrition, and followup.292

Table 19 Studies of Risk-Reducing Surgery

Author, year, quality rating | Inclusion criteria | Risk factors Enrolled, n | Mean age at surgery, y | Breast cancer incidence Risk estimate (95% CI) | Ovarian cancer incidence Risk estimate (95% CI) | Mortality Risk estimate (95% CI) | Mean followup,^*^ y
Mastectomy
Surgery vs. no surgery
Domchek et al, 2010^292^ Fair | BRCA 1/2 carrier No history of salpingo-oophorectomy | BRCA1 positive n=415^†^ | 37 | 0/43 vs. 19/372 HR NA | NR | NR | 2.7
Domchek et al, 2010^292^ Fair | BRCA 1/2 carrier No history of salpingo-oophorectomy | BRCA2 positive n=245^‡^ | 39 | 0/32 vs. 15/213 HR NA | NR | NR | 2.5
Skytte et al, 2011^294^ Good | BRCA1/2 carrier No history of mastectomy or salpingo-oophorectomy | BRCA1 positive n=201 BRCA2 positive n=10 | NR | 3/96 vs. 16/211 HR, 0.39 (0.12 to 1.36) | NR | NR | NR^§^
Surgery group (observed vs. expected)║
Evans et al, 2009^293,¶^ NA | Lifetime risk of breast cancer >25% | High-risk BRCA1/2 positive^**^ n=202 | NR | 0/307 vs. 21.3 HR NA | NR | NR | 7.5
Salpingo-oophorectomy or oophorectomy
Surgery vs. no surgery
Domchek et al, 2010^292,¶^ Fair | BRCA1/2 carrier No history of salpingo-oophorectomy | BRCA1 positive n=1003^†^ | 42 | 14% (32/236) vs. 20% (129/633) HR, 0.63 (0.41 to 0.96) | 2% (6/342) vs. 7% (49/661) HR, 0.31 (0.12 to 0.82) | All cause: 2% (8/327) vs. 7% (43/608) HR, 0.52 (0.24 to 1.14) | 5.6
Domchek et al, 2010^292,¶^ Fair | BRCA1/2 carrier No history of salpingo-oophorectomy | BRCA2 positive n=554^‡^ | 46 | 7% (7/100) vs. 23% (94/401) HR, 0.36 (0.16 to 0.82) | 0/123 vs. 14/431 HR NA | All cause: 0/120 vs. 17/403 HR NA | 5.8
Kramer et al, 2005^185,††^ Fair | BRCA1-positive family^‡‡^; no history of bilateral mastectomy | BRCA1 positive n=98 | NR | 18% (6/33) vs. 42% (27/65) HR, 0.38 (0.15 to 0.97) | NR | NR | 16.5
Kramer et al, 2005^185,††^ Fair | BRCA1-positive family^‡‡^; no history of bilateral mastectomy | BRCA1 negative n=353 | NR | 3% (1/34) vs. 1% (4/319) HR NR | NR | NR | 16.5
Kramer et al, 2005^185,††^ Fair | BRCA1-positive family^‡‡^; no history of bilateral mastectomy | Undetermined mutation status n=222 | NR | 0% (0/18) vs. 2.5% (5/204) HR NA | NR | NR | 16.5
Surgery group (observed vs. expected)^§§^
Olson et al, 2004^296,††^ NA | Women with bilateral oophorectomy | High-risk║║ Surgery <60 years n=55 | <60 | 3/55 vs. 5.4 RR, 0.56 (0.11 to 1.33) | NR | NR | NA
Olson et al, 2004^296,††^ NA | Women with bilateral oophorectomy | Surgery <50 years n=41 | <50 | 1/41 vs. 3.9 RR, 0.26 (0.001 to 0.99) | NR | NR | NA
Olson et al, 2004^296,††^ NA | Women with bilateral oophorectomy | Moderate risk^¶¶^ Surgery <60 years n=193 | <60 | 9/193 vs. 10.9 RR, 0.83 (0.38 to 1.44) | NR | NR | NA
Olson et al, 2004^296,††^ NA | Women with bilateral oophorectomy | Surgery <50 years n=130 | <50 | 5/130 vs. 7.7 RR, 0.65 (0.21 to 1.32) | NR | NR | NA
Prior report
Mastectomy
Hartmann et al, 1999^290^ Hartmann et al, 2001^291^ NA | Family history of breast cancer | High risk n=214 | 42 | 3/214 vs. 37 expected^***^; risk reduction, 92% (77% to 98%) | n=2 | Breast cancer: 2/214 vs.10 expected^***^; risk reduction, 81% (31% to 98%) | 14 (median)
Hartmann et al, 1999^290^ Hartmann et al, 2001^291^ NA | Family history of breast cancer | Moderate risk n=425 | 42 | 4/425 vs. 37 expected^‡‡^; risk reduction, 89.5% (p<0.001) | n=0 | Breast cancer: 0/425 vs. 10 expected^‡‡^; risk reduction, 100% (70% to 100%) | 14 (median)
Hartmann et al, 1999^290^ Hartmann et al, 2001^291^ NA | Family history of breast cancer | BRCA1 or BRCA2 positive^†††^ n=18 | 41 | 0/18 vs. 6.1/18 expected^‡‡‡^; risk reduction, 100% (51% to 100%) 0/18 vs. 4.5/18 expected^§§§^; risk reduction, 100% (33% to 100%) | NR | NR | 13.4 (median)
Oophorectomy (surgery vs. no surgery)
Struewing et al,1995^229^ Poor | Families with ≥3 cases of ovarian cancer or ≥2 cases of ovarian cancer and ≥1 cases of breast cancer <age 50 | First-degree relatives of breast or ovarian cancer cases n=390 N =12 families | NR | 3/44 vs. 14/346 Risk estimate: NR | 2/44 vs. 8/346║║║ Risk estimate: NR | NR | NR^¶¶¶^

* Based on followup to censoring date.

† BRCA1 carriers evaluated in group including those with and without surgery.

‡ BRCA2 carriers evaluated in group including those with and without surgery.

§ Total at-risk time in surgery group was 378.7 years vs. 934.6 years in the no surgery group.

║ Expected incidence based on life tables.

¶ Study included women with prior breast cancer; only data on women with no prior breast cancer included in evidence review.

** Total number of women with BRCA1/2 mutation, regardless of breast cancer history; study did not provide the number of women with a mutation and no prior history of breast cancer.

†† Oophorectomy performed.

‡‡ Families testing positive for BRCA1 mutation; families had multiple breast and ovarian cancer cases prior to testing.

§§ Expected incidence based on Gail model.

║║ One first-degree relative with breast cancer before age 50 years or one first-degree relative with ovarian cancer at any age and at least one other first- or second-degree relative with either diagnosis at any age.

¶¶ One first-degree relative with breast cancer at any age.

*** Based on control group of sisters.

††† Subgroup of high-risk group.

‡‡‡ Based on high-penetrance model.

§§§ Based on low-penetrance model.

║║║ Incidence includes postoophorectomy ovarian carcinomatosis.

¶¶¶ Followup for ovarian cancer incidence was 1665 person-years for no surgery group, 460 person-years for surgery group; followup for breast cancer incidence was 1587 person-years for no surgery group, 484 person-years for surgery group.

Abbreviations: CI = confidence interval; HR = hazard ratio; NA = not applicable; NR = not reported; RR = relative risk.

A study enrolling women from 22 North American and European centers evaluated outcomes for women with BRCA mutations.292 During 2.7 years of followup, no women who had risk-reducing mastectomies were diagnosed with breast cancer compared with 34 of 585 (5.8%) women who did not have mastectomies.

Another study compared observed with expected breast cancer cases in women with BRCA mutations or who were otherwise considered at high risk. Results indicated that none of 307 women who had bilateral mastectomies were diagnosed with breast cancer, while 21.3 cases were expected.293 In a study of women who were mutation carriers in Denmark, three of 96 (0.8% per person-year) women who underwent mastectomy were diagnosed with breast cancer versus 16 of 211 (1.7% per person-year) who did not (HR, 0.39 [95% CI, 0.12 to 1.36]), although the study was inadequately powered for this outcome.294

Salpingo-Oophorectomy or Oophorectomy. Four studies met inclusion criteria; one from the previous review229 and three from updated searches.185,292,296 The previous evidence review included a prospective cohort study of women from families with high ovarian cancer risk who had risk-reducing oophorectomy compared with first-degree relatives who were at similar risk and did not have surgery.229 Eight ovarian cancer cases occurred in 346 relatives without surgery (2.3%) versus two cases of carcinomatosis in 44 women with surgery (4.5%). Also, 14 cases of breast cancer occurred in relatives without surgery (4.0%) versus three cases in women with surgery (6.8%). Mean followup time was not reported for this study, but person-years ranged from 460 to 1,665. This study met criteria for poor-quality and was limited by a lack of information about groups at baseline, methods for ascertaining exposures and outcomes, followup, and attrition.229

One new study of risk-reducing salpingo-oophorectomy292 and two new studies of oophorectomy185,296 in high-risk women and women who were mutation carriers met inclusion criteria (Table 19, Appendix C12). Two studies185,292 met criteria for fair-quality and one was descriptive.296 The fair-quality studies were limited by a lack of information about groups at baseline, attrition, and followup.185,292

In a prospective cohort study evaluating the outcomes of women who were BRCA mutation carriers at 22 North American and European centers, salpingo-oophorectomy was significantly associated with reduced incidence of ovarian or primary peritoneal cancer (1.3% vs. 5.8%; HR, 0.28 [95% CI, 0.12 to 0.69]).292 In addition, salpingo-oophorectomy was associated with reduced breast cancer incidence (11.6% vs. 21.6%; HR, 0.54 [95% CI, 0.37 to 0.79]) and all-cause mortality (1.8% vs. 5.9%; HR, 0.45 [95% CI, 0.21 to 0.95]). Reductions in breast cancer–specific (0.5% vs. 2.3%; HR, 0.27 [95% CI, 0.05 to 1.33]) and ovarian cancer–specific mortality (0.7% vs. 2.5%; HR, 0.39 [95% CI, 0.12 to 1.29]) were not statistically significant.

In a prospective cohort study of women from families with known BRCA1 mutation carriers, oophorectomy was associated with reduced breast cancer incidence (18% vs. 42%; HR, 0.38 [95% CI, 0.15 to 0.97]).185 Risk reduction was most pronounced in women who had the procedure at a younger age.

A retrospective study compared observed versus expected breast cancer incidence rates in women who underwent oophorectomy.296 In this study, oophorectomy was associated with reduced risks that were more pronounced in women who were younger than age 50 years and premenopausal at time of surgery (O/E = 1/3.9; RR, 0.26 [95% CI, 0.001 to 0.99]) compared with older postmenopausal women (O/E = 3/5.4; RR, 0.56 [95% CI, 0.11 to 1.33]).

## Key Question 5 What Are the Potential Adverse Effects of Interventions to Reduce Risk for BRCA-Related Cancer?

### Summary

For breast cancer screening, the adverse effects of intensive screening were described in three studies of physical harms and two studies of anxiety. Results indicated that false-positive rates, unnecessary imaging, and unneeded surgeries were higher in women undergoing intensive screening using MRI versus mammography. Most women experienced no anxiety after breast cancer screening with MRI, mammography, or clinical breast examination. Two studies described harms of ovarian cancer screening; one reported an unneeded diagnostic surgery rate of 55 percent in women who were mutation carriers screened with TVUS and serum CA-125 testing.

There are no trials of risk-reducing medications specifically in women who are BRCA mutation carriers. A systematic review and meta-analysis of four tamoxifen and two raloxifene placebo-controlled RCTs and one head-to-head trial provided adverse event outcomes for women who had various levels of risk. Trials were limited by heterogeneity and data on long-term effects were incomplete. Tamoxifen and raloxifene increased thromboembolic events compared with placebo (4 to 7/1,000 women over 5 years) and tamoxifen had a greater effect than raloxifene (4/1,000 women over 5 years). Tamoxifen increased endometrial cancer compared with placebo (4/1,000 women over 5 years) and raloxifene (5/1,000 women over 5 years), and increased cataracts compared with raloxifene (15/1,000 women over 5 years). Both caused undesirable side effects in some women, such as vasomotor symptoms.

Case-series and before-after studies described surgical complications, physical effects, and distress measures related to risk-reducing surgery. Studies lacked important outcomes, enrolled small numbers of participants, and had no comparison groups. Some women experienced physical complications of surgery, had postsurgical symptoms, or changes in body image, while some women had improved anxiety.

### Evidence

#### Intensive Screening

Breast Cancer. The previous review identified no studies with information about the harms of intensive screening for breast cancer. The updated review includes three studies, in four publications, reporting false-positive or false-negative results, unneeded procedures, or recall rates (Table 20, Appendix C13),274,276,277,297 and two studies about discomfort, pain, or anxiety (Table 21, Appendix C14).275,298

Table 20 Harms of Intensive Screening for Breast Cancer Using Mammography vs. MRI in High-Risk Women

Author, year | N (BRCA1/2) # of cancer cases | Age at entry, y | Screening interval Followup, y | False-positive rate | False-negative, n | Recall rates | Unneeded^*^ additional exams or imaging Unneeded^*^ biopsy
Kriege et al, 2004^277^ Kriege et al, 2006^297^ Dutch MRISC study | 1909 (14/4) 39 BRCA1 45 BRCA2 | Mean, 40 | Annual, same-day Mean, 2.7 | n=39 cancers First imaging round (prior mammography): 5.5% vs. 14%; p<0.001 Subsequent imaging rounds: 4.6% vs. 8.2%; p<0.001 | n=39 cancers First imaging round (prior mammography): 12 vs. 1 Subsequent imaging rounds: 12 vs. 4 | NR | n=45 cancers Exams^†^: 207 vs. 420 Biopsy: 28% (7/25^‡^) vs. 43% (24/56^‡^)
Leach et al, 2005^274^ MARIBS study | 649 (13/6) 33 | Median, 40 | Annual, same-day Variable followup, ≥2 scans | NR | NR | 279 recalls overall 3.9% vs. 11% per woman-year Combined tests: 13% per woman-year 245/279 recalls for benign findings 8.5 recalls per cancer detected | All study arms^§^ Ultrasound: 38% (93/245) Core biopsy: 13% (32/245) FNA: 19% (47/245) Surgery: 3% (7/245) 0.21 benign biopsies per cancer detected
Le-Petross et al, 2011^276^ | 73 (51/49) 13 | Median, 44 | Biannual, alternating mammography with MRI Median, 2 | 15% (11/73) vs. 11% (8/73) | NR | NR | Imaging: 73% (8/11) vs. 50% (4/8) Biopsy: 27% (3/11) vs. 25% (2/8) Imaging plus biopsy: 0% vs. 25% (2/8)

* Women who were diagnosed as cancer free.

† Additional investigation included ultrasound ± fine needle biopsy or repeat mammography or repeat MRI.

‡ Women with BIRADS ≥3 on mammography or MRI.

§ Results not reported by imaging arm.

Abbreviations: BIRADS = Breast Imaging Reporting and Data System; FNA = fine needle aspiration; MARIBS = Magnetic Resonance Imaging Breast Screening; MRI = magnetic resonance imaging; MRISC = Magnetic Resonance Imaging Screening Study; NA = not applicable; NR = not reported.

Table 21 Distress Due to Intensive Screening for Breast Cancer in Women Who Are Mutation Carriers

Author, year, quality rating | N, study design | Mutation status | Comparison | Measures of distress | Anxiety | Depression | Sexual activity | Body image | General QOL
Rijnsburger et al, 2004^275^ Fair | 288; prospective cohort and pre-post | 35 BRCA1/2 mutation positive | A. CBE (n=287); B. CBE + mammography (n=134); C. CBE + MRI (n=109) | SF-36, EQ-5D, VAS, SCL-90 | 0 | NR | NR | NR | 0
Spiegel et al, 2011^298^ NA | 55; pre-post | BRCA1: 30/55 (54.5%) BRCA2: 25/55 (45.5%) | A. Recall examinations (n=18); B. No recall examinations (n=37) | HADS, WIS | X increase A vs. B^*^ | 0 | NR | NR | 0

X = statistically significant difference; 0 = studied but not significant.

* At 4 to 6 weeks after screening only, returned to baseline levels by 6 months.

Abbreviations: CBE = clinical breast examination; EQ-5D = EuroQoL-5 Dimensions; HADS = Hospital Anxiety and Depression Scale; MRI = magnetic resonance imaging; NA = not applicable; NR = not reported; QOL = quality of life; SCL-90 = Symptom Checklist-90; SF-36 = Short-Form 36-Item Health Survey; VAS = Visual Analogue Scale; WIS = Breast Cancer Worry Interference Scale.

In studies of false-positive or false-negative results, unneeded procedures, or recall rates, women with increased familial risk of breast cancer were recruited from the Netherlands, the United Kingdom, and the United States. Two studies used prospective designs,274,277,297 and one retrospectively analyzed data from a completed prospective study.276 Sample sizes ranged from 73 to 1,909, and 18 to 100 percent of participants were BRCA mutation carriers. Mean/median age at entry was 40 to 44 years, and mean/median followup was approximately 2 years or at least two annual scans by the time of analysis.277,297

Two studies reported false-positive rates of mammography compared with MRI.276,297 The Dutch MRISC reported results by screening round, and defined the false-positive rate as the number of positive test results in women who did not have cancer. The false-negative rate was defined as the number of negative test results in women who had cancer. This study reported significantly higher false-positive rates for MRI compared with mammography in the first and subsequent imaging rounds (first round with prior mammography, 14% vs. 5.5%; subsequent rounds, 8.2% vs. 4.6%; p<0.001 for both rounds).297 False-negative results for MRI were lower than for mammography, although numbers were small.

In a study of six monthly breast cancer screenings using MRI alternating with mammography, a result was considered a false-positive if initial findings on screening appeared suspicious, but followup clinical examination, imaging, or biopsy resulted in a final benign assessment. This study reported similar false-positive results for both modalities (MRI, 11%; mammography, 15%), and did not report false-negative findings.276

Two studies reported the number of unneeded additional imaging procedures or biopsies.276,277 These procedures were considered unneeded because final results were benign and women may never have undergone the procedures if the original screening test had not been performed. The Dutch MRISC determined the need for additional procedures using the Breast Imaging Reporting and Data System (BI-RADS) score from the screening examination. Women with BI-RADS scores of 3 (probably benign) or 0 (need additional imaging evaluation) underwent further evaluations using ultrasound with or without fine-needle aspiration or repeat mammography or MRI. Women with BI-RADS scores of 4 (suspicious abnormality) or 5 (highly suggestive of malignancy) underwent biopsy. Results indicated that 43 percent of women with unneeded biopsies had preceding screening MRI and 28 percent had mammography.277

A study that retrospectively analyzed data from a prospectively followed cohort of women who were BRCA mutation carriers or their first-degree relatives found that alternating MRI with mammography screening every 6 months yielded a greater proportion of unneeded imaging procedures (targeted ultrasound) in women screened with mammography (8/11) than with MRI (4/8).276 However, rates of unneeded biopsies were similar (3/11 for mammography and 2/8 for MRI).

Recall rates for annual MRI were higher than for annual mammography in a descriptive study conducted in the United Kingdom that included women who were mutation carriers (MRI, 11% per woman-year; mammography, 3.9% per woman-year; combined, 13% per woman-year).274 In this study, 245 of 279 recalls were for benign findings, amounting to 8.5 recalls per cancer detected.

A fair-quality prospective cohort study of women with a mean age of 40.9 years compared discomfort, pain, and anxiety of women undergoing intensive screening with annual mammography, MRI, and biannual clinical breast examinations with women only receiving biannual clinical breast examinations.275 These outcomes did not differ between groups, as measured by the Medical Outcomes Study 36-Item Short Form (Table 21, Appendix C14).275 Most women experienced no anxiety after each type of screening intervention (72% after mammography, 63% after MRI, 78% after clinical breast examination).

In a before-after study of MRI plus mammography, ultrasound, and clinical breast examination, women who were recalled reported higher anxiety scores compared with women who were not recalled at 4 to 6 weeks after screening (8.8 vs. 5.9, respectively; p=0.03).298 These represent midrange scores, as measured by the HADS. Between-group differences were not significant by 6 months (7.1 vs. 5.9, respectively).

Ovarian Cancer. Two studies met inclusion criteria, one from the previous review279 and one from updated searches.281 A prospective descriptive study included in the previous review estimated false-positive results for TVUS when used for screening for ovarian cancer in 1,601 self-referred asymptomatic women with at least one relative who was diagnosed with ovarian cancer.279 Forty-three percent of women were screened with only one ultrasound. In this study, 3.8 percent (61/1,601) of screened women had suspicious findings on TVUS and were referred to surgery. Cancer was detected in six of 61 referred cases, yielding a false-positive rate of 3.4 percent (95% CI, 2.6 to 4.5). Addition of color flow imaging to ultrasound reduced the number of false-positive cases from 55 to six.

The updated review identified a descriptive study conducted in the Netherlands that reported the number of unneeded diagnostic surgeries associated with ovarian cancer screening using annual serum CA-125 measurements and annual TVUS in 459 women who were BRCA mutation carriers281 (Appendix C13). Abnormalities were detected in 9 percent (40/459) of women with complete data, which included 3 percent (38/1,116) of screening visits, as well as visits for symptomatic complaints. Of 26 diagnostic procedures, cancer was not detected in 67 percent (4/6) following abnormal CA-125 measurement compared with 100 percent (9/9) following abnormal TVUS findings. Combined modalities resulted in an unneeded diagnostic surgery rate of 55 percent (6/11).

#### Risk-Reducing Medications

No studies evaluated the adverse effects of risk-reducing medications specifically in women who are BRCA mutation carriers, although adverse effects were reported in several RCTs of women who had various levels of risk and have been summarized in meta-analyses.116,283 Studies include four placebo-controlled trials of tamoxifen,284-287 two placebo-controlled trials of raloxifene,73,288 and a head-to-head RCT of tamoxifen versus raloxifene.289 No adverse effect outcomes were provided specifically by mutation status or family history risk in these trials. Details of the trials are provided in Appendix C11. Fair-quality trials were limited by incomplete reporting of followup,284,285,287 inadequate maintenance of comparable groups,284,285,287 high (>30%) crossover between groups,284 and low (<65%) numbers of participants completing all treatment years.285,286

In these trials, thromboembolic events were increased for tamoxifen (RR, 1.93 [95% CI, 1.41 to 2.64]; 4 trials; 4 cases/1,000 women over 5 years) and raloxifene (RR, 1.60 [95% CI, 1.15 to 2.23]; 2 trials; 7/1,000 women over 5 years) compared with placebo (Table 22).116,283 Raloxifene caused fewer events than tamoxifen in STAR (RR, 0.77 [95% CI, 0.60 to 0.93]; 4/1,000 women over 5 years).289 Coronary heart disease events or stroke were not increased in placebo-controlled trials, and did not differ in STAR, although women randomized to raloxifene had higher stroke mortality than placebo in RUTH (RR, 1.49 [95% CI, 1.00 to 2.24]).299

Table 22 Results of Trials of Risk-Reducing Medications: Adverse Effects115,116

Outcome | Raloxifene vs. tamoxifen | | Tamoxifen vs. placebo | | | Raloxifene vs. placebo
Outcome | Risk ratio (95% CI) | Events reduced/increased, n (95% CI)^*^ | Risk ratio (95% CI) (Trials, n)^†^ | Placebo rate (SE)^‡^ | Events reduced/increased, n (95% CI)^*^ | Risk ratio (95% CI) (Trials, n)^†^ | Placebo rate (SE)^‡^ | Events reduced/increased, n (95% CI)^*^
Thromboembolic events^§^ | 0.75 (0.60 to 0.93)║ | 4 (1 to 7) more tamoxifen | 1.93 (1.41 to 2.64) (4) | 0.91 (0.19) | 4 (2 to 9) more tamoxifen | 1.60 (1.15 to 2.23) (2) | 2.34 (0.25) | 7 (2 to 15) more raloxifene
Deep vein thrombosis | 0.72 (0.54 to 0.95)║ | 3 (1 to 5) more tamoxifen | 1.45 (0.89 to 2.37) (2) | | | 1.91 (0.87 to 4.23) (2)
Pulmonary embolus | 0.80 (0.57 to 1.11)║ | | 2.69 (1.12 to 6.47) (2) | 0.19 (0.07) | 2 (0.1 to 6) more tamoxifen | 2.19 (0.97 to 4.97) (2)
Coronary heart disease events | 1.10 (0.85 to 1.43)^¶^ | | 1.00 (0.79 to 1.27) (4) | | | 0.95 (0.84 to 1.06) (2)
Stroke | 0.96 (0.64 to1.43)^¶^ | | 1.36 (0.89 to 2.08) (4) | | | 0.96 (0.67 to 1.38) (2)
Endometrial cancer | 0.55 (0.36 to 0.83)║ | 5 (2 to 9) more tamoxifen | 2.13 (1.36 to 3.32) (3) | 0.75 (0.15) | 4 (1 to 10) more tamoxifen | 1.11 (0.65 to 1.89)^**^ (3)
Cataracts | 0.80 (0.72 to 0.95)║ | 15 (8 to 22) more tamoxifen | 1.25 (0.93 to 1.67)^††^ (3) | | | 0.93 (0.84 to 1.04) (2)

* Numbers of events increased for harms compared with placebo or other comparator per 1000 women, assuming 5 years of use.

† If meta-analysis.

‡ Per 1000 women. Estimated from a meta-analysis of rates from the placebo groups from the same trials included in the risk ratios.

§ Includes deep vein thrombosis and pulmonary embolus.

║ Updated results from the Study of Tamoxifen and Raloxifene (STAR), 2010.

¶ Initial results from STAR, 2006.

** Updated meta-analysis.

†† The risk ratio for cataracts was significantly increased in the NSABP P-1, 1998 (574 vs. 507 events; RR, 1.14 [95% CI, 1.01 to 1.29]).

Abbreviations: CI = confidence interval; NR = not reported; SE = standard error.

Tamoxifen caused more cases of endometrial cancer (RR, 2.13 [95% CI, 1.36 to 3.32]; 3 trials; 4/1,000 women over 5 years), and was related to more benign gynecologic conditions, surgical procedures (including hysterectomy), and uterine bleeding than placebo.116,283 Raloxifene did not increase risk for endometrial cancer or uterine bleeding.116,283 In the STAR trial, raloxifene caused fewer cases of endometrial cancer (RR, 0.55 [95% CI, 0.36 to 0.83]; 5/1,000 women over 5 years), hyperplasia, and procedures than tamoxifen.289 Women using tamoxifen had more cataract surgeries than placebo in the NSABP P-1 trial.284 Raloxifene did not increase risk for cataracts or cataract surgery compared with placebo, and caused fewer cataracts than tamoxifen in STAR (RR, 0.80 [95% CI, 0.72 to 0.95]; 15/1,000 women).289

Most common side effects were vasomotor symptoms and vaginal discharge, itching, or dryness for tamoxifen and vasomotor symptoms and leg cramps for raloxifene. In STAR, raloxifene users reported more musculoskeletal problems, dyspareunia, and weight gain, while tamoxifen users had more gynecological problems, vasomotor symptoms, leg cramps, and bladder control symptoms.289

#### Risk-Reducing Surgery

Mastectomy. The prior review found no studies that met inclusion criteria for the physical harms of mastectomy, though it described a series of 112 high-risk women, including 79 who were mutation carriers, undergoing risk-reducing mastectomy with immediate reconstruction. Twenty-one percent had physical complications, including hematomas, contracture, or implant rupture.300

Four descriptive studies about surgical complications, physical effects, or distress related to risk-reducing surgery met inclusion criteria for the updated review.301-305 Three studies reported information on physical harms of risk-reducing mastectomy.

In a case-series of 122 women who had undergone mastectomy, 64.4 percent reported postsurgical symptoms of numbness, pain, tingling, infection, swelling, breast hardness, bleeding, organizing hematoma, failed reconstruction, breathing problems, thrombosis, and pulmonary embolism.301 In a study of pain after surgery using the Health-Related Quality of Life tool, there were no significant differences between women's scores obtained before mastectomy and either 6 months or 1 year postmastectomy.302

A case-series from the Karolinska University evaluated the physical effects of risk-reducing mastectomy and immediate breast reconstruction in 59 high-risk women.303 Questionnaires were sent to study subjects at least 2 years after the mastectomy and at least 1 year after any corrective procedures. Eleven patients had postoperative infections and three of them needed implant extraction, four reported hematomas, two needed revisions of flap necrosis, and 35 required corrective procedures. Of the 55 patients who completed the questionnaires, 48 reported postmastectomy pain and discomfort. Of these, five required occasional pain medication and 12 reported that pain affected their daily lives.

Four descriptive studies, in five publications, provided data about distress due to mastectomy to reduce risk for BRCA-related cancer in women who were at increased risk because of family history or BRCA mutation (Table 23, Appendix C14).301-305

Table 23 Distress Due to Risk-Reducing Surgery

Author, year | N, study design | Mutation status | Comparison | Measures of distress | Anxiety | Depression | Sexual activity | Body image | General QOL
Mastectomy
Brandberg et al, 2008^302^ Brandberg et al, 2012^304^ | 90; pre-post | 37/90 (41.1%) BRCA1 13/90 (14.4%) BRCA2 2/90 (2.2%) unknown mutation | A. Before surgery (n=81); B. 6 months after (n=71); C. 1 year after (n=65) | NSI, SAQ, BIS, HADS, SF-36 | X decrease B & C vs. A | 0 | X^*^ decrease C vs. A & B | 0 | NR
Gahm et al, 2010^303^ | 1784; case-series | NR | A. Surgery (n=59); B. Control (n=1725) | NSI, SF-36, DRS | NR | NR | NR | NR | 0
Metcalfe et al, 2004^301^ | 60; case-series | 21.7% BRCA1/2 | A. Age <50 years (n=46); B. Age ≥50 years (n=14) | BSI, BIBC, IES, SAQ | 0 | NR | 0 | NR | NR
Salpingo-oophorectomy
Finch et al, 2011^306^ | 67; pre-post | BRCA1 or BRCA2 | A. Before surgery; B. After surgery | MENQOL, SAQ | NR | NR | X decrease B vs. A | NR | NR

X = statistically significant difference; 0 = studied but not significant.

* For pleasure subscale of SAQ only.

Abbreviations: BIBC=Body Image after Breast Cancer; BIS = Body Image Scale; BSI=Brief Symptom Inventory; DRS=Decision Regret Scale; HADS=Hospital Anxiety and Depression Scale; IES=Impact of Events Scale; MENQOL=Menopause-Specific Quality of Life-Intervention; NSI=not standard instrument; NR = not reported; QOL=quality of life; SAQ=Sexual Activity Questionnaire; SF-36 = Short-Form 36-Item Health Survey.

A before-after study enrolled 90 high-risk women who had risk-reducing bilateral mastectomies, including 41 percent (37/90) BRCA1 mutation carriers, 14 percent (13/90) BRCA2 mutation carriers, 29 percent (26/30) with 50 percent lifetime risk, and 9 percent (98/90) with 25 percent lifetime risk. Results indicated significant decreases in anxiety scores, as measured by the HADS, 6 months and 1 year after surgery compared with before surgery (mean, 3.80 vs. 3.83 vs. 5.59, respectively; p=0.0004).302,304 The study also reported decreased pleasure in sexual activity, as measured by the pleasure subscale of the Sexual Activity Questionnaire (SAQ), 1 year after surgery compared with 6 months after surgery and before surgery (mean, 11.18 vs. 12.21 vs. 12.28, respectively; p=0.005). Depression scores, body image concerns, or any other portion of the SAQ were not significantly different.

A case-series study of 59 women undergoing risk-reducing mastectomy compared with a reference sample of 1,725 women from a previous study of women considering risk-reducing mastectomy reported no significant differences on any psychological or sexual activity measures.303 These measures also did not differ in a separate case-series of women undergoing risk-reducing mastectomy that compared women younger versus older than age 50 years.301

A descriptive case-series study, utilizing semistructured interviews, described physical and psychological effects in 13 women 10 years after risk-reducing mastectomy. Most women reported that their family lives were unchanged (8/13 [62%]), although 39 percent (5/13) reported a negative effect on their relationship with their spouse, due to decreased sensation and changed body appearance.305 Most women considered the cosmetic results positive (10/13 [77%]) and most had discussed breast cancer risk with their daughters (10/11 [91%]).

Salpingo-Oophorectomy. The prior review found no studies that met inclusion criteria, though it included a descriptive study of risk-reducing salpingo-oophorectomy in women who were mutation carriers that included 70 percent of participants with personal histories of breast cancer. Four out of 80 women who underwent salpingo-oophorectomy without hysterectomy experienced complications of wound infection, bladder perforation, small bowel obstruction, and uterine perforation.79

Only one new study was identified for the updated review. A before-after study of women who were mutation carriers with a mean age of 47.5 years included 47 women with personal histories of breast cancer and 67 women without. Most women reported significant worsening of vasomotor symptoms (p<0.01), as measured by the Menopause-Specific Quality of Life-Intervention scale, and decreased sexual functioning (p<0.05), as measured by the SAQ, after risk-reducing salpingo-oophorectomy.306