# METHODS

## Analytic Framework and Key Questions

Based on evidence gaps identified from the previous review,1,2 the USPSTF and Agency for Healthcare Research and Quality (AHRQ) determined the key questions for this update using the methods of the USPSTF.100 Investigators created an analytic framework incorporating the key questions and outlining the patient populations, interventions, outcomes, and potential adverse effects (Figure 1). Definitions are described in Appendix A2 and key questions are outlined in Figure 1. A draft research plan describing the analytic framework, key questions, scope, and systematic review approach was posted on the USPSTF Web site for public comment for 30 days in March and April 2012. A total of 213 comments from 54 respondents were received and reviewed, and the research plan was modified after discussion with investigators, the AHRQ Medical Officer, and USPSTF members. In addition, the USPSTF requested information about the impact of genetic testing on family members and the effects of direct-to-consumer marketing of BRCA genetic tests. These are described in supplementary sections of the review.

Figure 1 Analytic Framework and Key Questions

Key Questions
1 Does risk assessment, genetic counseling, and genetic testing lead to reduced incidence of BRCA-related cancer and reduced cause-specific and all-cause mortality?
2a What is the accuracy of methods to assess familial cancer risk for BRCA-related cancer when performed by a nongenetics specialist in a clinical setting?
2b What are the benefits of genetic counseling in determining eligibility for genetic testing for BRCA-related cancer?
2c What is the clinical validity of genetic testing for deleterious mutations in women with increased risk for BRCA-related cancer?
3 What are the potential adverse effects of a) risk assessment, b) genetic counseling, and c) genetic testing?
4 Do interventions reduce the incidence of BRCA-related cancer and mortality in women with increased risk?
5 What are the potential adverse effects of interventions to reduce risk for BRCA-related cancer?

* Clinically significant mutations of BRCA1, BRCA2, or related syndromes.

† Testing may be done on the unaffected woman, her relative with cancer, or relative with highest risk, as appropriate.

‡ Interventions include increased early detection through intensive screening (earlier and more frequent mammography, breast magnetic resonance imaging), risk-reducing medications (tamoxifen, raloxifene), and risk-reducing surgery (mastectomy, salpingo-oophorectomy).

Uninformative negative test = no known mutation in relatives, none detected in patient; True negative test = known mutation in relatives but none detected in patient.

Figure 1 is a flow diagram of risk assessment, genetic counseling, and genetic testing. Women without cancer or known deleterious BRCA mutations, which are clinically significant mutations of BRCA1, BRCA2, or related syndromes, are assessed for their familial cancer risk. These women may experience adverse effects as they are determined to have either no increased risk or increased risk for BRCA mutations. Women with an increased risk for BRCA mutations are referred for genetic counseling, during which they may experience adverse effects. Following genetic counseling, women with an increased risk for BRCA mutations are referred for genetic testing, during which they may experience adverse effects. Testing may be done on the unaffected woman or her relative with cancer as appropriate. Women who undergo genetic counseling may be found to be true negative, which means there is a known mutation in their relatives but none detected in the patient, or they may have an uninformative negative status, meaning there is no known mutation in their relatives and none detected in the patient. They may also have a variant of uncertain significance or a BRCA mutation may be detected. For women with status that is not a true negative, they may be referred for interventions, including increased early detection through intensive screening (earlier and more frequent mammography, breast MRI), medications (such as tamoxifen or raloxifene), and risk-reducing surgery (such as mastectomy or oophorectomy). Women who undergo interventions may experience adverse effects. Women who undergo interventions may also have reduced incidence of BRCA-related cancer and reduced cause-specific and all-cause mortality.

The target population included women without cancer or known deleterious BRCA mutations who are seen in clinical settings applicable to U.S. primary care practice, although the ideal candidate for mutation testing could be a male or female relative with cancer. The conditions of interest were BRCA mutation carrier status and BRCA-related cancer (predominantly breast, ovarian, fallopian tube, and peritoneal).

## Search Strategies

In conjunction with a research librarian, investigators used the National Library of Medicine's Medical Subject Headings keyword nomenclature to search the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (2005 through the 4th Quarter 2012), Health Technology Assessment, National Health Sciences Economic Evaluation Database, Database of Abstracts of Reviews of Effects (4th Quarter 2012), and MEDLINE and PsycINFO (2004 to December 31, 2012) for relevant English-language studies, systematic reviews, and meta-analyses. Search strategies are listed in Appendix B1. Secondary referencing involved manually reviewing reference lists of papers and reviewing citations of key studies using Scopus.

## Study Selection

Investigators developed inclusion and exclusion criteria for abstracts and articles based on the target population, key questions, and outcome measures (Appendix B2). New research conducted in the United States or in similar populations that receive services and interventions applicable to U.S. medical practice published in 2003 or later was considered. After an initial review of abstracts, full-text articles were reviewed using additional inclusion criteria. In addition, studies from the previous review that met inclusion criteria for this update were included in summary tables and meta-analysis in order to build on prior relevant research.

RCTs, systematic reviews, prospective and retrospective cohort studies, case-control studies, and diagnostic accuracy evaluations that addressed key questions 1, 2, and 4 were included. These include studies of the accuracy of risk assessment methods, outcomes of genetic counseling and testing, and effectiveness studies of interventions to reduce risk of BRCA-related cancer in women who are mutation carriers. Risk assessment methods were included only if they were designed for use by nongenetics specialists to guide referrals and were feasible for clinical settings (i.e., brief, nontechnical, did not require special training to administer or interpret). Evaluation of complex models used in genetic counseling was outside the scope of this review. Interventions include intensive screening (e.g., earlier and more frequent mammography, breast MRI), risk-reducing medications (e.g., tamoxifen, raloxifene), and risk-reducing surgery (e.g., mastectomy, salpingo-oophorectomy). For intensive screening interventions, when effectiveness studies were not available, studies that reported test characteristics of screening modalities, such as sensitivity and specificity, were included. Only medications approved by the U.S. Food and Drug Administration for cancer risk reduction were considered, consistent with the scope of the USPSTF.

Studies of any design were included to describe potential adverse effects of risk assessment, genetic counseling, mutation testing, and risk-reducing interventions (key questions 3 and 5). Potential adverse effects include inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; false reassurance; incomplete testing; misinterpretation of the test result; anxiety; cancer worry; immediate and long-term harms associated with breast imaging, risk-reducing medications, and risk-reducing surgery; and ethical, legal, and social implications.

## Data Abstraction and Quality Rating

An investigator abstracted data about the study design and setting; participant characteristics; data collection procedures; numbers enrolled and lost to followup; methods of exposure and outcome ascertainment; analytic methods, including adjustment for confounders; and outcomes. A second investigator confirmed the accuracy of key data. By using predefined criteria for RCTs, systematic reviews, cohort, case-control, and diagnostic accuracy studies developed by the USPSTF,100,101 two investigators rated the quality of studies (good, fair, poor) and resolved discrepancies by consensus (Appendix B3).

Quality could not be assessed for many studies with designs that did not have predefined quality criteria, such as descriptive, cross-sectional, before-after, and case-series. For studies of penetrance (i.e., the probability of developing breast or ovarian cancer in women who have known BRCA1 or BRCA2 mutations) that computed a standardized incidence ratio (SIR) as the summary measure, we considered several factors to determine study quality in the absence of predefined criteria. Studies were considered high-quality if: 1) genotypes were known by direct measurement or inference from genotypes of relatives rather than probabilistically assigned; 2) breast and ovarian cancer outcomes were determined prospectively after ascertainment of the family genetic profile; 3) important covariates were measured for all individuals and accounted for in the analysis, including use of risk-reducing surgery and medications, age, Ashkenazi Jewish ancestry, race or ethnicity, and vital status; and 4) reported family history was validated by review of medical records of family members.

The applicability of studies was determined using the population, intervention, comparator, outcomes, timing of outcomes measurement, and setting format adapted to this topic.102

## Data Synthesis

We assessed the aggregate quality of the body of evidence for each key question (good, fair, poor) by using methods developed by the USPSTF based on the number, quality, and size of studies and consistency of results between studies.100 Studies were considered consistent if outcomes were generally in the same direction of effect and ranges of effect sizes were narrow.

### Statistical Meta-Analysis

To determine clinical outcomes related to various mutation testing results, we combined data in several meta-analyses to obtain estimates of mutation prevalence, penetrance, and relative risk for developing breast or ovarian cancer. These include estimates for women from unselected populations, high-risk cohorts, and Ashkenazi Jewish populations with tests indicating BRCA-positive (i.e., detected BRCA1 or BRCA2 mutations), variant of uncertain significance, uninformative negative, and true negative results using data from studies meeting inclusion criteria. Relevant studies from the previous review as well as those identified for this update were included in the meta-analyses.

To determine the appropriateness of meta-analysis, we considered clinical and methodological diversity and assessed statistical heterogeneity. We abstracted or calculated estimates of prevalence, penetrance, and relative risk (risk ratio [RR] or SIR) and their standard errors (SEs) from each study and used them in the meta-analysis. When the SIR was not reported, but the studies reported data for observed and expected numbers of cancer cases, or the study only reported the observed number of cancer cases and we could calculate the expected number of cancer cases from Surveillance Epidemiology and End Results data,39 we calculated the SIR and its CI based on observed and expected numbers of cancer cases using the relationship between the Poisson distribution and the chi-square distribution.103

We assessed the presence of statistical heterogeneity among the studies by using standard chi-square tests, and the magnitude of heterogeneity by using the I^2^ statistic.104 We used a random-effects model to combine data for prevalence, penetrance, and relative risk while accounting for variation among studies. In general, when there is no variation among studies, the random-effects model yields the same results as a fixed-effects model without a study effect.105 To account for clinical heterogeneity, we stratified analyses by clinical characteristics (e.g., breast vs. ovarian cancer, levels of risk, or methods used to select probands for BRCA-positive women) when necessary. We conducted sensitivity analyses to assess the robustness of results that considered variation from outlying studies. The results of the sensitivity analyses indicated no major differences from the main analysis. All analyses were performed using Stata/IC 12.1 (StataCorp, College Station, TX) and SAS 9.3 (SAS Institute, Cary, NC).

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners and revised prior to finalization (Appendix B4).

## Response to Comments Received During the Public Comment Period

A draft version of this evidence report was posted for public comment on the USPSTF Web site from April 2 to April 29, 2013. Comments were contributed by seven individuals and primarily concerned the scope of the review (i.e., include women with existing cancer, men, other types of mutations); issues that were already addressed by the systematic review, but were missed by the respondent (e.g., effect of risk-reducing salpingo-oophorectomy before and after menopause); studies or topics of interest that had no publications meeting inclusion criteria (e.g., testosterone supplements to reduce breast cancer risk); and comments about the recommendation statement. These comments did not lead to important changes in the systematic review.