# INTRODUCTION

## Purpose of Review and Prior USPSTF Recommendation

This systematic review is an update of the evidence for the U.S. Preventive Services Task Force (USPSTF) on the effectiveness and adverse effects of risk assessment, genetic counseling, and genetic testing for breast cancer susceptibility gene (BRCA)–related cancer in women who do not have cancer but are potentially at increased risk. Its purpose is to evaluate and summarize evidence addressing specific key questions important to the USPSTF as it considers new recommendations for primary care practice.

In 2005, based on results of a previous review,1,2 the USPSTF recommended against routine referral for genetic counseling or routine BRCA testing for women whose family histories are not associated with increased risks for deleterious mutations in breast cancer susceptibility gene 1 (BRCA1) or breast cancer susceptibility gene 2 (BRCA2) (D recommendation).3 The USPSTF also recommended that women whose family histories are associated with increased risks for mutations in the BRCA1 or BRCA2 genes be referred for genetic counseling and evaluation for BRCA testing (B recommendation).

The USPSTF concluded that the potential harms of routine referral for genetic counseling or BRCA mutation testing in women without family history risk outweigh the benefits, and that the benefits of referring women with family history risk to suitably trained health care providers outweigh the harms. Benefits included improved accuracy of risk assessment and pretest probability for testing and improved patient knowledge, risk perception, and psychological and health outcomes. Potential harms included inaccurate risk assessment; inappropriate testing; misinterpretation of test results; and ethical, legal, and social implications; among others.

The 2005 USPSTF recommendation was intended for the primary prevention of cancer and applied to women without previous diagnoses of breast or ovarian cancer, consistent with the USPSTF scope of preventive care for the general population. Recommendations for men and women with cancer were not included. The 2005 USPSTF recommendation is included in the Affordable Care Act for covered preventive services,4 and provided the basis for a Healthy People 2020 objective to increase the proportion of women with family histories of breast or ovarian cancer who receive genetic counseling.5

The previous systematic review1,2 identified several research limitations and evidence gaps. The review concluded that a primary care approach to genetic risk assessment and BRCA mutation testing had not been evaluated, and evidence was lacking to determine the benefits and harms of this approach for women without cancer. Risk assessment, genetic counseling, and mutation testing did not cause adverse psychological outcomes, and counseling improved distress and risk perception in the highly-selected populations studied. Studies of intensive cancer screening approaches, such as earlier and more frequent mammography, were inconclusive. Trials of risk-reducing medications, such as tamoxifen and raloxifene, reported reduced breast cancer incidence in women with varying baseline levels of risk compared with placebo, but also increased adverse effects. Observational studies of risk-reducing mastectomy and salpingo-oophorectomy reported reduced breast and ovarian cancer outcomes in women who were mutation carriers.

Limitations identified by the previous review included:

- The quality and generalizability of studies varied.
- Although several risk assessment tools were available, most were designed for use by genetics specialists rather than primary care providers.
- Methods of risk stratification were subject to misclassification, and data to guide clinicians in the best approach were lacking.
- Studies of the effectiveness of genetic counseling on patient decisions and outcomes were lacking.
- Most studies of BRCA mutation testing were conducted in highly-selected samples of women, many with preexisting breast or ovarian cancer or from previously identified kindreds.
- Family history risk was often based on self-reported information; thus, the accuracy of risk stratification was limited by the accuracy of reported family history.
- In some cases, data to determine penetrance came exclusively from one study, and when multiple studies were available, they were heterogeneous and likely unreliable. (Penetrance is the probability of developing breast or ovarian cancer in women who have a known BRCA1 or BRCA2 mutation.)
- Most studies used research laboratory techniques to detect clinically significant mutations that differed from the DNA sequencing available clinically.
- The clinical significance of mutations was determined by each study.
- The applicability of studies based on highly-selected women in research settings to the general screening population was questionable.
- Data were not available to determine the optimal age at which to test and how age at testing influenced estimates of benefits and adverse effects.
- The long-term impact of testing was unknown, and most studies followed patients for less than 1 year.
- Studies did not evaluate psychological aspects of medical outcomes.
- Few data were available about the impact of testing on family members.
- Treatment effects were influenced by several variables that were not available and not easily factored into estimates of clinical outcomes.

Evidence gaps identified by the previous review included:

- Impact of screening in the general population.
- Patient-centered issues, such as access to testing; effectiveness of screening approaches, including risk stratification; use of system supports; and patient acceptance and education.
- Studies about who should perform risk assessment and genetic counseling services, and what skills are needed.
- Studies about what happens after patients are identified as high-risk in clinical settings.
- The consequences of genetic testing for individuals and their relatives.
- Well-designed investigations using standardized measures and enrolling subjects who reflect the general population, including minority women.
- Information about predictors of cancer, response to interventions, and other modifying factors from an expanded database or registry of patients who are counseled and tested for BRCA mutations.
- Additional research on interventions, including trials of risk-reducing medications that enroll women who are mutation carriers, evaluations of the effect of age at intervention, measurement of long-term outcomes, and factors related to acceptance of risk-reducing interventions.

## Condition Definition

Clinically significant, or deleterious, mutations in the BRCA1 and BRCA2 genes are associated with increased risks for breast, ovarian, fallopian tube, and peritoneal cancer in women.6,7 Often referred to as the Hereditary Breast and Ovarian Cancer syndrome, this condition is described as BRCA-related cancer in this review to explicitly include fallopian tube and peritoneal cancer. Research indicates that BRCA-related fallopian tube cancer has probably been misdiagnosed as ovarian cancer in the past.8-10 These mutations are also associated with male breast cancer and, to a lesser degree, pancreatic and early-onset prostate cancer; BRCA2 mutations are associated with melanoma. Although all of these types of cancer are considered during familial risk assessment, studies with these cancer outcomes are outside the scope of this review. BRCA mutations cluster in families exhibiting an autosomal dominant pattern of transmission in either the maternal or paternal lineage.

Recent estimates indicate that clinically significant mutations in either of the BRCA genes increase a woman's risk of breast cancer by age 70 years to 45 to 65 percent.11,12 BRCA1 mutations increase ovarian, fallopian tube, or peritoneal cancer risk to 39 percent, and BRCA2 mutations to 10 to 17 percent.11,12 These mutations are estimated to occur in 1 in 300 to 500 women in the general population,13-16 and account for 5 to 10 percent of breast cancer overall.13,17

Specific BRCA mutations, known as founder mutations, are clustered among certain ethnic groups, including Ashkenazi Jews,18-20 blacks,21 and Hispanics,22,23 and among families in the Netherlands,24 Iceland,25,26 and Sweden.27 Several additional genes not included in this review are also associated with hereditary susceptibility to breast and ovarian cancer,7,28,29 but are not commonly tested.

Specific cancer phenotypes are also associated with BRCA mutations even in the absence of family history, including triple-negative breast cancer and high-grade serous ovarian or fallopian tube cancer.30-35 Pathologic and clinical characteristics of tumors also differ by the type of mutation. In a series of 3,797 cases of breast cancer in women who were BRCA1 mutation carriers, 78 percent were estrogen receptor (ER)–negative, 79 percent progesterone receptor (PR)–negative, 90 percent human epidermal growth factor receptor 2 (HER2)–negative, and 69 percent triple-negative.36 The proportion of ER-negative cases decreased with increasing age. In a series of 2,392 cases of breast cancer in women who were BRCA2 mutation carriers, 23 percent were ER-negative, 36 percent PR-negative, 87 percent HER2-negative, and 16 percent triple-negative.36 These characteristics are important in determining cancer treatment and prognosis.

## Prevalence and Burden of Disease

Breast cancer is the second most common cancer in women in the United States after nonmelanoma skin cancer, and is the second leading cause of cancer death after lung cancer.37,38 In 2013, an estimated 232,340 women in the United States will be diagnosed with breast cancer and 39,620 women will die from it.28 According to lifetime risk estimates for the general population, 12.3 percent (95% confidence interval [CI], 12.2 to 12.4) of women will develop breast cancer sometime during their lives, and 2.8 percent (95% CI, 2.76 to 2.80) will die from it.39 The 5-year relative survival rate for all stages of breast cancer in the United States is 89 percent, but improves to 99 percent with localized disease. Five-year relative survival rates for women with regional and distant disease are 84 and 23 percent, respectively.39

Ovarian cancer is the fifth leading cause of cancer death in women in the United States,38 accounting for an estimated 22,240 new cases and 14,030 deaths in 2013.^40^ According to lifetime risk estimates for the general population, 1.40 percent (95% CI, 1.38 to 1.43) of women will develop ovarian cancer sometime during their lives and 1.02 percent (95% CI, 1.01 to 1.03) will die from it.39 The 5-year relative survival rate for all stages of ovarian cancer in the United States is 44 percent, but may improve to 92 percent for women whose disease is detected and treated in early stages.39 However, up to 75 percent of women with ovarian cancer have nonlocalized disease at the time of diagnosis because early stages are often asymptomatic. Five-year relative survival rates for women with regional and distant disease are 72 and 27 percent, respectively.39

## Rationale for Screening/Screening Strategies

BRCA-related cancers are associated with family histories of these cancer types. Approximately 5 to 10 percent of women with breast cancer have a mother or sister with breast cancer, and up to 20 percent have either a first- or second-degree relative with breast cancer.41-45 Although most of these women do not have BRCA mutations, some women report family history patterns that suggest their presence. Genetic risk assessment and BRCA mutation testing involve determining individual risk for clinically significant BRCA mutations followed by mutation testing of high-risk individuals. Mutation testing of appropriate candidates could lead to increased awareness of cancer risk and effective use of interventions to reduce BRCA-related cancer incidence and mortality.

### Risk Assessment and Genetic Counseling

Several characteristics are associated with an increased likelihood of deleterious BRCA mutations,46-49 including breast cancer diagnosed at an early age (before age 40 or 50 years), bilateral breast cancer, triple-negative breast cancer diagnosed before age 50 years, history of both breast and ovarian cancer, breast cancer in male relatives, multiple cases of breast cancer in the family, both breast and ovarian cancer in the family, family members with two primary breast cancers, and Ashkenazi Jewish ancestry. These and other individual and family characteristics can be used to assess personal cancer risk and the need for referral for additional evaluation and testing. Approaches to assessing personal risk for BRCA mutation status range from simple checklists of criteria to comprehensive kindred analysis requiring expertise in cancer genetics. Practice and coverage standards in the United States generally follow the National Comprehensive Cancer Network (NCCN) referral criteria for genetic counseling (described in Appendix A1).50

Genetic counseling is the process of identifying and counseling individuals who are at risk for familial or inherited cancer and is recommended prior to BRCA mutation testing.50-52 Services include comprehensive evaluations of familial risk for inherited disorders using kindred analysis and models to estimate risk. These include models based on logistic regression (e.g., Couch46), Bayesian analysis (e.g., BRCAPRO,12,53 BOADICEA54), and patient data (Myriad prevalence tables55), among others. Some models are more appropriate for specific patients, and model accuracy varies across different populations.56 In the course of an evaluation for BRCA-related cancer, other cancer syndromes are sometimes identified. Genetic counseling also includes identification of candidates for testing, patient education, discussion of the benefits and harms of genetic testing, interpretation of results after testing, and discussion of management options. Some genetic counseling programs offer their services by telephone.

Providers of genetic counseling may be genetic counselors,57-59 nurse educators,60,61 or other health professionals with comparable skills.62 Accreditation standards from specialty groups specifically outline essential training and skills for genetics professionals.63

### Mutation Testing

The NCCN provides specific criteria for genetic testing.50 Guidelines recommend that mutation testing begin with a relative with known BRCA-related cancer, including male relatives, to determine if a clinically significant mutation is segregating in the family before testing individuals without cancer.50 If an affected family member is not available, then the relative with the highest probability of mutation should be tested. Ideally, results of the initial test will guide testing decisions of other family members. However, the optimal candidate may not be available for testing, limiting the interpretation of results. Individuals without cancer meeting NCCN criteria for testing include those from families with known BRCA1 or BRCA2 mutations or from families with extensive cancer history (further described in Appendix A1).

The type of mutation analysis required also depends on family history (Table 1). A small number of clinically significant BRCA1 and BRCA2 mutations have been found repeatedly in different families, including the three founder mutations common in the Ashkenazi Jewish population. However, most identified mutations have been found in only a few families.64 Individuals from families with known mutations or from ethnic groups with common mutations can be tested specifically for them. Several clinical laboratories in the United States test for specific mutations or sequence specific exons. The sensitivity and specificity of analytic techniques are determined by the laboratories and are not generally available.

Table 1 Types of Clinical Testing for BRCA Mutations in the United States96

Test | Description | Approximate cost (U.S. $)^*^
Comprehensive testing | Gene sequencing of the entire length of both BRCA1 and BRCA2 and a five-site rearrangement panel of specific large-scale rearrangements. | >$3000
Single site testing | One specific gene mutation when the mutation in the family has already been identified. | $475
Multisite panel | Three specific gene changes common among Ashkenazi Jewish ancestry. | $575
BRCA Rearrangement Test | Large-scale rearrangements within the BRCA genes that would not have been detected through comprehensive testing. | $700

* Reflects costs prior to the recent U.S. Supreme Court decision against DNA patents.

Individuals without linkages to known mutations can determine their mutation status by direct DNA sequencing. A commercial laboratory, Myriad Genetic Laboratories, previously held a patent on this procedure and provided most of the testing in the United States. Myriad reports analytic sensitivity and specificity as both greater than 99 percent.65 Approximately 12 percent of high-risk families without a BRCA1 or BRCA2 coding-region mutation may have other clinically significant genomic rearrangements.65,66 Many of these mutations can be tested using the BRCA Rearrangement Test, now available as a subsequent step in testing.

Tests may indicate positive (i.e., BRCA mutation detected), variant of uncertain clinical significance (i.e., an abnormality of the BRCA gene, but unknown if it is associated with an increased risk for cancer), uninformative negative, or true negative results. A true negative result represents the absence of a mutation in an individual who has relatives with cancer and known BRCA mutations. An uninformative negative also indicates the absence of a mutation in an individual; however, information about her relatives is not definitive because either a mutation was not detected by their tests or they have not been tested.

## Interventions

Interventions to reduce risk for cancer in women who are BRCA mutation carriers include earlier, more frequent, or intensive cancer screening; risk-reducing medications; and risk-reducing surgery. Cancer screening recommendations specifically for women who are BRCA mutation carriers are outside the scope of the USPSTF. The NCCN recommends that women who are BRCA mutation carriers conduct monthly breast self-examinations beginning by age 18 years, annual or semiannual clinician breast examinations beginning at age 25 years, and annual mammography and breast magnetic resonance imaging (MRI) beginning at age 25 years or individualized based on the earliest age of onset in the family.50 The NCCN also recommends that women consider risk-reducing mastectomy and salpingo-oophorectomy, monitoring with transvaginal ultrasound (TVUS) and cancer antigen-125 (CA-125) levels every 6 months for women not undergoing salpingo-oophorectomy, and risk-reducing medications.

Tamoxifen, a selective estrogen receptor modulator (SERM), is considered a candidate for breast cancer risk reduction based on its effectiveness in preventing recurrences in women with breast cancer.67 Placebo-controlled randomized, controlled trials (RCTs) of tamoxifen indicate reduced primary ER-positive breast cancer in women with family histories of breast cancer.68-72 Raloxifene, another SERM used primarily for treating osteoporosis, also reduced risk for breast cancer in trials of women with various levels of breast cancer risk.73,74 SERMs also have important adverse effects, including thromboembolism, endometrial cancer (tamoxifen), and vasomotor and other symptoms.75,76 Exemestane, an aromatase inhibitor, also reduces risk for primary breast cancer in women with increased risk77 and is in clinical use, but is not approved by the U.S. Food and Drug Administration for this indication. The USPSTF currently recommends consideration of risk-reducing medications for women who are at increased risk for breast cancer and low risk for complications, and discourages its use in average-risk women.78

Risk-reducing mastectomy and salpingo-oophorectomy are also options for women who are BRCA mutation carriers.79-82 Bilateral total simple mastectomy with or without reconstruction is currently the most common approach.83,84 This procedure provides more complete removal of breast tissue than the previously used subcutaneous mastectomy. However, no procedure completely removes all breast tissue85 and breast cancer can still occur postmastectomy.86 Surgical reports indicating the potential for cancer occurrence after bilateral oophorectomy have led to more extensive procedures to remove potential tumor sites, such as bilateral salpingo-oophorectomy with or without hysterectomy.87,88 Despite this approach, the occurrence of peritoneal carcinomatosis remains a possibility.89-91

## Current Clinical Practice

Guidelines recommend testing for mutations only when an individual has personal or family history of cancer suggestive of inherited cancer susceptibility, the test can be adequately interpreted, and results will aid in management.51,92

Actual practices in the United States are unclear. The lack of effectiveness trials, differing interpretations of existing research among specialties, variability of insurance coverage, and direct-to-consumer advertising targeting patients, physicians, and health systems have resulted in highly variable clinical practices. The initial focus of mutation testing has been on patients with cancer. For women without cancer or relatives with known BRCA mutations, an integrated clinical pathway generally involves a series of sequential steps, including: 1) risk stratification and referral for genetic counseling, 2) genetic counseling for women identified with increased risk based on family history information, 3) BRCA mutation testing for women or their relatives with significant familial risk, and 4) interventions to reduce risk based on benefits, harms, and patient preferences.

In practice, these steps may not be sequential or clearly defined. In the United States, genetic testing is marketed directly to consumers, who may bypass preceding steps. In surveys, many clinicians were unfamiliar with genetic tests and criteria for referral or testing.93,94 Some clinicians provide risk assessment, testing, and risk-reducing surgery without using comprehensive risk assessment methods or involving genetic counselors. Screening MRI is often performed based on risk criteria or other considerations that have not been evaluated for effectiveness, while risk-reducing medications are rarely used.95

Relevant data describing current clinical practice was collected through the Michigan Department of Community Health Cancer Genomics Program using statewide telephone surveys and a clinical genetic counseling database. Results indicated that approximately 8 percent of women without breast or ovarian cancer had two or more first- or second-degree relatives with breast or ovarian cancer.96 Among women without cancer who had family histories indicating that they would probably benefit from genetic counseling, 35.7 percent received genetic counseling and 9.8 percent had genetic testing during 2009. Most referrals of women without cancer were made by obstetricians/gynecologists, primary care physicians, or patients themselves, comprising 44.3 percent of patients counseled. Among women without cancer who saw genetic counselors, 55.2 percent underwent genetic testing. Of these, results indicated 91.6 percent were negative, 3.9 percent were positive, and 4.5 percent were variants of unknown significance. Respondents described their top three reasons for declining testing after receiving genetic counseling as: 1) not being the best candidate, 2) the test was not clinically indicated, and 3) inadequate insurance coverage.

The uptake of specialized services after genetic testing is generally high among women with positive test results that indicate the presence of clinically significant BRCA mutations.97,98 In a recent study of women who had genetic testing in a U.S. university-based cancer risk program, women with positive results were significantly more likely to have risk-reducing salpingo-oophorectomy and screening with TVUS and serum CA-125 testing, while those with true negative results were less likely to have these procedures.99 Among women with variants of uncertain significance and uninformative negative results, 12 percent had risk-reducing salpingo-oophorectomy, 37 percent had TVUS, and 34 percent had serum CA-125 testing.

## Recommendations of Other Groups

Current recommendations of other professional groups are described in Table 2.

Table 2 Recommendations of Other Groups

Organization, year | Recommendations
American Society of Clinical Oncology, 2010^327^ | ASCO recommends genetic testing when: 1) there is personal or family history suggestive of genetic cancer susceptibility, 2) the test can be adequately interpreted, and 3) the results will aid in diagnosis or medical management of the patient or family members at hereditary risk of cancer. ASCO recommends genetic testing only when pre- and post-test counseling is included.
American Congress of Obstetricians and Gynecologists, 2009^323^ | For patients who are likely to have hereditary breast and ovarian cancer syndrome, ACOG recommends further genetic risk assessment for women who have more than a 20%–25% chance of having an inherited predisposition to breast or ovarian cancer. ACOG also suggests genetic risk assessment may also be appropriate for patients with a 5%–10% chance of having hereditary risk. Recommended screening and prevention plans are based on individual risk factors and family history.
American Society of Human Genetics, 1994^322^ | Testing should initially be offered and performed on an investigational basis by appropriately trained health care professionals who have a therapeutic relationship with the patient and are fully aware of the genetic, clinical, and psychological implications of testing, as well as of the limitations of existing test procedures. Linkage analysis is recommended for select high-risk families, if it will provide for more refined counseling than is currently available from family history alone. It is premature to offer population screening, until the risks associated with specific BRCA1 mutations are determined.
National Comprehensive Cancer Network, 2012^50^ | NCCN recommends risk assessment and counseling if the hereditary breast and/or ovarian cancer syndrome testing criteria are met. Genetic testing is recommended if criteria are met (see Appendix A1).
European Society for Medical Oncology, 2011^324^ | In all cases in which a patient may be referred for BRCA testing, the ESMO Guidelines Working Group recommends informed consent and genetic counseling be completed first. Carriers should be encouraged to advise close family members to obtain genetic counseling.
National Society of Genetic Counselors, 2012^326^ | Genetic testing should be offered to individuals with a personal or family history suggestive of an inherited cancer syndrome; when the test can be adequately interpreted; if testing will influence medical management of the patient or relatives; when potential benefits outweigh potential risks; if testing is voluntary; and when the individual seeking testing or their legal proxy can provide informed consent.
Society of Gynecologic Oncologists Education Committee, 2007^325^ | The SGO Education Resource Panel for Hereditary Cancers believes that individuals with a personal risk of having an inherited predisposition to cancer of greater than approximately 20%–25% should undergo genetic risk assessment. It also believes that it is reasonable to offer genetic risk assessment to any individual with greater than approximately 5%–10% chance of having an inherited predisposition to cancer. Genetic testing for cancer predisposition requires informed consent that should include pretest education and counseling concerning the risks, benefits, and limitations of testing, including the implications of both positive and negative genetic test results.