# Evidence Tables and Quality Tables

Appendix C1 Quality Ratings for Randomized, Controlled Trials

Appendix C2 Quality Ratings for Cohort Studies

Appendix C3 Quality Ratings for Case-Control Studies

Appendix C4 Quality Rating for Systematic Review

Appendix C5 Familial Risk Assessment Models

Appendix C6 Evidence Table of Genetic Counseling

Appendix C7 Evidence Table of Prevalence of BRCA1 and BRCA2 Mutations

Appendix C8 Evidence Table of Penetrance of BRCA-Related Cancer

Appendix C9 Evidence Table of Distress After Genetic Testing

Appendix C10 Evidence Table of Intensive Screening Interventions

Appendix C11 Evidence Table of Risk-Reducing Medications

Appendix C12 Evidence Table of Risk-Reducing Surgery

Appendix C13 Evidence Table of Harms of Intensive Screening

Appendix C14 Evidence Table of Psychological and Sexual Functioning Harms of Interventions