# Detailed Methods

## Appendix B1 Search Strategies

### Ethical, legal, and social implications of genetic testing

Database: Ovid MEDLINE(R) without Revisions <2004to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/ or exp ovarian neoplasms/ (140349)
2. exp Mass Screening/ or gene.mp. or genes.mp. or genetic$.mp. or brca$.mp. (1445145)
3. exp LEGISLATION/ (75)
4. exp JURISPRUDENCE/ (74415)
5. lj.fs. (120944)
6. 3 or 4 or 5 (161388)
7. exp bioethical issues/ or exp bioethics/ or ethic$.mp. or bioethic$.mp. (67517)
8. exp human rights/ (62937)
9. 6 or 7 or 8 (229177)
10. 1 and 2 and 9 (529)
11. limit 10 to (human and english language) (471)

### Genetic testing

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Preventive Medicine/ (5575)
2. exp Family Practice/ (30023)
3. exp Primary Health Care/ (46956)
4. exp Physicians, Family/ (8506)
5. 1 or 2 or 3 or 4 (83722)
6. exp Breast Neoplasms/ or exp ovarian cancer/ (140349)
7. exp Genetic Predisposition to Disease/ (64428)
8. exp Genetic Screening/ (18587)
9. 6 and (7 or 8) (5051)
10. exp Breast Neoplasms/ge or exp ovarian cancer/ge (26159)
11. 9 or 10 (26498)
12. 5 and 11 (107)

### Genetic counseling

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Genetic Counseling/ or Genetic counseling.mp. or genetic counselling.mp. (9041)
2. decision making.mp. or exp Decision Making/ (101487)
3. exp RISK/ (521470)
4. risk$.mp. (946578)
5. exp Breast Neoplasms/ or breast neoplasm$.mp. or Breast cancer$.mp. or exp ovarian neoplasms/ or ovarian cancer$.mp. or ovarian neoplasm$.mp. (159780)
6. 1 and (2 or 3 or 4) and 5 (845)

### Prediction of disease occurrence

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/mo, pc, ep, eh or exp ovarian neoplasms/mo, pc, ep, eh (26852)
2. exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or brca1.mp. (7633)
3. exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or brca2.mp. (4955)
4. 2 or 3 (8589)
5. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge (26159)
6. (sensitivity and specificity).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (248591)
7. exp “Sensitivity and Specificity”/ (297204)
8. risk$.mp. or exp RISK/ (972965)
9. 5 and (6 or 7 or 8) (8244)
10. 1 and 4 and 9 (1154)

### Harms of risk assessment and testing

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/ or exp ovarian neoplasms/ (140349)
2. exp genetic screening/ae or exp genetic services/ae or exp genetic counseling/ae or exp genetic screening/px or exp genetic services/px or genetic counseling/px (1216)
3. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge (26159)
4. exp stress, psychological/ (45845)
5. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or toll)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (46774)
6. exp anxiety/ or anxious$.mp. or anxiet$.mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (74486)
7. 4 or 5 or 6 (117272)
8. (1 and 2) or (3 and 7) (519)

### General interventions

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr or exp ovarian Neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr (64932)
2. exp Treatment Outcome/ or treatment outcome$.mp. (481071)
3. exp “Outcome Assessment (Health Care)”/ or outcome assessment$.mp. (506781)
4. 1 or 2 or 3 (568295)
5. exp Breast Neoplasms/mo, ep, eh or exp ovarian Neoplasms/mo, ep, eh (21305)
6. exp Breast Neoplasms/ or exp ovarian neoplasms/ (140349)
7. exp MORTALITY/ or mortal$.mp. or mortality.fs. (447369)
8. exp INCIDENCE/ or incidence$.mp. or epidemiology.fs. or ethnology.fs. (866897)
9. 7 or 8 (1173771)
10. 6 and 9 (32386)
11. 5 or 10 (32386)
12. exp RISK/ (521470)
13. risk$.mp. (946578)
14. exp Genetic Predisposition to Disease/ or genetic predisposition to disease$.mp. (64440)
15. pedigree.mp. or exp PEDIGREE/ (35569)
16. 12 or 13 or 14 or 15 (1034441)
17. exp Breast Neoplasms/ge or exp ovarian neoplasms/ge (26159)
18. exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or brca1.mp. (7633)
19. exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or brca2.mp. (4955)
20. 17 or 18 or 19 (29475)
21. 4 and 11 and 16 and 20 (769)

### Harms of interventions

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/dt, su or exp ovarian neoplasms/dt, su (44424)
2. exp Breast Neoplasms/pc or exp ovarian neoplasms/pc (7801)
3. chemoprevention.mp. or exp CHEMOPREVENTION/ (14341)
4. primary prevention.mp. or exp Primary Prevention/ (52812)
5. 2 or 3 or 4 (73750)
6. postoperative complications.mp. or exp Postoperative Complications/ (194521)
7. intraoperative complications.mp. or exp Intraoperative Complications/ (23574)
8. ae.xs. or ct.fs. (11782)
9. exp stress, psychological/ (45845)
10. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or toll)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (46774)
11. ((psycholog$ or emotion$ or mental$) adj3 (stress$ or strain$ or burden$ or fear$ or toll)).mp. (47508)
12. exp anxiety/ or anxiet$.mp. or anxious$.mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (74486)
13. 9 or 10 or 11 or 12 (117833)
14. 6 or 7 or 8 or 13 (337084)
15. 1 and 5 and 14 (49)

### BRCA studies

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp case control studies/ (417789)
2. brca$.mp. (8951)
3. 1 and 2 (663)
4. exp breast neoplasms/ (113859)
5. exp ovarian neoplasms/ (30269)
6. 4 or 5 (140349)
7. 3 and 6 (578)

### Prediction models

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. (gail adj model$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (120)
2. (claus adj model$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (23)
3. 1 or 2 (135)
4. exp Models, Statistical/ (183287)
5. exp risk/ (521470)
6. exp Breast Neoplasms/ge [Genetics] (21383)
7. 4 and 5 and 6 (487)
8. 3 or 7 (613)
9. limit 8 to humans (613)
10. limit 9 to abstracts (584)
11. limit 9 to english (601)
12. 10 or 11 (613)

### Prophylactic surgery interventions

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/pc [Prevention & Control] (7136)
2. exp Ovarian Neoplasms/pc [Prevention & Control] (1016)
3. (mastectom$ or oophoectom$ or ovariectom$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (27586)
4. 1 or 2 (7801)
5. 3 and 4 (872)
6. (family adj5 histor$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (26320)
7. exp Genetic Predisposition to Disease/ (64428)
8. brca.mp. (1378)
9. (brca1 or brca2).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (8589)
10. 6 or 7 or 8 or 9 (93492)
11. 5 and 10 (488)
12. limit 11 to human (488)
13. limit 12 to english language (446)
14. limit 12 to abstracts (380)
15. 13 or 14 (479)

### Tamoxifen and raloxifene

Database: Ovid MEDLINE(R) without Revisions <2004 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Breast Neoplasms/pc [Prevention & Control] (7136)
2. exp Ovarian Neoplasms/pc [Prevention & Control] (1016)
3. 1 or 2 (7801)
4. (family adj5 histor$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (26320)
5. exp Genetic Predisposition to Disease/ (64428)
6. brca.mp. (1378)
7. (brca1 or brca2).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (8589)
8. 4 or 5 or 6 or 7 (93492)
9. exp Selective Estrogen Receptor Modulators/ (12837)
10. (serm or serms or tamoxifen or raloxifene).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (14849)
11. 9 or 10 (16490)
12. 3 and 8 and 11 (153)
13. exp Contraceptives, Oral/ (13048)
14. 3 and 8 and 13 (54)
15. 12 or 14 (195)
16. limit 15 to humans (195)
17. limit 16 to abstracts (166)
18. limit 16 to english (176)
19. 17 or 18 (191)

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | Asymptomatic adult (age 18 years or older) women with a family history of breast and/or ovarian cancer | Men, children, women with prior history of breast and/or ovarian cancer, no family history of breast and/or ovarian cancer
Interventions | Risk assessment, genetic counseling, and genetic testing for deleterious BRCA1 or BRCA2 mutations, interventions primarily aimed at reducing the risk of BRCA-related cancer in women with deleterious mutations: intensive screening (e.g., earlier and more frequent mammography, breast magnetic resonance imaging), use of medications (e.g., tamoxifen, raloxifene), and risk-reducing surgery (e.g., mastectomy, oophorectomy) | Surveillance, referral practices, testing for polymorphisms
Outcomes | Invasive breast cancer, invasive ovarian cancer, other BRCA-related cancer (fallopian tube, peritoneal), mortality (all cause, cancer-specific). Harms include inaccurate risk assessment; inappropriate testing; false-positive and false-negative results; adverse impact on the patient's relationships with family; false reassurance; incomplete testing; misinterpretation of the test result; anxiety; cancer worry; immediate and long-term harms associated with breast imaging, risk-reducing medications, and risk-reducing surgery; and ethical, legal, and social implications | Increased detection, predictors of adherence, uptake of screening or risk-reducing interventions
Study types and designs | Randomized, controlled trials; prospective and retrospective cohort studies; case-control studies; cross-sectional studies (for harms); systematic reviews; and meta-analyses | Case reports

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials (RCTs) and Cohort Studies

Criteria
- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

Criteria
- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

Definition of ratings based on criteria above

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

### Systematic Reviews

Criteria
- Search dates reported?
- Search methods reported?
- Comprehensive search?
- Inclusion criteria reported?
- Selection bias avoided?
- Validity criteria reported?
- Validity assessed appropriately?
- Methods used to combine studies reported?
- Findings combined appropriately?
- Conclusions supported by data?

Definitions of ratings based on above criteria

Good: | Meets all criteria: reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.
Fair: | Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.
Poor: | Studies will be graded poor if they have a major limitation in one or more of the above criteria.
Source: | Harris et al, 2001^100^

## Appendix B4 List of Reviewers

Expert reviewers
- Bruce Nedrow Calogne, M.D., M.P.H., President and CEO, Colorado Trust; Chair, Centers for Disease Control and Prevention Evaluating Genomic Applications for Practice and Prevention (EGAPP) Workgroup; Associate Professor of Family Medicine, Department of Family Medicine, University of Colorado Denver School of Medicine (UCD) and Associate Professor of Preventive Medicine and Biometrics, UCD Colorado School of Public Health
- Kelly Metcalfe, R.N., Ph.D., Associate Professor, Lawrence S. Bloomberg Faculty of Nursing, University of Toronto
- Steven Narod, M.D., Senior Scientist, Women's College Research Institute; Director, Familial Breast Cancer Research Unit, Women's College Research Institute; Professor, Dalla Lana School of Public Health, University of Toronto; Professor, Department of Medicine, University of Toronto; Tier 1 Canada Research Chair in Breast Cancer
- Mark Robson, M.D., Clinical Director, Clinical Genetics Service, Memorial Sloan Kettering Cancer Center

Federal reviewers
- Joseph Chin, M.D., Office of Clinical Standards and Quality, Centers for Medicare and Medicaid Services
- Mark H. Greene, M.D., Chief, Clinical Genetics Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, National Institutes of Health
- Katherine Kolor, Ph.D., Office of Public Health Genomics, Centers for Disease Control and Prevention
- Jacqueline Miller, M.D., Office of Public Health Genomics, Centers for Disease Control and Prevention

## Appendix B5 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, and suggestions by experts.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

§ Studies may contribute data to more than one key question.

Abbreviation: KQ = key question.

## Appendix B6 Excluded Studies List

Key to exclusion codes

2 | Background
3 | Wrong population
4 | Wrong intervention
5 | Wrong publication type
6 | Conducted prior to 2004
7 | Foreign language study, otherwise included
8 | Wrong outcome

Myriad Genetic Laboratories, Inc. http://www.myriadtests.com/index.php. 25 Oct, 2011. Exclusion code: 2.
Ad Hoc Committee on Genetic Counseling of the American Society of Human Genetics. Am J Hum Genet. 1975;27:240-242. Exclusion code: 2. [pmid: 1124768].
Tarasoff v. Regents of the University of California 551 P.2d 334. Supreme Court of California. 1976. Exclusion code: 5.
Statement of the American Society of Human Genetics on genetic testing for breast and ovarian cancer predisposition. Am J Hum Genet. 1994;55(5):i-iv. Exclusion code: 2. [pmid: 7977337].
FL recognizes duty to warn patient of transmissibility of genetic disease to child - Pate v. Threlkel, 661 So.2d 278 (Fla. 1995), rehearing denied (Oct 10, 1995). Supreme Court of Florida. 1995. Exclusion code: 5.
Statement of the American Society of Clinical Oncology: Genetic Testing for Cancer Susceptibility. J. Clin. Oncol. 1996;14(5):1730-1736. Exclusion code: 2. [pmid: 8622094].
Safer v. Estate of Pack, 677 A.2d 1188-NJ: Appellate Div. 1996. Superior Court of New Jersey, Appellate Division. 1996. Exclusion code: 5.
Tenuto v. Lederle Laboratories, Div of American Cyanamid Co, 90 NY2d 606, 687 NE2d 1300, 665 NYS2d 17. The Court of Appeals of the State of New York. 1997. Exclusion code: 5.
Molloy v. Meier C9 02 1821 C2 02 1837 C9 02 1821 C2 02 1837 C2 02 1837. Court Appeals of Minnesota. 2003. Exclusion code: 5.
Genetic susceptibility to breast and ovarian cancer: Assessment, counseling and testing guidelines. New York State Department of Health. 2004. Exclusion code: 2.
Gene patent fight. New Sci. 2005;186(2505):7. Exclusion code: 5. [pmid: 16178103].
Society of Gynecologic Oncologists Clinical Practice Committee Statement on Prophylactic Salpingo-oophorectomy. Gynecol. Oncol. 2005;98(2):179-181. Exclusion code: 5. [pmid: 15979696].
Summaries for patients. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: U.S. Preventive Services Task Force recommendations. Ann. Intern. Med. 2005;143(5):I47. Exclusion code: 5. [pmid: 16144889].
National Institutes of Health State-of-the-Science Conference statement: management of menopause-related symptoms. Ann. Intern. Med. 2005;142(12 Pt 1):1003-1013. Exclusion code: 5. [pmid: 15968015].
State by state comparison of insurance regulations. J. Natl. Cancer Inst. 2006;98(15):1034. Exclusion code: 5. [pmid: 16882939].
First do no harm. Lancet Oncol. 2009;10(10):927. Exclusion code: 5. [pmid: 19796744].
Study of Tamoxifen and Raloxifene (STAR) for the Prevention of Breast Cancer in Postmenopausal Women. 2011. http://www.cancer.gov/clinicaltrials/search/view?cdrid=651291&version=healthprofessional. 25 Oct, 2011. Exclusion code: 2.
Hereditary breast and ovarian cancer: risks and challenges. Proceedings of a meeting. September 10-12, 2009. Bari, Italy. Ann. Oncol. Suppl 1. 2011;22:i5-68. [pmid: 21438196]. Exclusion code: 5.
Aalfs CM, Mollema ED, Oort FJ, de Haes JCJM, Leschot NJ, Smets EMA. Genetic counseling for familial conditions during pregnancy: An analysis of patient characteristics. Clin. Genet. 2004;66(2):112-121. Exclusion code: 3. [pmid: 15253761].
Abeliovich D, Kaduri L, Lerer I, et al. The founder mutations 185delAG and 5382insC in BRCA1 and 6174delT in BRCA2 appear in 60% of ovarian cancer and 30% of early-onset breast cancer patients among Ashkenazi women. Am. J. Hum. Genet. 1997;60(3):505-514. Exclusion code: 2. [pmid: 9042909].
Abrahams E, Silver M. The case for personalized medicine. J Diabetes Sci Technol. 2009;3(4):680-684. Exclusion code: 5. [pmid: 20144313].
Acheson LS, Wang C, Zyzanski SJ, et al. Family history and perceptions about risk and prevention for chronic diseases in primary care: a report from the family healthware impact trial. Genet Med. 2010;12(4):212-218. Exclusion code: 3. [pmid: 20216073].
Acheson LS, Zyzanski SJ, Stange KC, Deptowicz A, Wiesner GL. Validation of a self-administered, computerized tool for collecting and displaying the family history of cancer. J. Clin. Oncol. 2006;24(34):5395-5402. Exclusion code: 8. [pmid: 17088568].
Ackermann S, Lux MP, Fasching PA, et al. Acceptance for preventive genetic testing and prophylactic surgery in women with a family history of breast and gynaecological cancers. Eur. J. Cancer Prev. 2006;15(6):474-479. Exclusion code: 8. [pmid: 17106324].
Acog. ACOG Practice Bulletin No. 89. Elective and risk-reducing salpingo-oophorectomy. Obstet. Gynecol. 2008;111(1):231-241. Exclusion code: 5. [pmid: 18165419].
Adams-Campbell LL, Makambi KH, Frederick WAI, Gaskins M, Dewitty RL, McCaskill-Stevens W. Breast cancer risk assessments comparing Gail and CARE models in African-American women. Breast J. 2009;15(Suppl 1):S72-75. Exclusion code: 8. [pmid: 19775333].
Ader T, Susswein LR, Callanan NP, Evans JP. Attitudes and practice of genetic counselors regarding anonymous testing for BRCA1/2. J Genet Couns. 2009;18(6):606-617. Exclusion code: 8. [pmid: 19798553].
Agnantis NJ, Paraskevaidis E, Roukos D. Preventing breast, ovarian cancer in BRCA carriers: rational of prophylactic surgery and promises of surveillance. Ann. Surg. Oncol. 2004;11(12):1030-1034. Exclusion code: 5. [pmid: 15545500].
Agnusdei D. Clinical efficacy of raloxifene in postmenopausal women. Eur. J. Obstet. Gynecol. Reprod. Biol. 1999;85(1):43-46. Exclusion code: 5. [pmid: 10428320].
Akbari MR, Zhang S, Fan I, et al. Clinical impact of unclassified variants of the BRCA1 and BRCA2 genes. J. Med. Genet. 2011;48(11):783-786. Exclusion code: 2. [pmid: 21965345].
Alarcon F, Bourgain C, Gauthier-Villars M, Plante-Bordeneuve V, Stoppa-Lyonnet D, Bonaiti-Pellie C. PEL: an unbiased method for estimating age-dependent genetic disease risk from pedigree data unselected for family history. Genet. Epidemiol. 2009;33(5):379-385. Exclusion code: 5. [pmid: 19089844].
Albada A, Ausems MGEM, Otten R, Bensing JM, van Dulmen S. Use and evaluation of an individually tailored website for counselees prior to breast cancer genetic counseling. J. Cancer Educ. 2011;26(4):670-681. Exclusion code: 4. [pmid: 21533850].
Albada A, van Dulmen S, Ausems MGEM, Bensing JM. A pre-visit website with question prompt sheet for counselees facilitates communication in the first consultation for breast cancer genetic counseling: findings from a randomized controlled trial. Genet Med. 2012;14(5):535-542. Exclusion code: 3. [pmid: 22241101].
Albada A, van Dulmen S, Lindhout D, Bensing JM, Ausems MGEM. A pre-visit tailored website enhances counselees' realistic expectations and knowledge and fulfils information needs for breast cancer genetic counselling. Fam Cancer. 2012;11(1):85-95. Exclusion code: 3. [pmid: 21901499].
Albada A, van Dulmen S, Otten R, Bensing JM, Ausems MGEM. Development of E-info gene(ca): a website providing computer-tailored information and question prompt prior to breast cancer genetic counseling. J Genet Couns. 2009;18(4):326-338. Exclusion code: 8. [pmid: 19440661].
Allain DC. Genetic counseling and testing for common hereditary breast cancer syndromes: a paper from the 2007 William Beaumont hospital symposium on molecular pathology. J Mol Diagn. 2008;10(5):383-395. Exclusion code: 5. [pmid: 18687797].
Allain DC, Sweet K, Agnese DM. Management options after prophylactic surgeries in women with BRCA mutations: a review. Cancer Control. 2007;14(4):330-337. Exclusion code: 5. [pmid: 17914333].
Altschuler A, Somkin CP. Women's decision making about whether or not to use breast cancer chemoprevention. Women Health. 2005;41(2):81-95. Exclusion code: 8. [pmid: 16219589].
American Civil Liberties Union. ACLU and PUBPAT Ask Supreme Court to Rule that Patents on Breast Cancer Genes Are Invalid. 2012. http://www.aclu.org/womens-rights/aclu-and-pubpat-ask-supreme-court-rule-patents-breast-cancer-genes-are-invalid. 24 Oct, 2012. Exclusion code: 2.
American College of Medical Genetics Professional Practice and Guidelines Committee. Genetic susceptibility to breast and ovarian cancer: Assessment, counseling, and testing guidelines executive summary. 1999. http://www.health.ny.gov/diseases/cancer/obcancer/contents.htm. 16 Oct 2012. Exclusion code: 2.
American College of Surgeons. Cancer Program Standards. 2012. http://www.facs.org/cancer/coc/programstandards2012.html. 26 Feb 2013. Exclusion code: 2.
American Congress of Obstetricians and Gynecologists, ACOG Committee on Practice Bulletins--Gynecology, ACOG Committee on Genetics, Society of Gynecologic Oncologists. ACOG Practice Bulletin No. 103: Hereditary breast and ovarian cancer syndrome. Obstet. Gynecol. 2009;113(4):957-966. Exclusion code: 5. [pmid: 19305347].
Amir E, Evans DG, Shenton A, et al. Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J. Med. Genet. 2003;40(11):807-814. Exclusion code: 2. [pmid: 14627668].
Amir E, Freedman O. Underestimation of risk by Gail model extends beyond women with atypical hyperplasia. J. Clin. Oncol. 2009;27(9):1526. author reply 1527. Exclusion code: 5. [pmid: 19204192].
Amir E, Freedman OC, Seruga B, Evans DG. Assessing women at high risk of breast cancer: a review of risk assessment models. J. Natl. Cancer Inst. 2010;102(10):680-691. Exclusion code: 2. [pmid: 20427433].
Andersen M, Drescher CW, Zheng Y, et al. Changes in cancer worry associated with participation in ovarian cancer screening. Psychooncology. 2007;16(9):814-820. Exclusion code: 3. [pmid: 17225260].
Anderson E, Berg J, Black R, et al. Prospective surveillance of women with a family history of breast cancer: auditing the risk threshold. Br. J. Cancer. 2008;98(4):840-844. Exclusion code: 3. [pmid: 18283300].
Anderson G, Jun M, Choi K. Breast cancer screening for Korean women must consider traditional risks as well as two genetic risk factors: genetic polymorphisms and inheritable gene mutations. Cancer Nurs. 2007;30(3):213-222. Exclusion code: 5. [pmid: 17510585].
Andersson I, Janzon L. Reduced breast cancer mortality in women under age 50: updated results from the Malmo Mammographic Screening Program. J Natl Cancer Inst Monogr. 1997;22:63-67. Exclusion code: 3. [pmid: 9709278].
Ando N, Iwamitsu Y, Kuranami M, et al. Concerns about inherited risk of breast cancer prior to diagnosis in Japanese patients with breast complaints. Fam Cancer. 2011;10(4):681-689. Exclusion code: 4. [pmid: 21701918].
Andolf E, Jorgensen C, Astedt B. Ultrasound examination for detection of ovarian carcinoma in risk groups. Obstet. Gynecol. 1990;75(1):106-109. Exclusion code: 8. [pmid: 2404221].
Andresen EM, Catlin TK, Wyrwich KW, Jackson-Thompson J. Retest reliability of surveillance questions on health related quality of life. J. Epidemiol. Community Health. 2003;57(5):339-343. Exclusion code: 2. [pmid: 12700216].
Andrews L, Meiser B, Apicella C, Tucker K. Psychological impact of genetic testing for breast cancer susceptibility in women of Ashkenazi Jewish background: a prospective study. Genet Test. 2004;8(3):240-247. Exclusion code: 3. [pmid: 15727246].
Andrieu N, Goldgar DE, Easton DF, et al. Pregnancies, breast-feeding, and breast cancer risk in the International BRCA1/2 Carrier Cohort Study (IBCCS). J. Natl. Cancer Inst. 2006;98(8):535-544. Exclusion code: 8. [pmid: 16622123].
Andrykowski MA, Boerner LM, Salsman JM, Pavlik E. Psychological Response to Test Results in an Ovarian Cancer Screening Program: A Prospective, Longitudinal Study. Health Psychol. 2004;23(6):622-630. Exclusion code: 3. [pmid: 15546230].
Ang P, Lim IHK, Lee TC, et al. BRCA1 and BRCA2 mutations in an Asian clinic-based population detected using a comprehensive strategy. Cancer Epidemiol. Biomarkers Prev. 2007;16(11):2276-2284. Exclusion code: 3. [pmid: 18006916].
Annunziata MA, Muzzatti B, Narciso D, et al. Mood state profile and coping strategies after BRCA-1/2 genetic test disclosure: a retrospective study in Italy. Support. Care Cancer. 2011;19(6):733-735. Exclusion code: 3. [pmid: 21267604].
Anonymous. Ovary removal reduces cancer risk for BRCA1/2 carriers. Health News. 2006;12(10):6-7. Exclusion code: 5. [pmid: 17162794].
Antill Y, Reynolds J, Young MA, et al. Risk-reducing surgery in women with familial susceptibility for breast and/or ovarian cancer. Eur. J. Cancer. 2006;42(5):621-628. Exclusion code: 3. [pmid: 16434187].
Antill YC, Reynolds J, Young MA, et al. Screening behavior in women at increased familial risk for breast cancer. Fam Cancer. 2006;5(4):359-368. Exclusion code: 4. [pmid: 16817030].
Antoniou A, Cunningham A, Peto J. The BOADICEA model of genetic susceptibility to breast and ovarian cancers: updates and extensions. Br J Ca. 2008;98(8):1457-1466. Exclusion code: 2. [pmid: 18349832].
Antoniou AC, Beesley J, McGuffog L, et al. Common breast cancer susceptibility alleles and the risk of breast cancer for BRCA1 and BRCA2 mutation carriers: Implications for risk prediction. Cancer Res. 2010;70(23):9742-9754. Exclusion code: 2. [pmid: 21118973].
Antoniou AC, Gayther SA, Stratton JF, Ponder BAJ, Easton DF. Risk models for familial ovarian and breast cancer. Genet. Epidemiol. 2000;18(2):173-190. Exclusion code: 2. [pmid: 10642429].
Antoniou AC, Goldgar DE, Andrieu N, et al. A weighted cohort approach for analysing factors modifying disease risks in carriers of high-risk susceptibility genes. Genet. Epidemiol. 2005;29(1):1-11. Exclusion code: 5. [pmid: 15880399].
Antoniou AC, Kartsonaki C, Sinilnikova OM, et al. Common alleles at 6q25.1 and 1p11.2 are associated with breast cancer risk for BRCA1 and BRCA2 mutation carriers. Hum. Mol. Genet. 2011;20(16):3304-3321. Exclusion code: 2. [pmid: 21593217].
Antoniou AC, Pharoah PD, McMullan G, et al. A comprehensive model for familial breast cancer incorporating BRCA1, BRCA2 and other genes. Br. J. Cancer. 2002;86(1):76-83. Exclusion code: 2. [pmid: 11857015].
Antoniou AC, Pharoah PPD, Smith P, Easton DF. The BOADICEA model of genetic susceptibility to breast and ovarian cancer. Br. J. Cancer. 2004;91(8):1580-1590. Exclusion code: 2. [pmid: 15381934].
Antoniou AC, Rookus M, Andrieu N, et al. Reproductive and hormonal factors, and ovarian cancer risk for BRCA1 and BRCA2 mutation carriers: Results from the International BRCA1/2 carrier cohort study. Cancer Epidemiol. Biomarkers Prev. 2009;18(2):601-610. Exclusion code: 8. [pmid: 19190154].
Appleton S, Watson M, Rush R, et al. A randomised controlled trial of a psychoeducational intervention for women at increased risk of breast cancer. Br. J. Cancer. 2004;90(1):41-47. Exclusion code: 6. [pmid: 14710204].
Arai M, Utsunomiya J, Miki Y. Familial breast and ovarian cancers. Int J Clin Oncol. 2004;9(4):270-282. Exclusion code: 5. [pmid: 15375703].
Arason A, Jonasdottir A, Barkardottir RB, et al. A population study of mutations and LOH at breast cancer gene loci in tumours from sister pairs: two recurrent mutations seem to account for all BRCA1/BRCA2 linked breast cancer in Iceland. J. Med. Genet. 1998;35(6):446-449. Exclusion code: 2. [pmid: 9643283].
Ardern-Jones A, Kenen R, Eeles R. Too much, too soon? Patients and health professionals' views concerning the impact of genetic testing at the time of breast cancer diagnosis in women under the age of 40. Eur. J Cancer Care. 2005;14(3):272-281. Exclusion code: 3. [pmid: 15952973].
Armakolas A, Ladopoulou A, Konstantopoulou I, et al. BRCA2 gene mutations in Greek patients with familial breast cancer. Hum. Mutat. 2002;19(1):81-82. Exclusion code: 3. [pmid: 11754111].
Armel SR, Hitchman K, Millar K, et al. The use of family history questionnaires: An examination of genetic risk estimates and genetic testing eligibility in the non-responder population. J Genet Couns. 2011;20(4):355-364. Exclusion code: 8. [pmid: 21448763].
Armel SR, McCuaig J, Finch A, et al. The effectiveness of family history questionnaires in cancer genetic counseling. J Genet Couns. 2009;18(4):366-378. Exclusion code: 3. [pmid: 19459037].
Armstrong K, Schwartz JS, Randall T, Rubin SC, Weber B. Hormone replacement therapy and life expectancy after prophylactic oophorectomy in women with BRCA1/2 mutations: A decision analysis. J. Clin. Oncol. 2004;22(6):1045-1054. Exclusion code: 6. [pmid: 14981106].
Armstrong K, Weber B, Ubel PA, Peters N, Holmes J, Schwartz JS. Individualized survival curves improve satisfaction with cancer risk management decisions in women with BRCA1/2 mutations. J. Clin. Oncol. 2005;23(36):9319-9328. Exclusion code: 8. [pmid: 16361631].
Arnold LD, Colditz GA. Hysterectomy With oophorectomy: implications for clinical decision making. Arch. Intern. Med. 2011;171(8):768-769. Exclusion code: 5. [pmid: 21518945].
Artioli G, Borgato L, Cappetta A, et al. Overall survival in BRCA-associated ovarian cancer: case-control study of an Italian series. Eur. J. Gynaecol. Oncol. 2010;31(6):658-661. Exclusion code: 3. [pmid: 21319511].
Arver B, Borg Å, Lindblom A. First BRCA1 and BRCA2 gene testing implemented in the health care system of Stockholm. Genet Test. 2001;5(1):1-8. Exclusion code: 6. [pmid: 11336395].
Arver B, Isaksson K, Atterhem H, et al. Bilateral prophylactic mastectomy in Swedish women at high risk of breast cancer: a national survey. Ann. Surg. 2011;253(6):1147-1154. Exclusion code: 3. [pmid: 21587115].
Ashikari RH, Ashikari AY, Kelemen PR, Salzberg CA. Subcutaneous mastectomy and immediate reconstruction for prevention of breast cancer for high-risk patients. Breast Cancer. 2008;15(3):185-191. Exclusion code: 5. [pmid: 18575951].
Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J. Clin. Epidemiol. 2011;64(11):1198-1207. Exclusion code: 4. [pmid: 21463926].
Augustine KM, Bogan TL. Operating a comprehensive high-risk breast cancer management program in a community hospital setting. AWHONN Lifelines. 2004;8(5):434-440. Exclusion code: 5. [pmid: 15560622].
Auranen A, Song H, Waterfall C, et al. Polymorphisms in DNA repair genes and epithelial ovarian cancer risk. Int. J. Cancer. 2005;117(4):611-618. Exclusion code: 3. [pmid: 15924337].
Avard D, Bridge P, Bucci LM, et al. Partnering in oncogenetic research - The INHERIT BRCAs experience: opportunities and challenges. Fam Cancer. 2006;5(1):3-13. Exclusion code: 5. [pmid: 16528603].
Aziz S, Kuperstein G, Rosen B, et al. A genetic epidemiological study of carcinoma of the fallopian tube. Gynecol. Oncol. 2001;80:341-345. Exclusion code: 2. [pmid: 11263928].
Bacha OM, Gregoire J, Grondin K, et al. Effectiveness of risk-reducing salpingo-oophorectomy in preventing ovarian cancer in a high-risk French Canadian population. Int J Gynecol Cancer. 2012;22(6):974-978. Exclusion code: 3. [pmid: 22740003].
Bados A, Gómez-Benito J, Balaguer G. The state-trait anxiety inventory, trait version: Does it really measure anxiety. J. Pers. Assess. 2010;92(6):560-567. Exclusion code: 2. [pmid: 20954057].
Baer HJ, Brawarsky P, Murray MF, Haas JS. Familial risk of cancer and knowledge and use of genetic testing. J. Gen. Intern. Med. 2010;25(7):717-724. Exclusion code: 3. [pmid: 20361271].
Baildam AD. Best surgical prophylaxis--risk-reducing mastectomy for women at high personal risk of breast cancer. Breast. Suppl 2. 2006;15:S21-25. Exclusion code: 5. [pmid: 17382857].
Baile WF, Buckman R, Lenzi R, Glober G, Beale EA, Kudelka AP. SPIKES - A six-step protocol for delivering bad news: Application to the patient with cancer. Oncologist. 2000;5(4):302-311. Exclusion code: 2. [pmid: 10964998].
Bakos AD, Hutson SP, Loud JT, Peters JA, Giusti RM, Greene MH. BRCA mutation-negative women from hereditary breast and ovarian cancer families: a qualitative study of the BRCA-negative experience. Health Expect. 2008;11(3):220-231. Exclusion code: 2. [pmid: 18816319].
Ballinger LL. Hereditary gynecologic cancers: risk assessment, counseling, testing and management. Obstet. Gynecol. Clin. North Am. 2012;39(2):165-181. Exclusion code: 5. [pmid: 22640709].
Balmana J, Diez O, Rubio I, Castiglione M, Group EGW. BRCA in breast cancer: ESMO Clinical Practice Guidelines. Ann. Oncol. Suppl 5. 2010;21:v20-22. Exclusion code: 2. [pmid: 20555082].
Balmaña J, Díez O, Rubio IT, Cardoso F. BRCA in breast cancer: ESMO clinical practice guidelines. Ann. Oncol. 2011;22(SUPPL. 6):vi31-vi34. Exclusion code: 2. [pmid: 21908500].
Balmana J, Sanz J, Bonfill X, et al. Genetic counseling program in familial breast cancer: analysis of its effectiveness, cost and cost-effectiveness ratio. Int. J. Cancer. 2004;112(4):647-652. Exclusion code: 8. [pmid: 15382046].
Bancroft EK, Locke I, Ardern-Jones A, et al. The carrier clinic: an evaluation of a novel clinic dedicated to the follow-up of BRCA1 and BRCA2 carriers--implications for oncogenetics practice. J. Med. Genet. 2010;47(7):486-491. Exclusion code: 3. [pmid: 20472659].
Bandera CA, Muto MG, Schorge JO, Berkowitz RS, Rubin SC, Mok SC. BRCA1 Gene Mutations in Women With Papillary Serous Carcinoma of the Peritoneum. Obstet. Gynecol. 1998;92(4):596-600. Exclusion code: 2. [pmid: 9764635].
Banegas MP, Gail MH, LaCroix A, et al. Evaluating breast cancer risk projections for Hispanic women. Breast Cancer Res. Treat. 2012;132(1):347-353. Exclusion code: 8. [pmid: 22147080].
Barks P, Goldgar C. Hereditary breast and ovarian cancer. JAAPA. 2012;25(3):63-65. Exclusion code: 4. [pmid: 22514962].
Barlow WE, White E, Ballard-Barbash R, et al. Prospective breast cancer risk prediction model for women undergoing screening mammography. J. Natl. Cancer Inst. 2006;98(17):1204-1214. Exclusion code: 8. [pmid: 16954473].
Barlow-Stewart K, Taylor SD, Treloar SA, Stranger M, Otlowski M. Verification of consumers' experiences and perceptions of genetic discrimination and its impact on utilization of genetic testing. Genet Med. 2009;11(3):193-201. Exclusion code: 3. [pmid: 19287242].
Barnes DR, Lee A, Investigators E, kConFab I, Easton DF, Antoniou AC. Evaluation of association methods for analysing modifiers of disease risk in carriers of high-risk mutations. Genet. Epidemiol. 2012;36(3):274-291. Exclusion code: 5. [pmid: 22714938].
Barnes MN, Chhieng DF, Dreher M, et al. Feasibility of performing chemoprevention trials in women at elevated risk of ovarian carcinoma: initial examination of celecoxib as a chemopreventive agent. Gynecol. Oncol. 2005;98(3):376-382. Exclusion code: 8. [pmid: 15993933].
Barrett-Connor E, Mosca L, Collins P, et al. Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N. Engl. J. Med. 2006;355(2):125-137. Exclusion code: 2. [pmid: 16837676].
Barrett-Connor E, Wenger NK, Grady D, et al. Hormone and nonhormone therapy for the maintenance of postmenopausal health: the need for randomized controlled trials of estrogen and raloxifene. J Womens Health. 1998;7(7):839-847. Exclusion code: 2. [pmid: 9785310].
Barsevick AM, Montgomery SV, Ruth K, et al. Intention to communicate BRCA1/BRCA2 genetic test results to the family. Journal of Family Psychology. 2008;22(2):303-312. Exclusion code: 2. [pmid: 18410217].
Barton M, CN W, IL L, EL H, SJ R, JG E. Complications following bilateral prophylactic mastectomy. J Natl Cancer Inst Monogr. 2005;35:61-66. Exclusion code: 3. [pmid: 16287887].
Basham VM, Lipscombe JM, Ward JM, et al. BRCA1 and BRCA2 mutations in a population-based study of male breast cancer. Breast Cancer Res. 2002;4(1). Exclusion code: 3. [pmid: 11879560].
Bates GW, Trajstman SEA, Jackson CA. Internal consistency, test-retest reliability and sex differences on the posttraumatic growth inventory in an Australian sample with trauma. Psychol. Rep. 2004;94(3 I):793-794. Exclusion code: 2. [pmid: 15217029].
Batista LI, Lu KH, Beahm EK, Arun BK, Bodurka DC, Meric-Bernstam F. Coordinated prophylactic surgical management for women with hereditary breast-ovarian cancer syndrome. BMC Cancer. 2008;8:101. Exclusion code: 3. [pmid: 18410690].
Baty BJ, Dudley WN, Musters A, Kinney AY. Uncertainty in BRCA1 cancer susceptibility testing. Am J Med Genet C Semin Med Genet. 2006;142C(4):241-250. Exclusion code: 3. [pmid: 17068806].
Baum M. Ramifications of screening for breast cancer: consent for screening. BMJ. 2006;332(7543):728. Exclusion code: 5. [pmid: 16565139].
Baumanis L, Evans JP, Callanan N, Susswein LR. Telephoned BRCA1/2 genetic test results: prevalence, practice, and patient satisfaction. J Genet Couns. 2009;18(5):447-463. Exclusion code: 8. [pmid: 19462222].
Baxter NN, Goodwin PJ, McLeod RS, Dion R, Devins G, Bombardier C. Reliability and validity of the body image after breast cancer questionnaire. Breast J. 2006;12(3):221-232. Exclusion code: 2. [pmid: 16684320].
Beauchamp TL, Childress JF. Principles of Biomedical Ethics. 4 ed. New York. Oxford University Press. 1994. Exclusion code: 5.
Beck AT, Steer RA, Garbin MG. Psychometric properties of the Beck Depression Inventory: twenty-five years of evaluation. Clin. Psychol. Rev. 1988;8(1):77-100. Exclusion code: 2.
Becker S, Cazares LH, Watson P, et al. Surfaced-enhanced laser desorption/ionization time-of-flight (SELDI-TOF) differentiation of serum protein profiles of BRCA-1 and sporadic breast cancer. Ann. Surg. Oncol. 2004;11(10):907-914. Exclusion code: 8. [pmid: 15383419].
Beckmann MW, Bani MR, Fasching PA, Strick R, Lux MP. Risk and risk assessment for breast cancer: molecular and clinical aspects. Maturitas. 2007;57(1):56-60. Exclusion code: 5. [pmid: 17386982].
Begg CB. On the use of familial aggregation in population-based case probands for calculating penetrance. J. Natl. Cancer Inst. 2002;94(16):1221-1226. Exclusion code: 2. [pmid: 12189225].
Begg CB, Haile RW, Borg A, et al. Variation of breast cancer risk among BRCA1/2 carriers. JAMA. 2008;299(2):194-201. Exclusion code: 3. [pmid: 18182601].
Begum S, Grunfeld EA, Ho-Asjoe M, Farhadi J. An exploration of patient decision-making for autologous breast reconstructive surgery following a mastectomy. Patient Educ. Couns. 2011;84(1):105-110. Exclusion code: 8. [pmid: 20688457].
Belkić KL, Cohen M, Márquez M, et al. Screening of high-risk groups for breast and ovarian cancer in Europe: A focus on the Jewish population. Oncology Reviews. 2010;4(4):233-267. Exclusion code: 5.
Screening for ovarian cancer: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-31998008413. Exclusion code: 5.
Bellcross CA. Evaluation of a cancer genetics referral screening tool. Bellcross, Cecelia A. U Wisconsin. Madison, US. 2008. Exclusion code: 2.
Bellcross CA, Kolor K, Goddard KAB, Coates RJ, Reyes M, Khoury MJ. Awareness and utilization of BRCA1/2 testing among U.S. primary care physicians. Am. J. Prev. Med. 2011;40(1):61-66. Exclusion code: 2. [pmid: 21146769].
Benjamin C, Flynn M, Hallett C, Ellis I, Booth K. The use of the life course paradigm and life course charts to explore referral for family history of breast cancer. Int. J. Nurs. Stud. 2008;45(1):95-109. Exclusion code: 5. [pmid: 17157849].
Bennett IC, Muller J, Cockburn L, et al. Outcomes of multimodality breast screening for women at increased risk of familial breast cancer. World J. Surg. 2010;34(5):979-986. Exclusion code: 4. [pmid: 20108093].
Bennett P, Parsons E, Brain K, Hood K, reTrace Study T. Long-term cohort study of women at intermediate risk of familial breast cancer: experiences of living at risk. Psychooncology. 2010;19(4):390-398. Exclusion code: 3. [pmid: 19514016].
Bennett P, Phelps C, Brain K, Hood K, Gray J. A randomized controlled trial of a brief self-help coping intervention designed to reduce distress when awaiting genetic risk information. J. Psychosom. Res. 2007;63(1):59-64. Exclusion code: 3. [pmid: 17586338].
Bennett P, Wilkinson C, Turner J, et al. The impact of breast cancer genetic risk assessment on intentions to perform cancer surveillance behaviors. J Genet Couns. 2007;16(5):617-623. Exclusion code: 8. [pmid: 17549613].
Benshushan A, Rojansky N, Chaviv M, et al. Climacteric symptoms in women undergoing risk-reducing bilateral salpingo-oophorectomy. Climacteric. 2009;12(5):404-409. Exclusion code: 8. [pmid: 19479488].
Beran TM, Stanton AL, Kwan L, et al. The trajectory of psychological impact in BRCA1/2 genetic testing: does time heal. Ann. Behav. Med. 2008;36(2):107-116. Exclusion code: 3. [pmid: 18787910].
Berek JS, Chalas E, Edelson M, et al. Prophylactic and risk-reducing bilateral salpingo-oophorectomy: recommendations based on risk of ovarian cancer. Obstet. Gynecol. 2010;116(3):733-743. Exclusion code: 5. [pmid: 20733460].
Berg WA, Blume JD, Adams AM, et al. Reasons women at elevated risk of breast cancer refuse breast MR imaging screening: ACRIN 6666. Radiology. 2010;254(1):79-87. Exclusion code: 8. [pmid: 20032143].
Berlin L, Hall FM. More mammography muddle: emotions, politics, science, costs, and polarization. Radiology. 2010;255(2):311-316. Exclusion code: 5. [pmid: 20413746].
Berliner JL, Fay AM, Practice Issues Subcommittee of the National Society of Genetic Counselors' Familial Cancer Risk Counseling Special Interest G. Risk assessment and genetic counseling for hereditary breast and ovarian cancer: recommendations of the National Society of Genetic Counselors. J Genet Couns. 2007;16(3):241-260. Exclusion code: 2. [pmid: 17508274].
Effectiveness of prophylactic surgery, chemoprevention, and intensive surveillance in women carriers of BRCA 1/2 gene mutations (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006001132. Exclusion code: 5.
Bermejo-Perez MJ, Marquez-Calderon S, Llanos-Mendez A. Effectiveness of preventive interventions in BRCA1/2 gene mutation carriers: a systematic review. Int. J. Cancer. 2007;121(2):225-231. Exclusion code: 6. [pmid: 17471565].
Bermejo-Pérez MJ, Márquez-Calderón S, Llanos-Méndez A. Cancer surveillance based on imaging techniques in carriers of BRCA1/2 gene mutations: A systematic review. Br. J. Radiol. 2008;81(963):172-179. Exclusion code: 6. [pmid: 18208856].
Bernholtz S, Laitman Y, Kaufman B, Paluch Shimon S, Friedman E. Cancer risk in Jewish BRCA1 and BRCA2 mutation carriers: effects of oral contraceptive use and parental origin of mutation. Breast Cancer Res. Treat. 2011;129(2):557-563. Exclusion code: 8. [pmid: 21499684].
Berrington de Gonzalez A, Berg CD, Visvanathan K, Robson M. Estimated risk of radiation-induced breast cancer from mammographic screening for young BRCA mutation carriers. J. Natl. Cancer Inst. 2009;101(3):205-209. Exclusion code: 8. [pmid: 19176458].
Berry D, Parmigiani G, Sanchez J, Schildkraut J, Winer E. Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J. Natl. Cancer Inst. 1997;89(3):227-238. Exclusion code: 2. [pmid: 9017003].
Besic N, Cernivc B, De Grève J, et al. BRCA2 gene mutations in Slovenian male breast cancer patients. Genet Test. 2008;12(2):203-209. Exclusion code: 3. [pmid: 18439106].
Biglia N, Defabiani E, Ponzone R, Mariani L, Marenco D, Sismondi P. Management of risk of breast carcinoma in postmenopausal women. Endocr Relat Cancer. 2004;11(1):69-83. Exclusion code: 5. [pmid: 15027886].
Biglia N, Mariani L, Ponzone R, Sismondi P. Oral contraceptives, salpingo-oophorectomy and hormone replacement therapy in BRCA1-2 mutation carriers. Maturitas. 2008;60(2):71-77. Exclusion code: 5. [pmid: 18472232].
Bilimoria MM, Jordan VC. The duration of adjuvant tamoxifen therapy. Cancer Treat. Res. 1998;94:181-193. Exclusion code: 5. [pmid: 9587688].
Bingham R. Hereditary breast and ovarian cancer: research on how women respond to genetic testing. Nurs Womens Health. 2012;16(4):319-324. Exclusion code: 5. [pmid: 22900808].
Bird S. Breast screening and failure to diagnose breast cancer. Aust. Fam. Physician. 2009;38(4):237-238. Exclusion code: 5. [pmid: 19350074].
Bish A, Sutton S, Jacobs C, Levene S, Ramirez A, Hodgson S. No news is (not necessarily) good news: Impact of preliminary results for BRCA1 mutation searches. Genet Med. 2002;4(5):353-358. Exclusion code: 3. [pmid: 12394348].
Biswas S, Berry DA. Determining joint carrier probabilities of cancer-causing genes using Markov chain Monte Carlo methods. Genet. Epidemiol. 2005;29(2):141-154. Exclusion code: 8. [pmid: 16025444].
Biswas S, Tankhiwale N, Blackford A, et al. Assessing the added value of breast tumor markers in genetic risk prediction model BRCAPRO. Breast Cancer Res. Treat. 2012;133(1):347-355. Exclusion code: 4. [pmid: 22270937].
Bjelland I, Dahl AA, Haug TT, Neckelmann D. The validity of the Hospital Anxiety and Depression Scale: An updated literature review. J. Psychosom. Res. 2002;52(2):69-77. Exclusion code: 2. [pmid: 11832252].
Bjorge T, Lie AK, Hovig E, et al. BRCA1 mutations in ovarian cancer and borderline tumours in Norway: a nested case-control study. Br. J. Cancer. 2004;91(10):1829-1834. Exclusion code: 3. [pmid: 15477862].
Bjorvatn C, Eide GE, Hanestad BR, et al. Risk perception, worry and satisfaction related to genetic counseling for hereditary cancer. J Genet Couns. 2007;16(2):211-222. Exclusion code: 3. [pmid: 17279329].
Blecharz P, Szatkowski W, Klimek M, Urbanski K. The prevalence of BRCA1 mutations among families at high-risk of breast and ovarian cancer in province of Malopolska between 2004-2009. Przegl. Lek. 2009;66(12):1046-1048. Exclusion code: 7. [pmid: 20514903].
Bleret V, Cusumano P, Dezfoulian B, et al. Bilateral prophylactic mastectomy for women at very high risk for breast cancer: beyond the technique. Rev. Med. Liege. 2011;66(5-6):250-253. Exclusion code: 7. [pmid: 21826956].
Bleret V, Desreux J, Cusumano P, et al. Primary and secondary prevention for women at high risk for breast cancer. Rev. Med. Liege. 2011;66(5-6):245-249. Exclusion code: 7. [pmid: 21826955].
Bober SL, Hoke LA, Duda RB, Regan MM, Tung NM. Decision-making about tamoxifen in women at high risk for breast cancer: clinical and psychological factors. J. Clin. Oncol. 2004;22(24):4951-4957. Exclusion code: 8. [pmid: 15598980].
Bober SL, Hoke LA, Duda RB, Tung NM. Recommendation recall and satisfaction after attending breast/ovarian cancer risk counseling. J Genet Couns. 2007;16(6):755-762. Exclusion code: 3. [pmid: 17674165].
Boccardo F, Rubagotti A, Amoroso D, et al. Sequential tamoxifen and aminoglutethimide versus tamoxifen alone in the adjuvant treatment of postmenopausal breast cancer patients: results of an Italian cooperative study. J. Clin. Oncol. 2001;19(22):4209-4215. Exclusion code: 3. [pmid: 11709564].
Bodmer D, Ligtenberg MJL, van der Hout AH, et al. Optimal selection for BRCA1 and BRCA2 mutation testing using a combination of ‘easy to apply’ probability models. Br. J. Cancer. 2006;95(6):757-762. Exclusion code: 3. [pmid: 16909138].
Boenink M. Unambiguous test results or individual independence? The role of clients and families in predictive BRCA-testing in the Netherlands compared to the USA. Soc. Sci. Med. 2011;72(11):1793-1801. Exclusion code: 8. [pmid: 20650557].
Bolton K, Chenevix-Trench G, Goh C. Association between BRCA1 and BRCA2 mutations and survival in women with invasive epithelial ovarian cancer. JAMA. 2012;307(4):382-390. Exclusion code: 2. [pmid: 22274685].
Bonadona V, Sinilnikova OM, Chopin S, et al. Contribution of BRCA1 and BRCA2 germ-line mutations to the incidence of breast cancer in young women: results from a prospective population-based study in France. Genes. Chromosomes Cancer. 2005;43(4):404-413. Exclusion code: 3. [pmid: 15887246].
Bondy ML, Newman LA. Assessing breast cancer risk: evolution of the Gail Model. J. Natl. Cancer Inst. 2006;98(17):1172-1173. Exclusion code: 5. [pmid: 16954464].
Bordeleau LJ, Lipa JE, Neligan PC. Management of the BRCA mutation carrier or high-risk patient. Clin. Plast. Surg. 2007;34(1):15-27. abstract v. Exclusion code: 5. [pmid: 17307068].
Borgen PI, Hill AD, Tran KN, et al. Patient regrets after bilateral prophylactic mastectomy. Ann. Surg. Oncol. 1998;5(7):603-606. Exclusion code: 5. [pmid: 9831108].
Borry P, Fryns JP, Schotsmans P, Dierickx K. Attitudes towards carrier testing in minors: A systematic review. Genet. Couns. 2005;16(4):341-352. Exclusion code: 3. [pmid: 16440876].
Borry P, Stultiens L, Nys H, Dierickx K. Attitudes towards predictive genetic testing in minors for familial breast cancer: a systematic review. Crit. Rev. Oncol. Hematol. 2007;64(3):173-181. Exclusion code: 3. [pmid: 17553690].
Bosetti C, Negri E, Trichopoulos D, et al. Long-term effects of oral contraceptives on ovarian cancer risk. Int. J. Cancer. 2002;102(3):262-265. Exclusion code: 3. [pmid: 12397647].
Bosse K, Rhiem K, Wappenschmidt B, et al. Screening for ovarian cancer by transvaginal ultrasound and serum CA125 measurement in women with a familial predisposition: a prospective cohort study. Gynecol. Oncol. 2006;103(3):1077-1082. Exclusion code: 3. [pmid: 16904167].
Boughey JC, Hartmann LC, Anderson SS, et al. Evaluation of the Tyrer-Cuzick (International Breast Cancer Intervention Study) model for breast cancer risk prediction in women with atypical hyperplasia. J. Clin. Oncol. 2010;28(22):3591-3596. Exclusion code: 2. [pmid: 20606088].
Bowen DJ, Bourcier E, Press N, Lewis FM, Burke W. Effects of individual and family functioning on interest in genetic testing. Community Genet. 2004;7(1):25-32. Exclusion code: 8. [pmid: 15475668].
Bowen DJ, Harris J, Jorgensen CM, Myers MF, Kuniyuki A. Socioeconomic influences on the effects of a genetic testing direct-to-consumer marketing campaign. Public Health Genomics. 2010;13(3):131-142. Exclusion code: 2. [pmid: 19641293].
Bowen DJ, Powers D. Effects of a mail and telephone intervention on breast health behaviors. Health Educ. Behav. 2010;37(4):479-489. Exclusion code: 3. [pmid: 20157016].
Bowen DJ, Singal R, Eng E, Crystal S, Burke W. Jewish identity and intentions to obtain breast cancer screening. Cultur Divers Ethni Minor Psychol. 2003;9(1):79-87. Exclusion code: 4. [pmid: 12647327].
Boyd J, Sonoda Y, Federici MG, et al. Clinicopathologic features of BRCA-linked and sporadic ovarian cancer. JAMA. 2000;283(17):2260-2265. Exclusion code: 2. [pmid: 10807385].
Boyle P, Mezzetti M, La Vecchia C, Franceschi S, Decarli A, Robertson C. Contribution of three components to individual cancer risk predicting breast cancer risk in Italy. Eur. J. Cancer Prev. 2004;13(3):183-191. Exclusion code: 2. [pmid: 15167217].
Bradbury AR, Ibe CN, Dignam JJ, et al. Uptake and timing of bilateral prophylactic salpingo-oophorectomy among BRCA1 and BRCA2 mutation carriers. Genet Med. 2008;10(3):161-166. Exclusion code: 3. [pmid: 18344704].
Bradbury AR, Olopade OI. Genetic susceptibility to breast cancer. Rev Endocr Metab Disord. 2007;8(3):255-267. Exclusion code: 5. [pmid: 17508290].
Bradbury AR, Patrick-Miller L, Egleston B, et al. Parent opinions regarding the genetic testing of minors for BRCA1/2. J. Clin. Oncol. 2010;28(21):3498-3505. Exclusion code: 2. [pmid: 20567018].
Bradbury AR, Patrick-Miller L, Pawlowski K, et al. Learning of your parent's BRCA mutation during adolescence or early adulthood: A study of offspring experiences. Psychooncology. 2009;18(2):200-208. Exclusion code: 2. [pmid: 18702049].
Brain A. Randomized trial of a specialist genetic assessment service for familial breast cancer. J. Natl. Cancer Inst. 2000;92:1345-1351. Exclusion code: 8. [pmid: 10944557].
Braithwaite D, Emery J, Walter F, Prevost AT, Sutton S. Psychological impact of genetic counseling for familial cancer: A systematic review and meta-analysis. J. Natl. Cancer Inst. 2004;96(2):122-133. Exclusion code: 6. [pmid: 14734702].
Braithwaite D, Emery J, Walter F, Prevost AT, Sutton S. Psychological impact of genetic counseling for familial cancer: A systematic review and meta-analysis. Fam Cancer. 2006;5(1):61-75. Exclusion code: 2. [pmid: 16528610].
Braithwaite RS, Chlebowski RT, Lau J, George S, Hess R, Col NF. Meta-analysis of vascular and neoplastic events associated with tamoxifen. J. Gen. Intern. Med. 2003;18(11):937-947. Exclusion code: 2. [pmid: 14687281].
Brandenburg DL, Matthews AK, Johnson TP, Hughes TL. Breast cancer risk and screening: a comparison of lesbian and heterosexual women. Women Health. 2007;45(4):109-130. Exclusion code: 3. [pmid: 18032170].
Brandt A, Lorenzo Bermejo J, Sundquist J, Hemminki K. Breast cancer risk in women who fulfill high-risk criteria: at what age should surveillance start. Breast Cancer Res. Treat. 2010;121(1):133-141. Exclusion code: 8. [pmid: 19641988].
Brehaut JC, O'Connor AM, Wood TJ, et al. Validation of a decision regret scale. Med. Decis. Making. 2003;23(4):281-292. Exclusion code: 2. [pmid: 12926578].
Brekelmans CT, Seynaeve C, Bartels CC, et al. Effectiveness of breast cancer surveillance in BRCA1/2 gene mutation carries and women with high familial risk. J. Clin. Oncol. 2001;19(4):924-930. Exclusion code: 8. [pmid: 11181654].
Brekelmans CTM, Seynaeve C. Can bilateral prophylactic salpingo-oophorectomy reduce cancer mortality in carriers of a BRCA1 or BRCA2 mutation. Lancet Oncol. 2006;7(3):191-193. Exclusion code: 5. [pmid: 16510328].
Brekelmans CTM, Tilanus-Linthorst MMA, Seynaeve C, et al. Tumour characteristics, survival and prognostic factors of hereditary breast cancer from BRCA2-, BRCA1- and non-BRCA1/2 families as compared to sporadic breast cancer cases. Eur. J. Cancer. 2007;43(5):867-876. Exclusion code: 3. [pmid: 17307353].
Bresser PJC, Seynaeve C, Van Gool AR, et al. Satisfaction with prophylactic mastectomy and breast reconstruction in genetically predisposed women. Plast. Reconstr. Surg. 2006;117(6):1675-1682. discussion 1683-1674. Exclusion code: 3. [pmid: 16651934].
Bresser PJC, Seynaeve C, Van Gool AR, et al. The course of distress in women at increased risk of breast and ovarian cancer due to an (identified) genetic susceptibility who opt for prophylactic mastectomy and/or salpingo-oophorectomy. Eur. J. Cancer. 2007;43(1):95-103. Exclusion code: 3. [pmid: 17095208].
Bresser PJC, Van Gool AR, Seynaeve C, et al. Who is prone to high levels of distress after prophylactic mastectomy and/or salpingo-ovariectomy. Ann. Oncol. 2007;18(10):1641-1645. Exclusion code: 3. [pmid: 17660493].
Briasoulis E, Ziogas D, Fatouros M. Prophylactic surgery in the complex decision-making management of BRCA mutation carriers. Ann. Surg. Oncol. 2008;15(6):1788-1790. Exclusion code: 5. [pmid: 18197455].
Brierley KL, Campfield D, Ducaine W, et al. Errors in delivery of cancer genetics services: Implications for practice. Conn. Med. 2010;74(7):413-423. Exclusion code: 8. [pmid: 20806621].
Brinton JT, Barke LD, Freivogel ME, Jackson S, O'Donnell CI, Glueck DH. Breast cancer risk assessment in 64,659 women at a single high-volume mammography clinic. Acad. Radiol. 2012;19(1):95-99. Exclusion code: 4. [pmid: 22054804].
Brohet RM, Goldgar DE, Easton DF, et al. Oral contraceptives and breast cancer risk in the international BRCA1/2 carrier cohort study: a report from EMBRACE, GENEPSO, GEO-HEBON, and the IBCCS Collaborating Group. J. Clin. Oncol. 2007;25(25):3831-3836. Exclusion code: 8. [pmid: 17635951].
Brooks GA, Stopfer JE, Erlichman J, Davidson R, Nathanson KL, Domchek SM. Childhood cancer in families with and without BRCA1 or BRCA2 mutations ascertained at a high-risk breast cancer clinic. Cancer Biol Ther. 2006;5(9):1098-1102. Exclusion code: 3. [pmid: 16931905].
Brower V. FDA to regulate direct-to-consumer genetic tests. J. Natl. Cancer Inst. 2010;102(21):1610-1612. 1617. Exclusion code: 5. [pmid: 20966430].
Brower V. US court reverses gene patent ruling for BRCA1 and BRCA2. Lancet Oncol. 2011;12(9):835. Exclusion code: 2. [pmid: 21984989].
Brown DL, Andreotti RF, Lee SI, et al. ACR Appropriateness Criteria: ovarian cancer screening. 2009. http://www.guideline.gov. 4/4/2012. Exclusion code: 2.
Brown J, Buckley D, Coulthard A, et al. Magnetic resonance imaging screening in women at genetic risk of breast cancer: Imaging and analysis protocol for the UK multicentre study. Magn. Reson. Imaging. 2000;18(7):765-776. Exclusion code: 5. [pmid: 11027869].
Brown J, Coulthard A, Dixon AK, et al. Protocol for a national multi-centre study of magnetic resonance imaging screening in women at genetic risk of breast cancer. Breast. 2000;9(2):78-82. Exclusion code: 5. [pmid: 14731703].
Brown J, Coulthard A, Dixon AK, et al. Rationale for a national multi-centre study of magnetic resonance imaging screening in women at genetic risk of breast cancer. Breast. 2000;9(2):72-77. Exclusion code: 5. [pmid: 14731702].
Brown KL, Moglia DM, Grumet S. Genetic counseling for breast cancer risk: general concepts, challenging themes and future directions. Breast Dis. 2007;27:69-96. Exclusion code: 5. [pmid: 17917141].
Brown P. Risk assessment: controversies and management of moderate- to high-risk individuals. Breast J. Suppl 1. 2005;11:S11-19. Exclusion code: 5. [pmid: 15725110].
Brunet J. Hereditary breast cancer and genetic counseling in young women. Breast Cancer Res. Treat. Suppl 1. 2010;123:7-9. Exclusion code: 5. [pmid: 20711663].
Bruno M, Digennaro M, Tommasi S, et al. Attitude towards genetic testing for breast cancer susceptibility: a comparison of affected and unaffected women. Eur. J Cancer Care. 2010;19(3):360-368. Exclusion code: 8. [pmid: 19912305].
Bruno M, Tommasi S, Stea B, et al. Awareness of breast cancer genetics and interest in predictive genetic testing: a survey of a southern Italian population. Ann. Oncol. Suppl 1. 2004;15:I48-I54. Exclusion code: 8. [pmid: 15280188].
Brunsvold AN, Wung SF, Merkle CJ. BRCA1 genetic mutation and its link to ovarian cancer: implications for advanced practice nurses. J. Am. Acad. Nurse Pract. 2005;17(12):518-526. Exclusion code: 5. [pmid: 16293160].
Buckmaster AM, Gallagher P. Experiences of and perspectives on genetic testing for breast/ovarian cancer in and outside of the customary clinical setting. Psychol Health. 2010;25(9):1041-1059. Exclusion code: 8. [pmid: 20204956].
Budroni M, Cesaraccio R, Coviello V, et al. Role of BRCA2 mutation status on overall survival among breast cancer patients from Sardinia. BMC Cancer. 2009;9:62. Exclusion code: 3. [pmid: 19232099].
Bulletins ACoP. Hereditary breast and ovarian cancer syndrome. Gynecol. Oncol. 2009;113(1):6-11. Exclusion code: 5. [pmid: 19309638].
Burke W, Culver J, Pinsky L, et al. Genetic assessment of breast cancer risk in primary care practice. Am J Med Genet A. 2009;149A(3):349-356. Exclusion code: 5. [pmid: 19208375].
Burke W, Daly M, Garber JE, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. II. BRCA1 and BRCA2, Cancer Genetics Study Consortium. JAMA. 1997;277(12):997-1003. Exclusion code: 2. [pmid: 9091675].
Burke W, Kahn MJ, Garber JE, Collins FS. “First do no harm” also applies to cancer susceptibility testing. Cancer J. Sci. Am. 1996;2(5):250-252. Exclusion code: 5. [pmid: 9166540].
Burki N. Hereditary breast and ovarian cancer - indications for genetic testing, counseling and options for mutation carriers. Ther. Umsch. 2010;67(7):359-366. Exclusion code: 7. [pmid: 20577964].
Burness ML, Olopade OI. Is screening with magnetic resonance imaging in BRCA mutation carriers a safe and effective alternative to prophylactic mastectomy. J. Clin. Oncol. 2011;29(13):1652-1654. Exclusion code: 5. [pmid: 21444875].
Burwinkel B, Wirtenberger M, Klaes R, et al. Association of NCOA3 polymorphisms with breast cancer risk. Clin. Cancer Res. 2005;11(6):2169-2174. Exclusion code: 3. [pmid: 15788663].
Butow P, Meiser B, Price M, et al. Psychological Morbidity in Women at Increased Risk of Developing Breast Cancer: A Controlled Study. Psychooncology. 2005;14(3):196-203. Exclusion code: 4. [pmid: 15386776].
Butow PN, Lobb EA. Analyzing the process and content of genetic counseling in familial breast cancer consultations. J Genet Couns. 2004;13(5):403-424. Exclusion code: 4. [pmid: 15604639].
Butow PN, Lobb EA, Meiser B, Barratt A, Tucker KM. Psychological outcomes and risk perception after genetic testing and counselling in breast cancer: a systematic review. MJA. 2003;178:77-81. Exclusion code: 6. [pmid: 12526728].
Buys SS, Partridge E, Black A, et al. Effect of screening on ovarian cancer mortality: The Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening randomized controlled trial. JAMA. 2011;305(22):2295-2302. Exclusion code: 3. [pmid: 21642681].
Bylund CL, Fisher CL, Brashers D, et al. Sources of uncertainty about daughters' breast cancer risk that emerge during genetic counseling consultations. J Genet Couns. 2012;21(2):292-304. Exclusion code: 2. [pmid: 21833819].
Byrd LM, Shenton A, Maher ER, et al. Better life expectancy in women with BRCA2 compared with BRCA1 mutations is attributable to lower frequency and later onset of ovarian cancer. Cancer Epidemiol. Biomarkers Prev. 2008;17(6):1535-1542. Exclusion code: 3. [pmid: 18559571].
Cabrera E, Blanco I, Yague C, Zabalegui A. The impact of genetic counseling on knowledge and emotional responses in Spanish population with family history of breast cancer. Patient Educ. Couns. 2010;78(3):382-388. Exclusion code: 3. [pmid: 19948386].
Calderon-Margalit R, Paltiel O. Prevention of breast cancer in women who carry BRCA1 or BRCA2 mutations: a critical review of the literature. Int. J. Cancer. 2004;112(3):357-364. Exclusion code: 2. [pmid: 15382059].
Calzone K, Wattendorf D, Dunn BK. The application of genetics and genomics to cancer prevention. Semin. Oncol. 2010;37(4):407-418. Exclusion code: 5. [pmid: 20816510].
Calzone KA, Prindiville SA, Jourkiv O, et al. Randomized comparison of group versus individual genetic education and counseling for familial breast and/or ovarian cancer. J. Clin. Oncol. 2005;23(15):3455-3464. Exclusion code: 3. [pmid: 15908654].
Cameron LD, Reeve J. Risk perceptions, worry, and attitudes about genetic testing for breast cancer susceptibility. Psychol Health. 2006;21(2):211-230. Exclusion code: 4. [pmid: 21985118].
Campfield Bonadies D, Moyer A, Matloff ET. What I wish I'd known before surgery: BRCA carriers' perspectives after bilateral salipingo-oophorectomy. Fam Cancer. 2011;10(1):79-85. Exclusion code: 3. [pmid: 20852945].
Cao MZ. Analysis of BRCA1 mutations among familial and/or breast cancer praecox patients in the east of Shandong in China. Prog Mod Biomed. 2009;9:1028-1030. Exclusion code: 3.
Cappelli M, Verma S, Korneluk Y, et al. Psychological and genetic counseling implications for adolescent daughters of mothers with breast cancer. Clin. Genet. 2005;67(6):481-491. Exclusion code: 3. [pmid: 15857415].
Carcangiu ML, Peissel B, Pasini B, Spatti G, Radice P, Manoukian S. Incidental carcinomas in prophylactic specimens in BRCA1 and BRCA2 germ-line mutation carriers, with emphasis on fallopian tube lesions: report of 6 cases and review of the literature. Am. J. Surg. Pathol. 2006;30(10):1222-1230. Exclusion code: 8. [pmid: 17001151].
Carlson KJ. Screening for ovarian cancer. 2011. http://www.uptodate.com/contents/screening-for-ovarian-cancer?source=see_link&anchor=H3#H17. 09 Nov, 2011. Exclusion code: 2.
Carroll JC, Cremin C, Allanson J, et al. Hereditary breast and ovarian cancers. Can. Fam. Physician. 2008;54(12):1691-1692. Exclusion code: 5. [pmid: 19074707].
Carroll JC, Heisey R, Warner E. Family history and breast cancer. CMAJ. 2012;184(12):1391. Exclusion code: 5. [pmid: 22291177].
Carroll JC, Wilson BJ, Allanson J, et al. GenetiKit: A randomized controlled trial to enhance delivery of genetics services by family physicians. Fam. Pract. 2011;28(6):615-623. Exclusion code: 2. [pmid: 21746696].
Carroll PA, Nolan C, Clarke R, et al. Surgical management of an Irish cohort of BRCA-mutation carriers. Breast. 2011;20(5):419-423. Exclusion code: 8. [pmid: 21570850].
Carter RE. Psychological evaluation a consideration in the ethics of genetic testing for breast cancer. Psychiatric Annals. 2004;34(2):119-124. Exclusion code: 5.
Caruso A, Vigna C, Bigazzi V, et al. Factors associated with an individuals' decision to withdraw from genetic counseling for BRCA1 and BRCA2 genes mutations: are personality traits involved. Fam Cancer. 2011;10(3):581-589. Exclusion code: 8. [pmid: 21604195].
Caruso A, Vigna C, Maggi G, Sega FM, Cognetti F, Savarese A. The withdrawal from oncogenetic counselling and testing for hereditary and familial breast and ovarian cancer. A descriptive study of an Italian sample. J. Exp. Clin. Cancer Res. 2008;27:75. Exclusion code: 3. [pmid: 19025627].
Caruso A, Vigna C, Marozzo B, et al. Subjective versus objective risk in genetic counseling for hereditary breast and/or ovarian cancers. J. Exp. Clin. Cancer Res. 2009;28:157. Exclusion code: 3. [pmid: 20025726].
Carver CS, Scheier MF, Weintraub JK. Assessing Coping Strategies: A Theoretically Based Approach. J. Pers. Soc. Psychol. 1989;56(2):267-283. Exclusion code: 2. [pmid: 2926629].
Casey WJ 3rd, Rebecca AM, Andres LA, et al. Safety and efficacy of perforator flap breast reconstruction with combined intraabdominal procedures. Ann. Plast. Surg. 2010;64(2):144-150. Exclusion code: 3. [pmid: 20098096].
Cauley JA, Norton L, Lippman ME, et al. Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-Year results from the MORE trial. Breast Cancer Res. Treat. 2001;65(2):125-134. Exclusion code: 5. [pmid: 11261828].
Cavallone L, Arcand SL, Maugard CM, et al. Comprehensive BRCA1 and BRCA2 mutation analyses and review of French Canadian families with at least three cases of breast cancer. Fam Cancer. 2010;9(4):507-517. Exclusion code: 3. [pmid: 20694749].
Centers for Disease Control and Prevention. Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing -- Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. MMWR. 2004;53(27):603-606. Exclusion code: 2. [pmid: 15254451].
Centers for Disease Control and Prevention. Breast Cancer Statistics 2010. http://www.cdc.gov/cancer/breast/statistics/. 10 October 2012. 2012. Exclusion code: 2.
Centers for Disease Control and Prevention. Breast Cancer Risk Factors. 2011. http://www.cdc.gov/cancer/breast/basic_info/risk_factors.htm. 09 Nov, 2011. Exclusion code: 2.
Centers for Disease Control and Prevention. Gynecologic Cancers: Ovarian Cancer. 2011. http://www.cdc.gov/cancer/ovarian/index.htm. 09 Nov, 2011. Exclusion code: 2.
What is the impact of genetic counselling in women at increased risk of developing hereditary breast cancer: a meta-analytic review (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-10901. Exclusion code: 5.
Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-20229. Exclusion code: 5.
A systematic review of the effectiveness of magnetic resonance imaging (MRI) as an addition to mammography and ultrasound in screening young women at high risk of breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-19491. Exclusion code: 5.
A systematic review of perceived risks, psychological and behavioral impacts of genetic testing (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-19593. Exclusion code: 5.
Psychological outcomes and risk perception after genetic testing and counselling in breast cancer: a systematic review (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-13579. Exclusion code: 6.
Psychological consequences of predictive genetic testing: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-13585. Exclusion code: 6.
Oral contraceptive use and breast or ovarian cancer risk in BRCA1/2 carriers: a meta-analysis (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-26006. Exclusion code: 2.
Meta-analysis of risk reduction estimates associated with risk-reducing salpingo-oophorectomy in BRCA1 or BRCA2 mutation carriers (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-21122. Exclusion code: 3.
Magnetic resonance imaging of the breast in screening women considered to be at high genetic risk of breast cancer (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-15169. Exclusion code: 2.
Interventions to improve risk communication in clinical genetics: systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-21188. Exclusion code: 8.
Impact of gene expression profiling tests on breast cancer outcomes (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-15868. Exclusion code: 5.
Diagnostic accuracy of methods for the detection of BRCA1 and BRCA2 mutations: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-17808. Exclusion code: 8.
Cancer surveillance based on imaging techniques in carriers of BRCA1/2 gene mutations: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-20623. Exclusion code: 5.
Body image after bilateral prophylactic mastectomy: an integrative literature review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-18650. Exclusion code: 5.
Comparative effectiveness of screening and prevention strategies among BRCA1/2-affected mutation carriers (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22011000379. Exclusion code: 5.
Evaluation of a surveillance programme for women with a family history of breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22009101998. Exclusion code: 5.
Genetic nurse counsellors can be an acceptable and cost-effective alternative to clinical geneticists for breast cancer risk genetic counselling: evidence from two parallel randomised controlled equivalence trials (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22006001753. Exclusion code: 5.
Randomized trial of a specialist genetic assessment service for familial breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22000001369. Exclusion code: 5.
Prevention with tamoxifen or other hormones versus prophylactic surgery in BRCA1/2-positive women: a decision analysis (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22000000354. Exclusion code: 5.
Systematic review of management options for women with a hereditary predisposition to ovarian cancer (Provisional abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-12502. Exclusion code: 5.
Nonpharmacologic strategies for managing common chemotherapy adverse effects: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=dare&AN=00125498-100000000-21072. Exclusion code: 3.
Benefits and costs of screening Ashkenazi Jewish women for BRCA1 and BRCA2 (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-21999000349. Exclusion code: 5.
Magnetic Resonance imaging for breast cancer diagnostics. Systematic review and economic assessment (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010001463. Exclusion code: 5.
Challberg J, Ashcroft L, Lalloo F, et al. Menopausal symptoms and bone health in women undertaking risk reducing bilateral salpingo-oophorectomy: significant bone health issues in those not taking HRT. Br. J. Cancer. 2011;105(1):22-27. Exclusion code: 3. [pmid: 21654687].
Chan K, Morris GJ. Chemoprevention of breast cancer for women at high risk. Semin. Oncol. 2006;33(6):642-646. Exclusion code: 3. [pmid: 17145342].
Chang J, Yang WT, Choo HF. Mammography in Asian patients with BRCA1 mutations. Lancet. 1999;353(9169):2070-2071. Exclusion code: 2. [pmid: 10376643].
Chan-Smutko G, Patel D, Shannon KM, Ryan PD. Professional challenges in cancer genetic testing: who is the patient. Oncologist. 2008;13(3):232-238. Exclusion code: 5. [pmid: 18378533].
Chapman JS, Powell CB, McLennan J, et al. Surveillance of survivors: follow-up after risk-reducing salpingo-oophorectomy in BRCA 1/2 mutation carriers. Gynecol. Oncol. 2011;122(2):339-343. Exclusion code: 8. [pmid: 21531449].
Chappuis PO. Breast cancer screening different from that used for the general population: who is concerned and with which approach?. Rev Med Suisse. 2006;2(66):1296-1298. 1301. 1292. 1304. 1295. Exclusion code: 7. [pmid: 16775990].
Charles S, Kessler L, Stopfer JE, Domchek S, Halbert CH. Satisfaction with genetic counseling for BRCA1 and BRCA2 mutations among African American women. Patient Educ. Couns. 2006;63(1-2):196-204. Exclusion code: 8. [pmid: 16533589].
Chart PL, Franssen E. Management of women at increased risk for breast cancer: Preliminary results from a new program. Can. Med. Assoc. J. 1997;157:1235-1242. Exclusion code: 3. [pmid: 9361645].
Chen J, Pee D, Ayyagari R, et al. Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J. Natl. Cancer Inst. 2006;98(17):1215-1226. Exclusion code: 8. [pmid: 16954474].
Chen L, Hsu L, Malone K. A frailty-model-based approach to estimating the age-dependent penetrance function of candidate genes using population-based case-control study designs: an application to data on the BRCA1 gene. Biometrics. 2009;65(4):1105-1114. Exclusion code: 5. [pmid: 19210733].
Chen Z, Arendell L, Aickin M, et al. Hip bone density predicts breast cancer risk independently of Gail score: results from the Women's Health Initiative. Cancer. 2008;113(5):907-915. Exclusion code: 5. [pmid: 18666209].
Cherbal F, Salhi N, Bakour R, Adane S, Boualga K, Maillet P. BRCA1 and BRCA2 unclassified variants and missense polymorphisms in Algerian breast/ovarian cancer families. Dis. Markers. 2012;32(6):343-353. Exclusion code: 4. [pmid: 22684231].
Chereau E, Uzan C, Balleyguier C, et al. Characteristics, treatment, and outcome of breast cancers diagnosed in BRCA1 and BRCA2 gene mutation carriers in intensive screening programs including magnetic resonance imaging. Clin Breast Cancer. 2010;10(2):113-118. Exclusion code: 8. [pmid: 20299317].
Cheung EL, Olson AD, Yu TM, Han PZ, Beattie MS. Communication of BRCA results and family testing in 1,103 high-risk women. Cancer Epidemiol. Biomarkers Prev. 2010;19(9):2211-2219. Exclusion code: 8. [pmid: 20699375].
Chlebowski RT, Anderson GL, Lane DS, et al. Predicting risk of breast cancer in postmenopausal women by hormone receptor status. J. Natl. Cancer Inst. 2007;99(22):1695-1705. Exclusion code: 2. [pmid: 18000216].
Chun J, Schnabel F, Ogunyemi O. Assessing a Bayesian risk prediction model in a high-risk breast cancer population. AMIA Annu Symp Proc. Annual Symposium Proceedings/AMIA Symposium. 2007:913. Exclusion code: 8. [pmid: 18694013].
Ciernikova S, Tomka M, Kovac M, Stevurkova V, Zajac V. Ashkenazi founder BRCA1/BRCA2 mutations in Slovak hereditary breast and/or ovarian cancer families. Neoplasma. 2006;53(2):97-102. Exclusion code: 3. [pmid: 16575464].
Cink TM. Breast cancer screening update and evaluation of the high-risk patient. S. D. J. Med. Spec No. 2010:23-30. Exclusion code: 2. [pmid: 20401983].
Cipollini G, Tommasi S, Paradiso A, et al. Genetic alterations in hereditary breast cancer. Ann. Oncol. Suppl 1. 2004;15:I7-I13. Exclusion code: 8. [pmid: 15280181].
Claes E, Evers-Kiebooms G, Boogaerts A, Decruyenaere M, Denayer L, Legius E. Diagnostic genetic testing for hereditary breast and ovarian cancer in cancer patients: women's looking back on the pre-test period and a psychological evaluation. Genet Test. 2004;8(1):13-21. Exclusion code: 3. [pmid: 15140370].
Claes E, Evers-Kiebooms G, Decruyenaere M, et al. Surveillance behavior and prophylactic surgery after predictive testing for hereditary breast/ovarian cancer. Behav. Med. 2005;31(3):93-105. Exclusion code: 8. [pmid: 16252621].
Claes E, Evers-Kiebooms G, Denayer L, et al. Predictive genetic testing for hereditary breast and ovarian cancer: psychological distress and illness representations 1 year following disclosure. J Genet Couns. 2005;14(5):349-363. Exclusion code: 8. [pmid: 16195942].
Clamp A, Danson S, Clemons M. Hormonal and genetic risk factors for breast cancer. Surgeon. 2003;1(1):23-31. Exclusion code: 5. [pmid: 15568421].
Clarke S, Butler K, Esplen MJ. The phases of disclosing BRCA1/2 genetic information to offspring. Psychooncology. 2008;17(8):797-803. Exclusion code: 2. [pmid: 18646247].
Claus EB, Risch H, Thompson WD. Genetic analysis of breast cancer in the cancer and steroid hormone study. Am. J. Hum. Genet. 1991;48:232-242. Exclusion code: 2. [pmid: 1990835].
Clements A, Henderson BJ, Tyndel S, et al. Diagnosed with breast cancer while on a family history screening programme: an exploratory qualitative study. Eur. J Cancer Care. 2008;17(3):245-252. Exclusion code: 3. [pmid: 18419627].
Cnota W, Sodowski K, Olesiak-Andryszczak M, Pilch-Kowalczyk M. Program for early detection of ovarian cancer for women as prophylaxis provided at a municipal hospital. Wiad. Lek. Suppl 1. 2004;57:43-47. Exclusion code: 7. [pmid: 15884203].
Cohen JV, Chiel L, Boghossian L, et al. Non-cancer endpoints in BRCA1/2 carriers after risk-reducing salpingo-oophorectomy. Fam Cancer. 2012;11(1):69-75. Exclusion code: 8. [pmid: 21898151].
Cohen M. Breast cancer early detection, health beliefs, and cancer worries in randomly selected women with and without a family history of breast cancer. Psychooncology. 2006;15(10):873-883. Exclusion code: 4. [pmid: 16374894].
Col NF, Chlebowski RT. Risks and benefits of therapy with menopausal hormones versus selective estrogen-receptor modulators in peri- and postmenopausal women at increased breast cancer risk. Menopause. 2008;15(4 Suppl):804-809. Exclusion code: 5. [pmid: 18596602].
Colditz GA, Rosner B. Cumulative risk of breast cancer to age 70 years according to risk factor status: Data from the nurses' health study. Am. J. Epidemiol. 2000;152(10):950-964. Exclusion code: 2. [pmid: 11092437].
Colditz GA, Rosner BA, Chen WY, Holmes MD, Hankinson SE. Risk factors for breast cancer according to estrogen and progesterone receptor status. J. Natl. Cancer Inst. 2004;96(3):218-228. Exclusion code: 2. [pmid: 14759989].
Colditz GA, Willett WC, Hunter DJ. Family history, age, and risk of breast cancer. Prospective data from the Nurses' Health Study. JAMA. 1993;270(3):338-343. Exclusion code: 2. [pmid: 8123079].
Colditz GA, Willett WC, Stampfer MJ. Menopause and the risk of coronary heart disease in women. N. Engl. J. Med. 1987;316(18):1105-1110. Exclusion code: 6. [pmid: 3574358].
Cole DEC. New genetic technologies: clinical application and ethical issues in familial ovarian cancer. Clin Invest Med. 2004;27(1):16-18. Exclusion code: 5. [pmid: 15061581].
Collaborative Group on Hormonal Factors in Breast Cancer. Familial breast cancer: collaborative reanalysis of individual data from 52 epidemiological studies including 58,209 women with breast cancer and 101,986 women without the disease. Lancet. 2001;358(9291):1389-1399. Exclusion code: 6. [pmid: 11705483].
Collier R. Young women with breast cancer genes face tough choices. CMAJ. 2012;184(8):E401-402. Exclusion code: 5. [pmid: 22508975].
Comen E, Balistreri L, Gonen M, et al. Discriminatory accuracy and potential clinical utility of genomic profiling for breast cancer risk in BRCA-negative women. Breast Cancer Res. Treat. 2011;127(2):479-487. Exclusion code: 4. [pmid: 20957429].
Condello C, Gesuita R, Pensabene M, et al. Distress and family functioning in oncogenetic counselling for hereditary and familial breast and/or ovarian cancers. J Genet Couns. 2007;16(5):625-634. Exclusion code: 2. [pmid: 17701329].
Contant C, van Wersch A, Menke-Pluymers M, Wai R, Eggermont A, van Geel A. Satisfaction and prosthesis related complaints in women with immediate breast reconstruction following prophylactic and oncological mastectomy. Psychology, Health & Medicine. 2004;9(1):71-84. Exclusion code: 3.
Contant CM, Menke-Pluijmers MB, Seynaeve C, et al. Clinical experience of prophylactic mastectomy followed by immediate breast reconstruction in women at hereditary risk of breast cancer (HB(O)C) or a proven BRCA1 and BRCA2 germ-line mutation. Eur. J. Surg. Oncol. 2002;28(6):627-632. Exclusion code: 3. [pmid: 12359199].
Contegiacomo A, Pensabene M, Capuano I, et al. An oncologist-based model of cancer genetic counselling for hereditary breast and ovarian cancer. Ann. Oncol. 2004;15(5):726-732. Exclusion code: 3. [pmid: 15111339].
Cook NR, Paynter NP. Genetics and breast cancer risk prediction--are we there yet. J. Natl. Cancer Inst. 2010;102(21):1605-1606. Exclusion code: 5. [pmid: 20956781].
Cook-Deegan R, DeRienzo C, Carbone J, Chandrasekharan S, Heaney C, Conover C. Impact of gene patents and licensing practices on access to genetic testing for inherited susceptibility to cancer: comparing breast and ovarian cancers with colon cancers. Genet Med. 2010;12(4 Suppl):S15-38. Exclusion code: 2. [pmid: 20393305].
Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J. Natl. Cancer Inst. 1999;91(18):1541-1548. Exclusion code: 2. [pmid: 10491430].
Couch FJ. Genetic epidemiology of BRCA1. Cancer Biol Ther. 2004;3(6):509-514. Exclusion code: 5. [pmid: 15254414].
Coulson AS, Glasspool DW, Fox J, Emery J. RAGs: A novel approach to computerized genetic risk assessment and decision support from pedigrees. Methods Inf. Med. 2001;40(4):315-322. Exclusion code: 2. [pmid: 11552344].
Courtillot C, Touraine P. Management of families at high risk for hereditary breast-ovarian cancers: the endocrinologist's point of view. Ann. Endocrinol. (Paris). 2008;69(3):193-200. Exclusion code: 7. [pmid: 18294609].
Cox DG, Hankinson SE, Hunter DJ. The erbB2/HER2/neu receptor polymorphism Ile655Val and breast cancer risk. Patient Educ. Couns. 2005;15(7):447-450. Exclusion code: 8. [pmid: 15970791].
Cox SL, Zlot AI, Silvey K, et al. Patterns of cancer genetic testing: a randomized survey of Oregon clinicians. J Cancer Epidemiol. 2012;2012:294730. Exclusion code: 2. [pmid: 23150730].
Craft M. Hereditary breast and ovarian cancer: high-risk management. Oncology (Williston Park). 2007;21(11 Suppl Nurse Ed):19-21. Exclusion code: 5. [pmid: 18154204].
Crispo A, D'Aiuto G, De Marco M, et al. Gail model risk factors: impact of adding an extended family history for breast cancer. Breast J. 2008;14(3):221-227. Exclusion code: 3. [pmid: 18373641].
Crotser CB, Boehmke M. Survivorship considerations in adults with hereditary breast and ovarian cancer syndrome: State of the science. J Cancer Surviv. 2009;3(1):21-42. Exclusion code: 5. [pmid: 19165605].
Crotser CB, Dickerson SS. Women Receiving News of a Family BRCA1/2 Mutation: Messages of Fear and Empowerment. J Nurs Scholarsh. 2010;42(4):367-378. Exclusion code: 3. [pmid: 21091619].
Crum C, Drapkin R, Kindelberger DW. Lessons from BRCA: the tubal fimbria emerges as an origin for pelvic serous cancer. Clin Med Res. 2007;5(1):35-44. Exclusion code: 2. [pmid: 17456833].
Crump RJ, Fitzgerald RP, Legge M. ‘Going-to-have-cancerness’: a study of living with increased risk of BRCA1 and BRCA2 mutations for six South Island women. J Prim Health Care. 2010;2(4):311-317. Exclusion code: 5. [pmid: 21125072].
Cruzado JA, Perez-Segura P, Olivera H, et al. Necessity of psychological treatment in people with risk of hereditary cancer who initiate genetic counseling. Study of predictor variables. Psicooncologia. 2005;2(2-3):303-316. Exclusion code: 8.
Cruzado JA, Segura PP, Olivera H. Psychological impact and intervention needs in genetic counseling for women with hereditary breast cancer risk. Psicooncologia. 2007;4(2-3):465-482. Exclusion code: 8.
Cruzado JA, Segura PP, Rojo L, et al. Psychological impact of genetic testing evaluated by the multidimensional impact of cancer risk assessment (MICRA) questionnaire. A study of psychometric properties of MICRA. Psicooncologia. 2011;8(1):125-142. Exclusion code: 8.
Culler D, Grimes SJ, Acheson LS, Wiesner GL. Cancer genetics in primary care. Prim. Care. 2004;31(3):649-683. xi. Exclusion code: 2. [pmid: 15331253].
Culver J, Lowstuter K, Bowling L. Assessing breast cancer risk and BRCA1/2 carrier probability. Breast Dis. 2006;27:5-20. Exclusion code: 5. [pmid: 17917138].
Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. JAMA. 1999;281(23):2189-2197. Exclusion code: 2. [pmid: 10376571].
Cummings SR, Tice JA, Bauer S, et al. Prevention of breast cancer in postmenopausal women: Approaches to estimating and reducing risk. J. Natl. Cancer Inst. 2009;101(6):384-398. Exclusion code: 8. [pmid: 19276457].
Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Saf. 2001;24(14):1039-1053. Exclusion code: 2. [pmid: 11735660].
Cusido M, Colome C, Rodriguez I, Fabregas R. Oncologic risk counselling unit. Selection of risk groups and results. Med. Clin. (Barc). 2009;132(20):779-782. Exclusion code: 7. [pmid: 19285318].
Cutuli B, Lesur A, Namer M, Kerbrat P. Breast cancer chemoprevention. Rational, trials results and future. Bull. Cancer (Paris). 2009;96(5):519-530. Exclusion code: 7. [pmid: 19467983].
Cuzick J. First results from the International Breast Cancer Intervention Study (IBIS-I): A randomised prevention trial. Lancet. 2002;360(9336):817-824. Exclusion code: 2. [pmid: 12243915].
Cuzick J, Powels T, Veronesi U, et al. Overview of the main outcomes in breast-cancer prevention trials. Lancet. 2003;361(9354):296-300. Exclusion code: 2. [pmid: 12559863].
Cypowyj C, Eisinger F, Huiart L, Sobol H, Morin M, Julian-Reynier C. Subjective interpretation of inconclusive BRCA1/2 cancer genetic test results and transmission of information to the relatives. Psychooncology. 2009;18(2):209-215. Exclusion code: 3. [pmid: 19061202].
Cypowyj C, Eisinger F, Morin M, Mogoutov A, Sobol H, Julian-Reynier C. Information-seeking behaviour and psycho-social interactions during the genetic testing process. Community Genet. 2003;6(4):224-234. Exclusion code: 8. [pmid: 15331868].
Cyrus-David M, King J, Bevers T, Robinson E. Validity assessment of the Breast Cancer Risk Reduction Health Belief Scale. Cancer. 2009;115(21):4907-4916. Exclusion code: 8. [pmid: 19637346].
Cyrus-David MS. Knowledge and accuracy of perceived personal risk in underserved women who are at increased risk of breast cancer. J. Cancer Educ. 2010;25(4):617-623. Exclusion code: 8. [pmid: 20229073].
Dagan E, Gil S. BRCA1/2 Mutation Carriers: Psychological Distress and Ways of Coping. J Psychosoc Oncol. 2004;22(3):93-106. Exclusion code: 5.
d'Agincourt-Canning L. A gift or a yoke? Women's and men's responses to genetic risk information from BRCA1 and BRCA2 testing. Clin. Genet. 2006;70(6):462-472. Exclusion code: 5. [pmid: 17100990].
d'Agincourt-Canning L. Genetic testing for hereditary breast and ovarian cancer: Responsibility and choice. Qual. Health Res. 2006;16(1):97-118. Exclusion code: 3. [pmid: 16317179].
Daguet E, Malhaire C, Hardit C, et al. MR breast screening in patients with genetic mutation. J. Radiol. 2008;89(6):783-790. Exclusion code: 7. [pmid: 18641565].
Daly MB, Axilbund JE, Bryant E, et al. Genetic/familial high-risk assessment: breast and ovarian. J Natl Compr Canc Netw. 2006;4(2):156-176. Exclusion code: 5. [pmid: 16451772].
Daly MB, Axilbund JE, Buys S, et al. Genetic/familial high-risk assessment: breast and ovarian. J Natl Compr Canc Netw. 2010;8(5):562-594. Exclusion code: 2. [pmid: 20495085].
Daly PA. Genetic counselling in breast and colorectal cancer. Ann. Oncol. Suppl 2. 2005;16:ii163-169. Exclusion code: 5. [pmid: 15958450].
Dancyger C, Wiseman M, Jacobs C, Smith JA, Wallace M, Michie S. Communicating BRCA1/2 genetic test results within the family: A qualitative analysis. Psychol Health. 2011;26(8):1018-1035. Exclusion code: 2. [pmid: 21797732].
Danforth KN, Im TM, Whitlock EP. Addendum to Screening for Ovarian Cancer: Evidence Update for the US Preventive Services Task Force Reaffirmation Recommendation Statement. Rockville, MD. Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services. 2012. Exclusion code: 2.
Dann RB, Kelley JL, Zorn KK. Strategies for ovarian cancer prevention. Obstet. Gynecol. Clin. North Am. 2007;34(4):667-686. viii. Exclusion code: 5. [pmid: 18061863].
Dapic V, Monteiro ANA. Functional implications of BRCA1 for early detection, prevention, and treatment of breast cancer. Crit. Rev. Eukaryot. Gene Expr. 2006;16(3):233-252. Exclusion code: 5. [pmid: 17073553].
Daum H, Sagi M, Pikarsky E, Pruss D, Hamburger T, Peretz T. Prophylactic oophorectomy among carriers of BRCA1/2 mutations--demographic and pathologic data. Harefuah. 2006;145(1):13-17. 79. 80. Exclusion code: 7. [pmid: 16450717].
Surveillance of women at high risk of breast cancer: a tech brief (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32007000446. Exclusion code: 5.
Davis S, Stewart S, Bloom J. Increasing the accuracy of perceived breast cancer risk: results from a randomized trial with Cancer Information Service callers. Prev. Med. 2004;39(1):64-73. Exclusion code: 4. [pmid: 15207987].
De Bock GH, Hesselink JW, Roorda C, et al. Model of care for women at increased risk of breast and ovarian cancer. Maturitas. 2012;71(1):3-5. Exclusion code: 5. [pmid: 22078659].
de Bock GH, Jacobi CE, Jonker MA, Nagelkerke NJD, van Houwelingen JC. A breast cancer prediction model. Stat. Med. 2005;24(10):1610-1612. author reply 1612. Exclusion code: 5. [pmid: 15880578].
de Bock GH, Vliet Vlieland TP, Hageman GC, Oosterwijk JC, Springer MP, Kievit J. The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam. Pract. 1999;16(1):71-77. Exclusion code: 2. [pmid: 10321400].
de Hullu JA, Kets CM, Massuger LF, Ligtenberg ML, van Ham MA, Hoogerbrugge N. Familial history of ovarian carcinoma: policy. Ned. Tijdschr. Geneeskd. 2011;155:A2392. Exclusion code: 7. [pmid: 21262027].
De Leeuw JRJ, van Vliet MJ, Ausems MGEM. Predictors of choosing life-long screening or prophylactic surgery in women at high and moderate risk for breast and ovarian cancer. Fam Cancer. 2008;7(4):347-359. Exclusion code: 8. [pmid: 18338239].
de Silva D, Gilbert F, Needham G, Deans H, Turnpenny P, Haites N. Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J. Med. Genet. 1995;32(11):862-866. Exclusion code: 2. [pmid: 8592328].
Decarli A, Calza S, Masala G, Specchia C, Palli D, Gail MH. Gail model for prediction of absolute risk of invasive breast cancer: independent evaluation in the Florence-European Prospective Investigation Into Cancer and Nutrition cohort. J. Natl. Cancer Inst. 2006;98(23):1686-1693. Exclusion code: 3. [pmid: 17148770].
Decensi A, Maisonneuve P, Rotmensz N, et al. Effect of tamoxifen on venous thromboembolic events in a breast cancer prevention trial. Circulation. 2005;111(5):650-656. Exclusion code: 3. [pmid: 15699284].
Decruyenaere M, Evers-Kiebooms G, Denayer L, et al. Predictive testing for hereditary breast and ovarian cancer: A psychological framework for pre-test counselling. Eur. J. Hum. Genet. 2000;8(2):130-136. Exclusion code: 6. [pmid: 10757645].
Deffieux X, Touboul C, Uzan C, et al. Chemoprevention and prophylactic surgery in ovarian carcinoma. J. Gynecol. Obstet. Biol. Reprod. (Paris). 2007;36(8):756-763. Exclusion code: 7. [pmid: 17719183].
DeMarco TA, McKinnon WC. Life after BRCA1/2 testing: family communication and support issues. Breast Dis. 2007;27:127-136. Exclusion code: 5. [pmid: 17917144].
DeMarco TA, Peshkin BN, Mars BD, Tercyak KP. Patient satisfaction with cancer genetic counseling: a psychometric analysis of the Genetic Counseling Satisfaction Scale. J Genet Couns. 2004;13(4):293-304. Exclusion code: 8. [pmid: 19736695].
den Heijer M, Seynaeve C, Timman R, et al. Body image and psychological distress after prophylactic mastectomy and breast reconstruction in genetically predisposed women: a prospective long-term follow-up study. Eur. J. Cancer. 2012;48(9):1263-1268. Exclusion code: 3. [pmid: 22105017].
den Heijer M, Seynaeve C, Vanheusden K, et al. Psychological distress in women at risk for hereditary breast cancer: The role of family communication and perceived social support. Psychooncology. 2011;20(12):1317-1323. Exclusion code: 8. [pmid: 20925135].
den Heijer M, Vos J, Seynaeve C, et al. The impact of social and personal resources on psychological distress in women at risk for hereditary breast cancer. Psychooncology. 2012;21(2):153-160. Exclusion code: 8. [pmid: 22271535].
Dent R, Warner E. Screening for hereditary breast cancer. Semin. Oncol. 2007;34(5):392-400. Exclusion code: 5. [pmid: 17920893].
Derogatis LR, Melisaratos N. The Brief Symptom Inventory: An introductory report. Psychol. Med. 1983;13(3):595-605. Exclusion code: 2. [pmid: 6622612].
DerSimonian R, Laird NM. Meta-analysis in clinical trials. Control. Clin. Trials. 1986;7:177-188. Exclusion code: 2. [pmid: 3802833].
Devilee P, Rookus MA. A tiny step closer to personalized risk prediction for breast cancer. N. Engl. J. Med. 2010;362(11):1043-1045. Exclusion code: 5. [pmid: 20237351].
Dhingra K. Antiestrogens--tamoxifen, SERMs and beyond. Invest. New Drugs. 1999;7(3):285-311. Exclusion code: 2. [pmid: 10665480].
Di Pietro ML, Giuli A, Spagnolo AG. Ethical implications of predictive DNA testing for hereditary breast cancer. Ann. Oncol. Suppl 1. 2004;15:I65-I70. Exclusion code: 5. [pmid: 15280191].
DiCastro M, Frydman M, Friedman I, et al. Genetic counseling in hereditary breast/ovarian cancer in Israel: Psychosocial impact and retention of genetic information. Am. J. Med. Genet. 2002;111(2):147-151. Exclusion code: 3. [pmid: 12210341].
Dillard AJ, Ubel PA, Smith DM, et al. The distinct role of comparative risk perceptions in a breast cancer prevention program. Ann. Behav. Med. 2011;42(2):262-268. Exclusion code: 8. [pmid: 21698518].
DiLorenzo TA, Schnur J, Montgomery GH, Erblich J, Winkel G, Bovbjerg DH. A model of disease-specific worry in heritable disease: the influence of family history, perceived risk and worry about other illnesses. J. Behav. Med. 2006;29(1):37-49. Exclusion code: 5. [pmid: 16470344].
Dite GS, Whittemore AS, Knight JA, et al. Increased cancer risks for relatives of very early-onset breast cancer cases with and without BRCA1 and BRCA2 mutations. Br. J. Cancer. 2010;103(7):1103-1108. Exclusion code: 3. [pmid: 20877337].
Dohany L, Gustafson S, Ducaine W, Zakalik D. Psychological Distress with Direct-to-Consumer Genetic Testing: A Case Report of an Unexpected Positive Test Result. J Genet Couns. 2012:1-3. Exclusion code: 5. [pmid: 22207396].
Dolbeault S, Flahault C, Stoppa-Lyonnet D, Bredart A. Communication in genetic counselling for breast/ovarian cancer. Recent Results Cancer Res. 2006;168:23-36. Exclusion code: 5. [pmid: 17073189].
Dombernowsky SL, Weischer M, Freiberg JJ, Bojesen SE, Tybjaerg-Hansen A, Nordestgaard BG. Missense polymorphisms in BRCA1 and BRCA2 and risk of breast and ovarian cancer. Cancer Epidemiol. Biomarkers Prev. 2009;18(8):2339-2342. Exclusion code: 5. [pmid: 19661094].
Domchek SM, Armstrong K, Weber BL. Clinical management of BRCA1 and BRCA2 mutation carriers. Nat Clin Pract Oncol. 2006;3(1):2-3. Exclusion code: 5. [pmid: 16407858].
Domchek SM, Friebel TM, Neuhausen SL, et al. Mortality after bilateral salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers: a prospective cohort study. Lancet Oncol. 2006;7(3):223-229. Exclusion code: 2. [pmid: 16510331].
Domchek SM, Rebbeck TR. Prophylactic oophorectomy in women at increased cancer risk. Curr. Opin. Obstet. Gynecol. 2007;19(1):27-30. Exclusion code: 5. [pmid: 17218848].
Domchek SM, Rebbeck TR. Preventive surgery is associated with reduced cancer risk and mortality in women with BRCA1 and BRCA2 mutations. LDI Issue Brief. 2010;16(2):1-4. Exclusion code: 5. [pmid: 21545057].
Domchek SM, Stopfer JE, Rebbeck TR. Bilateral risk-reducing oophorectomy in BRCA1 and BRCA2 mutation carriers. J Natl Compr Canc Netw. 2006;4(2):177-182. Exclusion code: 5. [pmid: 16451773].
Domchek SM, Weber BL. Clinical management of BRCA1 and BRCA2 mutation carriers. Oncogene. 2006;25(43):5825-5831. Exclusion code: 5. [pmid: 16998496].
Dørum A, Kristensen GB, Abeler VM, Tropé CG, Møller P. Early detection of familial ovarian cancer. Eur. J. Cancer. 1996;32(10):1645-1651. Exclusion code: 6. [pmid: 8983269].
Dorval M, Bouchard K, Maunsell E, et al. Health behaviors and psychological distress in women initiating BRCA1/2 genetic testing: comparison with control population. J Genet Couns. 2008;17(4):314-326. Exclusion code: 8. [pmid: 18481164].
Dorval M, Drolet M, LeBlanc M, Maunsell E, Dugas MJ, Simard J. Using the Impact of Event Scale to evaluate distress in the context of genetic testing for breast cancer susceptibility. Psychol. Rep. 2006;98(3):873-881. Exclusion code: 3. [pmid: 16933689].
Dorval M, Gauthier G, Maunsell E, et al. No evidence of false reassurance among women with an inconclusive BRCA1/2 genetic test result. Cancer Epidemiol. Biomarkers Prev. 2005;14(12):2862-2867. Exclusion code: 3. [pmid: 16365001].
Dorval M, Nogués C, Berthet P, et al. Breast and ovarian cancer screening of non-carriers from BRCA1/2 mutation-positive families: 2-year follow-up of cohorts from France and Quebec. Eur. J. Hum. Genet. 2011;19(5):494-499. Exclusion code: 8. [pmid: 21248744].
Dougall AL, Smith AW, Somers TJ, Posluszny DM, Rubinstein WS, Baum A. Coping with genetic testing for breast cancer susceptibility. Psychosom. Med. 2009;71(1):98-105. Exclusion code: 3. [pmid: 19124622].
Doughty Rice C, Ruschman JG, Martin LJ, Manders JB, Miller E. Retrospective comparison of patient outcomes after in-person and telephone results disclosure counseling for BRCA1/2 genetic testing. Fam Cancer. 2010;9(2):203-212. Exclusion code: 3. [pmid: 20473602].
Douglas HA, Hamilton RJ, Grubs RE. The effect of BRCA gene testing on family relationships: A thematic analysis of qualitative interviews. J Genet Couns. 2009;18(5):418-435. Exclusion code: 3. [pmid: 19479365].
Dowdy SC, Stefanek M, Hartmann LC. Surgical risk reduction: prophylactic salpingo-oophorectomy and prophylactic mastectomy. Am. J. Obstet. Gynecol. 2004;191(4):1113-1123. Exclusion code: 5. [pmid: 15507929].
Drazan L, Vesely J, Hyza P, Kubek T, Foretova L, Coufal O. Surgical prevention of breast carcinoma in patients with hereditary risk. Klin. 2012;25(Suppl):S78-83. Exclusion code: 7. [pmid: 22920212].
Dudbridge F, Fletcher O, Walker K, et al. Estimating causal effects of genetic risk variants for breast cancer using marker data from bilateral and familial cases. Cancer Epidemiol. Biomarkers Prev. 2012;21(2):262-272. Exclusion code: 8. [pmid: 22028405].
Duffy SW, Tabar L, Olsen AH, et al. Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J. Med. Screen. 2010;17(1):25-30. Exclusion code: 2. [pmid: 20356942].
Dumitrescu RG, Cotarla I. Understanding breast cancer risk -- where do we stand in 2005. J Cell Mol Med. 2005;9(1):208-221. Exclusion code: 5. [pmid: 15784178].
Effectiveness of magnetic resonance imaging (MRI) screening for women at high risk of breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32007000624. Exclusion code: 5.
Dutil J, Colon-Colon JL, Matta JL, Sutphen R, Echenique M. Identification of the prevalent BRCA1 and BRCA2 mutations in the female population of Puerto Rico. Cancer Genet. 2012;205(5):242-248. Exclusion code: 3. [pmid: 22682623].
Dyer C. US judge rules that patents on breast cancer genes are unlawful. BMJ. 2010;340:c1870. Exclusion code: 5. [pmid: 20360219].
Dyer C. US Supreme Court is asked to rule on validity of patents on BRCA1 and BRCA2 genes. BMJ. 2012;345:e6624. Exclusion code: 2. [pmid: 23033368].
Easton DF, Bishop DT, Ford D, Crockford GP, The Breast Cancer Linkage Consortium. Genetic linkage analysis in familial breast and ovarian cancer: Results from 214 families. Am J Hum Genet. 1993;52:678-701. Exclusion code: 2. [pmid: 8460634].
Easton DF, Ford D, Bishop DT, The Breast Cancer Linkage Consortium. Breast and ovarian cancer incidence in BRCA1-mutation carriers. Am J Hum Genet. 1995;56:265-271. Exclusion code: 2. [pmid: 7825587].
Easton DF, Hopper JL, Thomas DC, et al. Breast cancer risks for BRCA1/2 carriers. Science. 2004;306(5705):2187-2191. author reply 2187-2191. Exclusion code: 5. [pmid: 15622557].
Eccles D. Guidelines for a genetic risk based approach to advising women with a family history of breast cancer. J. Med. Genet. 2000;37:203-209. Exclusion code: 2. [pmid: 10699057].
Eccles D, Gerty S, Simmonds P, et al. Prospective study of Outcomes in Sporadic versus Hereditary breast cancer (POSH): study protocol. BMC Cancer. 2007;7:160. Exclusion code: 5. [pmid: 17697367].
Edlich RF, Cross CL, Wack CA, Chase ME, Lin KY, Long WB 3rd. Breast cancer and ovarian cancer genetics: an update. J. Environ. Pathol. Toxicol. Oncol. 2008;27(4):245-256. Exclusion code: 5. [pmid: 19105530].
Edlich RF, Winters KL, Lin KY. Breast cancer and ovarian cancer genetics. J. Long. Term Eff. Med. Implants. 2005;15(5):533-545. Exclusion code: 5. [pmid: 16218901].
Edwards A, Gray J, Clarke A, et al. Interventions to improve risk communication in clinical genetics: systematic review. Patient Educ. Couns. 2008;71:4-25. Exclusion code: 8. [pmid: 18207694].
Personalised risk communication for informed decision making about taking screening tests. 2011. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=coch&AN=00075320-100000000-01239. Exclusion code: 5.
Edwards QT, Seibert D. Pre- and posttest evaluation of a breast cancer risk assessment program for nurse practitioners. J. Am. Acad. Nurse Pract. 2010;22(7):376-381. Exclusion code: 8. [pmid: 20590960].
Edwards QT, Seibert D, Maradiegue A, et al. Breast cancer and the family tree. An issue for all practice settings. Adv. Nurse Pract. 2007;15(5):34-41. quiz 41-32. Exclusion code: 5. [pmid: 20000211].
Edwards TA, Thompson HS, Kwate NOA, et al. Association between temporal orientation and attitudes about BRCA1/2 testing among women of African descent with family histories of breast cancer. Patient Educ. Couns. 2008;72(2):276-282. Exclusion code: 3. [pmid: 18479882].
Eerola H, Vahteristo P, Sarantaus L, et al. Survival of breast cancer patients in BRCA1, BRCA2, and non-BRCA1/2 breast cancer families: A relative survival analysis from Finland. Int. J. Cancer. 2001;93(3):368-372. Exclusion code: 6. [pmid: 11433401].
Einbeigi Z, Bergman A, Kindblom LG, et al. A founder mutation of the BRCA1 gene in Western Sweden associated with a high incidence of breast and ovarian cancer. Eur. J. Cancer. 2001;37(15):1904-1909. Exclusion code: 2. [pmid: 11576847].
Eisen A, Lubinski J, Klijn J, et al. Breast cancer risk following bilateral oophorectomy in BRCA1 and BRCA2 mutation carriers: an international case-control study. J. Clin. Oncol. 2005;23(30):7491-7496. Exclusion code: 3. [pmid: 16234515].
Eisen A, Rebbeck TR, Wood WC, Weber BL. Prophylactic surgery in women with a hereditary predisposition to breast and ovarian cancer. J. Clin. Oncol. 2000;18(9):1980-1995. Exclusion code: 5. [pmid: 10784640].
Eisinger F. Prophylactic mastectomy: ethical issues. Br. Med. Bull. 2007;81-82:7-19. Exclusion code: 5. [pmid: 17409120].
Eisinger F, Horsman DE. Genetic risk assessment and BRCA mutation testing. Ann. Intern. Med. 2006;144(5):376. author reply 376-377. Exclusion code: 5. [pmid: 16520482].
Eisinger F, Huiart L, Sobol H. The choice of bilateral prophylactic mastectomy. J. Clin. Oncol. 2005;23(6):1330-1331. author reply 1331-1332. Exclusion code: 5. [pmid: 15718344].
Eisinger F, Reynier CJ, Chabal F, Luquet C, Moatti JP, Sobol H. Acceptable strategies for dealing with hereditary breast/ovarian cancer risk. J. Natl. Cancer Inst. 1997;89(10):731. Exclusion code: 3. [pmid: 9168189].
Ellberg C, Jonsson G, Olsson H. Can a phenotype for recessive inheritance in breast cancer be defined. Fam Cancer. 2010;9(4):525-530. Exclusion code: 3. [pmid: 20549370].
Ellington L, Kelly KM, Reblin M, Latimer S, Roter D. Communication in genetic counseling: cognitive and emotional processing. Health Commun. 2011;26(7):667-675. Exclusion code: 2. [pmid: 21660793].
Ellington L, Maxwel A, Baty BJ, Roter D, Dudley WN, Kinney AY. Genetic counseling communication with an African American BRCA1 kindred. Soc. Sci. Med. 2007;64(3):724-734. Exclusion code: 8. [pmid: 17081667].
Elwyn G, Iredale R, Gray J. Reactions of GPs to a triage-controlled referral system for cancer genetics. Fam. Pract. 2002;19(1):65-71. Exclusion code: 2. [pmid: 11818352].
Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann. Hum. Biol. 2005;32(2):218-227. Exclusion code: 5. [pmid: 16096220].
Emery J, Walton R, Coulson A, Glasspool D, Ziebland S, Fox J. Computer support for recording and interpreting family histories of breast and ovarian cancer in primary care (RAGs): qualitative evaluation with simulated patients. BMJ. 1999;319(7201):32-36. Exclusion code: 2. [pmid: 10390458].
Emery J, Walton R, Murphy M, et al. Computer support for interpreting family histories of breast and ovarian cancer in primary care: comparative study with simulated cases. BMJ. 2000;321(7252):28-32. Exclusion code: 2. [pmid: 10875832].
Eng-Wong J, Orzano-Birgani J, Chow CK, et al. Effect of raloxifene on mammographic density and breast magnetic resonance imaging in premenopausal women at increased risk for breast cancer. Cancer Epidemiol. Biomarkers Prev. 2008;17(7):1696-1701. Exclusion code: 8. [pmid: 18583470].
Ensenauer RE, Michels VV, Reinke SS. Genetic testing: practical, ethical, and counseling considerations. Mayo Clin. Proc. 2005;80(1):63-73. Exclusion code: 5. [pmid: 15667031].
Erblich J, Brown K, Kim Y, Valdimarsdottir HB, Livingston BE, Bovbjerg DH. Development and validation of a Breast Cancer Genetic Counseling Knowledge Questionnaire. Patient Educ. Couns. 2005;56(2):182-191. Exclusion code: 8. [pmid: 15653247].
Escobar PF, Starks DC, Fader AN, Barber M, Rojas-Espalliat L. Single-port risk-reducing salpingo-oophorectomy with and without hysterectomy: surgical outcomes and learning curve analysis. Gynecol. Oncol. 2010;119(1):43-47. Exclusion code: 3. [pmid: 20579712].
Esplen MJ, Stuckless N, Hunter J, et al. The BRCA Self-Concept Scale: A new instrument to measure self-concept in BRCA 1/2 mutation carriers. Psychooncology. 2009;18(11):1216-1229. Exclusion code: 8. [pmid: 19180529].
Esserman L, Kaklamani V. Lessons learned from genetic testing. JAMA. 2010;304(9):1011-1012. Exclusion code: 5. [pmid: 20810382].
Esserman LJ, Ozanne EM, Dowsett M, Slingerland JM. Tamoxifen may prevent both ER+ and ER- breast cancers and select for ER- carcinogenesis: an alternative hypothesis. Breast Cancer Res. 2005;7(6):R1153-1158. Exclusion code: 5. [pmid: 16457695].
Essink-Bot ML, Rijnsburger AJ, van Dooren S, de Koning HJ, Seynaeve C. Women's acceptance of MRI in breast cancer surveillance because of a familial or genetic predisposition. Breast. 2006;15(5):673-676. Exclusion code: 8. [pmid: 16556497].
Esteban Cardenosa E, Bolufer Gilabert P, de Juan Jimenez I, et al. Relationship of BRCA1 and BRCA2 mutations with cancer burden in the family and tumor incidence. Fam Cancer. 2010;9(3):291-295. Exclusion code: 8. [pmid: 20711702].
Esteves V, Thuler L, Amendola L, et al. Prevalence of BRCA1 and BRCA2 gene mutations in families with medium and high risk of breast and ovarian cancer in Brazil. Braz. J. Med. Biol. Res. 2009;42(5):453-457. Exclusion code: 3. [pmid: 19377795].
Etchegary H, Miller F, deLaat S, Wilson B, Carroll J, Cappelli M. Decision-making about inherited cancer risk: Exploring dimensions of genetic responsibility. J Genet Couns. 2009;18(3):252-264. Exclusion code: 2. [pmid: 19294336].
Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group, Berg AO, Armstrong K, et al. Recommendations from the EGAPP Working Group: Can tumor gene expression profiling improve outcomes in patients with breast cancer. Genet Med. 2009;11(1):66-73. Exclusion code: 2. [pmid: 19125125].
Evans DG, Gaarenstroom KN, Stirling D, et al. Screening for familial ovarian cancer: Poor survival of BRCA1/2 related cancers. J. Med. Genet. 2009;46(9):593-597. Exclusion code: 8. [pmid: 18413372].
Evans DG, Howell A. Breast cancer risk for noncarriers of family-specific BRCA1 and BRCA2 mutations: more trouble with phenocopies. J. Clin. Oncol. 2012;30(10):1142-1143. author reply 1143-1144. Exclusion code: 5. [pmid: 22370324].
Evans DGR, Eccles DM, Rahman N, et al. A new scoring system for the chances of identifying a BRCA 1/2 mutation outperforms existing models including BRCAPRO. J. Med. Genet. 2004;41:474-480. Exclusion code: 2. [pmid: 15173236].
Evans DGR, Howell A. Breast cancer risk-assessment models. Breast Cancer Res. 2007;9(5):213. Exclusion code: 5. [pmid: 17888188].
Evans DGR, Young K, Bulman M, Shenton A, Wallace A, Lalloo F. Probability of BRCA1/2 mutation varies with ovarian histology: results from screening 442 ovarian cancer families. Clin. Genet. 2008;73(4):338-345. Exclusion code: 2. [pmid: 18312450].
Evans JP, Skrzynia C, Susswein L, Harlan M. Genetics and the young woman with breast cancer. Breast Dis. 2005;23:17-29. Exclusion code: 3. [pmid: 16823163].
Evans KD. Review of the US preventive services task force's statement on screening for breast cancer. JDMS. 2010;26(1):19-23. Exclusion code: 5.
Evans WP, Lee CH, Monsees BS, Monticciolo DL, Rebner M. U.S. Preventive Services Task Force: the unbalanced view. Radiology. 2010;257(1):297. author reply 297-298. Exclusion code: 5. [pmid: 20851949].
Fabian CJ, Kimler BF. Use of biomarkers for breast cancer risk assessment and prevention. J. Steroid Biochem. Mol. Biol. 2007;106(1-5):31-39. Exclusion code: 4. [pmid: 17596932].
Fabian CJ, Kimler BF, Mayo MS, Khan SA. Breast-tissue sampling for risk assessment and prevention. Endocr Relat Cancer. 2005;12(2):185-213. Exclusion code: 4. [pmid: 15947097].
Fackenthal JD, Olopade OI. Breast cancer risk associated with BRCA1 and BRCA2 in diverse populations. Nat Rev Cancer. 2007;7(12):937-948. Exclusion code: 5. [pmid: 18034184].
Fackenthal JD, Zhang J, Zhang B, et al. High prevalence of BRCA1 and BRCA2 mutations in unselected Nigerian breast cancer patients. Int. J. Cancer. 2012;131(5):1114-1123. Exclusion code: 3. [pmid: 22034289].
Fakkert IE, Jansen L, Meijer K, et al. Breast cancer screening in BRCA1 and BRCA2 mutation carriers after risk reducing salpingo-oophorectomy. Breast Cancer Res. Treat. 2011;129(1):157-164. Exclusion code: 3. [pmid: 21373873].
Fallowfield L, Fleissig A, Barrett J, et al. Awareness of ovarian cancer risk factors, beliefs and attitudes towards screening: baseline survey of 21,715 women participating in the UK Collaborative Trial of Ovarian Cancer Screening. Br. J. Cancer. 2010;103(4):454-461. Exclusion code: 8. [pmid: 20648018].
Fanale D, Amodeo V, Corsini LR, Rizzo S, Bazan V, Russo A. Breast cancer genome-wide association studies: There is strength in numbers. Oncogene. 2012;31(17):2121-2128. Exclusion code: 2. [pmid: 21996731].
Fang CY, Cherry C, Devarajan K, Li T, Malick J, Daly MB. A prospective study of quality of life among women undergoing risk-reducing salpingo-oophorectomy versus gynecologic screening for ovarian cancer. Gynecol. Oncol. 2009;112(3):594-600. Exclusion code: 3. [pmid: 19141360].
Farooq A, Naveed AK, Azeem Z, Ahmad T. Breast and ovarian cancer risk due to prevalence of BRCA1 and BRCA2 variants in pakistani population: A Pakistani database report. J Oncol. 2011. Exclusion code: 3. [pmid: 21559243].
Fasching PA, Bani MR, Nestle-Kramling C, et al. Evaluation of mathematical models for breast cancer risk assessment in routine clinical use. Eur. J. Cancer Prev. 2007;16(3):216-224. Exclusion code: 8. [pmid: 17415092].
Federico M, Maiorana A, Mangone L, et al. Identification of families with hereditary breast and ovarian cancer for clinical and mammographic surveillance: The Modena Study Group proposal. Breast Cancer Res. Treat. 1999;55(3):213-221. Exclusion code: 6. [pmid: 10517166].
Fialho AM, Chakrabarty AM. Law-medicine interfacing: patenting of human genes and mutations. Recent Pat DNA Gene Seq. 2011;5(2):81-85. Exclusion code: 5. [pmid: 21574951].
Finch A, Beiner M, Lubinski J, et al. Salpingo-oophorectomy and the risk of ovarian, fallopian tube, and peritoneal cancers in women with a BRCA1 or BRCA2 Mutation. JAMA. 2006;296(2):185-192. Exclusion code: 3. [pmid: 16835424].
Finch A, Metcalfe K, Lui J, et al. Breast and ovarian cancer risk perception after prophylactic salpingo-oophorectomy due to an inherited mutation in the BRCA1 or BRCA2 gene. Clin. Genet. 2009;75(3):220-224. Exclusion code: 3. [pmid: 19263514].
Finlay E, Stopfer JE, Burlingame E, et al. Factors determining dissemination of results and uptake of genetic testing in families with known BRCA1/2 mutations. Genet Test. 2008;12(1):81-91. Exclusion code: 2. [pmid: 18373407].
Firth C, Jacobs C, Evison M, Pichert G, Izatt L, Hunter MS. Novel one-stop multidisciplinary follow-up clinic for BRCA1/2 carriers: patient satisfaction and decision making. Psychooncology. 2011;20(12):1301-1308. Exclusion code: 8. [pmid: 22114045].
Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J. Natl. Cancer Inst. 1998;90(18):1371-1388. Exclusion code: 2. [pmid: 9747868].
Fishman DA, Cohen L, Blank SV, et al. The role of ultrasound evaluation in the detection of early-stage epithelial ovarian cancer. Am. J. Obstet. Gynecol. 2005;192(4):1214-1222. Exclusion code: 3. [pmid: 15846205].
The clinical effectiveness and cost-effectiveness of genotyping for CYP2D6 for the management of women with breast cancer treated with tamoxifen: a systematic review (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000281. Exclusion code: 3.
Fletcher KE, Clemow L, Peterson BA, Lemon SC, Estabrook B, Zapka JG. A path analysis of factors associated with distress among first-degree female relatives of women with breast cancer diagnosis. Health Psychol. 2006;25(3):413-424. Exclusion code: 4. [pmid: 16719614].
Fletcher SW. Screening for breast cancer. 2011. http://www.uptodate.com/contents/screening-for-breast-cancer?source=search_result&search=breast+cancer+screening&selectedTitle=1%7E34#H22. 09 Nov, 2011. Exclusion code: 2.
Force USPST. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: recommendation statement. Ann. Intern. Med. 2005;143(5):355-361. Exclusion code: 2. [pmid: 16144894].
Ford D, Easton DF. The genetics of breast and ovarian cancer. Br. J. Cancer. 1995;72(4):805-812. Exclusion code: 2. [pmid: 7547224].
Ford D, Easton DF, Bishop DT, Narod SA, Goldgar DE. Risks of cancer in BRCA1-mutation carriers. Lancet. 1994;343(8899):692-695. Exclusion code: 2. [pmid: 7907678].
Ford ME, Alford SH, Britton D, McClary B, Gordon HS. Factors influencing perceptions of breast cancer genetic counseling among women in an urban health care system. J Genet Couns. 2007;16(6):735-753. Exclusion code: 8. [pmid: 17701328].
Forman AD, Hall MJ. Influence of race/ethnicity on genetic counseling and testing for hereditary breast and ovarian cancer. Breast J. Suppl 1. 2009;15:S56-62. Exclusion code: 8. [pmid: 19775331].
Foster C, Evans DGR, Eeles R, et al. Non-uptake of predictive genetic testing for BRCA1/2 among relatives of known carriers: attributes, cancer worry, and barriers to testing in a multicenter clinical cohort. Genet Test. 2004;8(1):23-29. Exclusion code: 8. [pmid: 15140371].
Foulkes WD, Chappuis PO, Wong N, et al. Primary node negative breast cancer in BRCA1 mutation carriers has a poor outcome. Ann. Oncol. 2000;11(3):307-313. Exclusion code: 6. [pmid: 10811497].
Foulkes WD, Wong N, Brunet JS, et al. Germ-line BRCA1 mutation is an adverse prognostic factor in Ashkenazi Jewish women with breast cancer. Clin. Cancer Res. 1997;3(12 I):2465-2469. Exclusion code: 6. [pmid: 9815648].
Freedman AN, Seminara D, Gail MH, et al. Cancer risk prediction models: a workshop on development, evaluation, and application. J. Natl. Cancer Inst. 2005;97(10):715-723. Exclusion code: 2. [pmid: 15900041].
Freedman AN, Wideroff L, Olson L, et al. US physicians' attitudes toward genetic testing for cancer susceptibility. Am. J. Med. Genet. 2003;120 A(1):63-71. Exclusion code: 3. [pmid: 12794694].
Friebel TM, Domchek SM, Neuhausen SL, et al. Bilateral prophylactic oophorectomy and bilateral prophylactic mastectomy in a prospective cohort of unaffected BRCA1 and BRCA2 mutation carriers. Clin Breast Cancer. 2007;7(11):875-882. Exclusion code: 8. [pmid: 18269778].
Friedenson B. Assessing and managing breast cancer risk: clinical tools for advising patients. MedGenMed. 2004;6(1):8. Exclusion code: 5. [pmid: 15208521].
Friedman LC. Psychological impact of receiving negative BRCA1 mutation test results in Ashkenazim. Genet Med. 1999;1(3):74-79. Exclusion code: 3. [pmid: 11336456].
Friedman LC, Kramer RM. Reproductive issues for women with BRCA mutations. J. Natl. Cancer Inst. Monographs. 2005;(34):83-86. Exclusion code: 5. [pmid: 15784831].
Fries MH, Holt C, Carpenter I, et al. Guidelines for evaluation of patients at risk for inherited breast and ovarian cancer: recommendations of the Department of Defense Familial Breast/Ovarian Cancer Research Project. Mil. Med. 2002;167(2):93-98. Exclusion code: 2. [pmid: 11873549].
Frost CJ, Venne V, Cunningham D, Gerritsen-McKane R. Decision making with uncertain information: learning from women in a high risk breast cancer clinic. J Genet Couns. 2004;13(3):221-236. Exclusion code: 5. [pmid: 15604633].
Frost MH, Schaid DJ, Sellers TA, et al. Long-term satisfaction and psychological and social function following bilateral prophylactic mastectomy. JAMA. 2000;284(3):319-324. Exclusion code: 5. [pmid: 10891963].
Fry A, Busby-Earle C, Rush R, Cull A. Prophylactic oophorectomy versus screening: psychosocial outcomes in women at increased risk of ovarian cancer. Psychooncology. 2001;10(3):231-241. Exclusion code: 5. [pmid: 11351375].
Fuller S, Anderson RC. Adjustment issues related to bilateral prophylactic mastectomy in women at elevated risk of developing breast cancer. Plast. Surg. Nurs. 2006;26(2):60-65. quiz 66-67. Exclusion code: 5. [pmid: 16783176].
Gaarenstroom KN, Van Der Hiel B, Tollenaar RAEM, et al. Efficacy of screening women at high risk of hereditary ovarian cancer: Results of an 11-year cohort study. Int J Gynecol Cancer. 2006;16(SUPPL. 1):54-59. Exclusion code: 8. [pmid: 16515568].
Gabrovska PN, Smith RA, O'Leary G, Haupt LM, Griffiths LR. Investigation of the 1758G>C and 2880A>G variants within the NCOA3 gene in a breast cancer affected Australian population. Gene. 2011;482(1-2):68-72. Exclusion code: 3. [pmid: 21601620].
Gadzicki D, Wingen LU, Teige B, et al. Communicating BRCA1 and BRCA2 genetic test results. J. Clin. Oncol. 2006;24(18):2969-2970. Exclusion code: 5. [pmid: 16782939].
Gail M, Brinton L, Byar D, Corle D, Green S, Schairer C. Projecting individualized probablities of developing breast cancer for white females who are being examined annually. J. Natl. Cancer Inst. 1989;81(24):1879-1886. Exclusion code: 2. [pmid: 2593165].
Gail MH. Discriminatory accuracy from single-nucleotide polymorphisms in models to predict breast cancer risk. J. Natl. Cancer Inst. 2008;100(14):1037-1041. Exclusion code: 8. [pmid: 18612136].
Gail MH, Anderson WF, Garcia-Closas M, Sherman ME. Absolute risk models for subtypes of breast cancer. J. Natl. Cancer Inst. 2007;99(22):1657-1659. Exclusion code: 2. [pmid: 18000214].
Gail MH, Costantino JP, Pee D, et al. Projecting individualized absolute invasive breast cancer risk in African American women. J. Natl. Cancer Inst. 2007;99(23):1782-1792. Exclusion code: 3. [pmid: 18042936].
Gail MH, Mai PL. Comparing breast cancer risk assessment models. J. Natl. Cancer Inst. 2010;102(10):665-668. Exclusion code: 2. [pmid: 20427429].
Gallagher KM, Updegraff JA, Rothman AJ, Sims L. Perceived susceptibility to breast cancer moderates the effect of gain- and loss-framed messages on use of screening mammography. Health Psychol. 2011;30(2):145-152. Exclusion code: 8. [pmid: 21401248].
Gammon AD, Rothwell E, Simmons R, et al. Awareness and preferences regarding BRCA1/2 genetic counseling and testing among Latinas and non-Latina White women at increased risk for hereditary breast and ovarian cancer. J Genet Couns. 2011;20(6):625-638. Exclusion code: 3. [pmid: 21691939].
Ganz PA. Breast cancer, menopause, and long-term survivorship: critical issues for the 21st century. Am. J. Med. Suppl 12B. 2005;118:136-141. Exclusion code: 3. [pmid: 16414339].
Garber JE, Hartman AR. Prophylactic oophorectomy and hormone replacement therapy: Protection at what price. J. Clin. Oncol. 2004;22(6):978-980. Exclusion code: 5. [pmid: 14981100].
Geiger AM, Yu O, Herrinton LJ, et al. A population-based study of bilateral prophylactic mastectomy efficacy in women at elevated risk for breast cancer in community practices. Arch. Intern. Med. 2005;165(5):516-520. Exclusion code: 3. [pmid: 15767526].
Geirdal AO, Dahl AA. The relationship between psychological distress and personality in women from families with familial breast/ovarian or hereditary non-polyposis colorectal cancer in the absence of demonstrated mutations. J Genet Couns. 2008;17(4):384-393. Exclusion code: 8. [pmid: 18607701].
Gerdes AMA, Ejlertsen B. Inherited breast and ovarian cancers. Ugeskr. Laeger. 2006;168(24):2367-2369. Exclusion code: 7. [pmid: 16822422].
Gershoni-Baruch R, Dagan E, Fried G, et al. Significantly lower rates of BRCA1/BRCA2 founder mutations in Ashkenazi women with sporadic compared with familial early onset breast cancer. Eur. J. Cancer. 2000;36(8):983-986. Exclusion code: 2. [pmid: 10885601].
Gevensleben H, Serce N, Buttner R. Hereditary breast and ovarian cancers. Pathologe. 2010;31(6):438-444. Exclusion code: 7. [pmid: 20848107].
Gibbon S. Re-examining geneticization: family trees in breast cancer genetics. Sci Cult. 2002;11(4):429-457. Exclusion code: 5. [pmid: 15971366].
Gil F, Méndez I, Sirgo A, Llort G, Blanco I, Cortés-Funes H. Perception of breast cancer risk and surveillance behaviours of women with family history of breast cancer: A brief report on a Spanish cohort. Psychooncology. 2003;12(8):821-827. Exclusion code: 8. [pmid: 14681955].
Gil FL, Costa G. Psychological aspects of risk reduction surgery (mastectomy and ooforectomy). Psicooncologia. 2005;2(2-3):317-328. Exclusion code: 5.
Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clin. Genet. 2000;58(4):299-308. Exclusion code: 2. [pmid: 11076055].
Giuliano AE, Boolbol S, Degnim A, Kuerer H, Leitch AM, Morrow M. Society of Surgical Oncology: position statement on prophylactic mastectomy. Approved by the Society of Surgical Oncology Executive Council, March 2007. Ann. Surg. Oncol. 2007;14(9):2425-2427. Exclusion code: 5. [pmid: 17597344].
Gjorgov NA. Breast cancer risk assessments to barrier contraception exposure. A new approach. Makedonska Akademija na Naukite i Umetnostite Oddelenie Za Bioloshki i Meditsinski Nauki Prilozi. 2009;30(1):217-232. Exclusion code: 4. [pmid: 19736543].
Glenn BA, Chawla N, Bastani R. Barriers to genetic testing for breast cancer risk among ethnic minority women: an exploratory study. Ethn. Dis. 2012;22(3):267-273. Exclusion code: 8. [pmid: 22870568].
Goffin JR, Chappuis PO, Bégin LR, et al. Impact of germline BRCA1 mutations and overexpression of p53 on prognosis and response to treatment following breast carcinoma: 10-Year follow-up data. Cancer. 2003;97(3):527-536. Exclusion code: 3. [pmid: 12548593].
Gold ER, Carbone J. Myriad Genetics: In the eye of the policy storm. Genet Med. 2010;12(4 Suppl):S39-70. Exclusion code: 2. [pmid: 20393310].
Goldberg JI, Borgen PI. Breast cancer susceptibility testing: past, present and future. Expert Rev Anticancer Ther. 2006;6(8):1205-1214. Exclusion code: 5. [pmid: 16925486].
Goldfrank D, Chuai S, Bernstein JL, et al. Effect of mammography on breast cancer risk in women with mutations in BRCA1 or BRCA2. Cancer Epidemiol. Biomarkers Prev. 2006;15(11):2311-2313. Exclusion code: 4. [pmid: 17119064].
Golshan M, Miron A, Nixon AJ, et al. The prevalence of germline BRCA1 and BRCA2 mutations in young women with breast cancer undergoing breast-conservation therapy. Am. J. Surg. 2006;192(1):58-62. Exclusion code: 3. [pmid: 16769276].
Gomez-Garcia EB, Ambergen T, Blok MJ, van den Wijngaard A. Patients with an unclassified genetic variant in the BRCA1 or BRCA2 genes show different clinical features from those with a mutation. J. Clin. Oncol. 2005;23(10):2185-2190. Exclusion code: 8. [pmid: 15800311].
Gonzalez-Angulo AM, Timms KM, Liu S, et al. Incidence and outcome of BRCA mutations in unselected patients with triple receptor-negative breast cancer. Clin. Cancer Res. 2011;17(5):1082-1089. Exclusion code: 3. [pmid: 21233401].
Goodnight JE, Quagliana JM, Morton DL. Failure of subcutaneous mastectomy to prevent the development of breast cancer. J. Surg. Oncol. 1984;26:198-201. Exclusion code: 2. [pmid: 6330460].
Goodwin PJ, Phillips KA, West DW, et al. Breast cancer prognosis in BRCA1 and BRCA2 mutation carriers: an International Prospective Breast Cancer Family Registry population-based cohort study. J. Clin. Oncol. 2012;30(1):19-26. Exclusion code: 8. [pmid: 22147742].
Goozner M. Ruling on BRCA gene patents could have limited impact. J. Natl. Cancer Inst. 2010;102(11):754-757. Exclusion code: 5. [pmid: 20498427].
Górski B, Jakubowska A, Huzarski T, et al. A high proportion of founder BRCA1 mutations in Polish breast cancer families. Int. J. Cancer. 2004;110(5):683-686. Exclusion code: 8. [pmid: 15146557].
Goss PE, Ingle JN, Ales-Martinez JE, et al. Exemestane for breast-cancer prevention in postmenopausal women. N. Engl. J. Med. 2011;364(25):2381-2391. Exclusion code: 2. [pmid: 21639806].
Gotlieb WH, Barchana M, Ben-Baruch G, Friedman E. Malignancies following bilateral salpingo-oophorectomy (BSO). Eur. J. Surg. Oncol. 2006;32(10):1231-1234. Exclusion code: 3. [pmid: 16626923].
Graeser MK, Engel C, Rhiem K, et al. Contralateral breast cancer risk in BRCA1 and BRCA2 mutation carriers. J. Clin. Oncol. 2009;27(35):5887-5892. Exclusion code: 2. [pmid: 19858402].
Gramling R, Anthony D, Lowery J, et al. Association between screening family medical history in general medical care and lower burden of cancer worry among women with a close family history of breast cancer. Genet Med. 2005;7(9):640-645. Exclusion code: 4. [pmid: 16301866].
Grana G, Daly M, Sands C. The role of prophylactic mastectomy in managing genetic risk. Breast Cancer Res. Treat. 1994;32(Suppl):72. Exclusion code: 5.
Granader EJ, Dwamena B, Carlos RC. MRI and mammography surveillance of women at increased risk for breast cancer: recommendations using an evidence-based approach. Acad. Radiol. 2008;15(12):1590-1595. Exclusion code: 5. [pmid: 19000876].
Grandner MA, Kripke DF, Yoon IY, Youngstedt SD. Criterion validity of the Pittsburgh Sleep Quality Index: Investigation in a non-clinical sample. Sleep Biol Rhythms. 2006;4(2):129-136. Exclusion code: 2. [pmid: 22822303].
Grann VR, Patel P, Bharthuar A, et al. Breast cancer-related preferences among women with and without BRCA mutations. Breast Cancer Res. Treat. 2010;119(1):177-184. Exclusion code: 8. [pmid: 19322653].
Grant AM, Van Teijlingen ER, Forrest-Keenan K, Torrance N, Wilson BJ, Haites NE. Does breast cancer genetic counselling meet women's expectations? A qualitative study. Critical Public Health. 2006;16(4):281-293. Exclusion code: 8.
Graubard BI, Freedman AN, Gail MH. Five-year and lifetime risk of breast cancer among U.S. subpopulations: implications for magnetic resonance imaging screening. Cancer Epidemiol. Biomarkers Prev. 2010;19(10):2430-2436. Exclusion code: 2. [pmid: 20841391].
Gray SW. Direct-to-consumer genetic testing and its potential impact on patient care: What oncologists need to know. Community Oncology. 2011;8(9):49-50. Exclusion code: 5.
Gray SW, Hornik RC, Schwartz JS, Armstrong K. The impact of risk information exposure on women's beliefs about direct-to-consumer genetic testing for BRCA mutations. Clin. Genet. 2012;81(1):29-37. Exclusion code: 2. [pmid: 21992449].
Gray SW, O'Grady C, Karp L, et al. Risk information exposure and direct-to-consumer genetic testing for BRCA mutations among women with a personal or family history of breast or ovarian cancer. Cancer Epidemiol. Biomarkers Prev. 2009;18(4):1303-1311. Exclusion code: 2. [pmid: 19318436].
Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genet Med. 2005;7(4):221-229. Exclusion code: 3. [pmid: 15834239].
Green MJ, Peterson SK, Baker MW, et al. Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA. 2004;292(4):442-452. Exclusion code: 3. [pmid: 15280342].
Greene MH, Mai PL. What have we learned from risk-reducing salpingo-oophorectomy. J. Natl. Cancer Inst. 2009;101(2):70-71. Exclusion code: 2. [pmid: 19141782].
Greene MH, Piedmonte M, Alberts D, et al. A prospective study of risk-reducing salpingo-oophorectomy and longitudinal CA-125 screening among women at increased genetic risk of ovarian cancer: design and baseline characteristics: a Gynecologic Oncology Group study. Cancer Epidemiol. Biomarkers Prev. 2008;17(3):594-604. Exclusion code: 5. [pmid: 18349277].
Gregory H, Wordsworth S, Gibbons B, Wilson B, Haites N. Risk estimation for familial breast cancer: improving the system of counselling. Eur. J. Hum. Genet. 2007;15(11):1139-1144. Exclusion code: 8. [pmid: 17637807].
Griebsch I, Brown J, Boggis C, et al. Cost-effectiveness of screening with contrast enhanced magnetic resonance imaging vs X-ray mammography of women at a high familial risk of breast cancer. Br. J. Cancer. 2006;95(7):801-810. Exclusion code: 8. [pmid: 17016484].
Grindedal EM, Renkonen-Sinisalo L, Vasen H, et al. Survival in women with MMR mutations and ovarian cancer: a multicentre study in Lynch syndrome kindreds. J. Med. Genet. 2010;47(2):99-102. Exclusion code: 3. [pmid: 19635727].
Gronwald J, Byrski T, Huzarski T, et al. A survey of preventive measures among BRCA1 mutation carriers from Poland. Clin. Genet. 2007;71(2):153-157. Exclusion code: 8. [pmid: 17250664].
Gronwald J, Byrski T, Huzarski T, et al. Influence of selected lifestyle factors on breast and ovarian cancer risk in BRCA1 mutation carriers from Poland. Breast Cancer Res. Treat. 2006;95(2):105-109. Exclusion code: 8. [pmid: 16261399].
Gronwald J, Elsakov P, Gorski B, Lubinski J. High incidence of 4153delA BRCA1 gene mutations in Lithuanian breast- and breast-ovarian cancer families. Breast Cancer Res. Treat. 2005;94(2):111-113. Exclusion code: 3. [pmid: 16261409].
Gronwald J, Huzarski T, Byrski B, et al. Cancer risks in first degree relatives of BRCA1 mutation carriers: effects of mutation and proband disease status. J. Med. Genet. 2006;43(5):424-428. Exclusion code: 3. [pmid: 16227521].
Gronwald J, Huzarski T, Byrski T, et al. Direct-to-patient BRCA1 testing: the Twoj Styl experience. Breast Cancer Res. Treat. 2006;100(3):239-245. Exclusion code: 5. [pmid: 16807675].
Gronwald J, Tung N, Foulkes WD, et al. Tamoxifen and contralateral breast cancer in BRCA1 and BRCA2 carriers: an update. Int. J. Cancer. 2006;118(9):2281-2284. Exclusion code: 3. [pmid: 16331614].
Grzybowska E, Zientek H, Jasinska A, et al. High frequency of recurrent mutations in BRCA1 and BRCA2 genes in polish families with breast and ovarian cancer. Hum. Mutat. 2000;16(6):482-490. Exclusion code: 8. [pmid: 11102977].
Gu D, Zhuang L, Huang H, et al. TGFB1 T29C polymorphism and breast cancer risk: a meta-analysis based on 10,417 cases and 11,455 controls. Breast Cancer Res. Treat. 2010;123(3):857-861. Exclusion code: 8. [pmid: 20157775].
Guenard F, Labrie Y, Ouellette G, et al. Germline mutations in the breast cancer susceptibility gene PTEN are rare in high-risk non-BRCA1/2 French Canadian breast cancer families. Fam Cancer. 2007;6(4):483-490. Exclusion code: 8. [pmid: 17636424].
Gui GPH, Hogben RKF, Walsh G, A'Hern R, Eeles R. The incidence of breast cancer from screening women according to predicted family history risk: Does annual clinical examination add to mammography. Eur. J. Cancer. 2001;37(13):1668-1673. Exclusion code: 8. [pmid: 11527694].
Gui GPH, Kadayaprath G, Darhouse N, et al. Clinical outcome and service implications of screening women at increased breast cancer risk from a family history. Eur. J. Surg. Oncol. 2006;32(7):719-724. Exclusion code: 4. [pmid: 16784834].
Guirguis-Blake J. Cancer genetic risk assessment for individuals at risk of familial breast cancer. Am. Fam. Physician. 2008;77(4):449-450. Exclusion code: 5. [pmid: 18326163].
Gulden C, Olopade OI. Risk assessment and genetic testing for ovarian cancer. Am. J. Roentgenol. 2010;194(2):309-310. Exclusion code: 5. [pmid: 20093589].
Guo S, Yang S, Taylor C, Sonenshein GE. Green tea polyphenol epigallocatechin-3 gallate (EGCG) affects gene expression of breast cancer cells transformed by the carcinogen 7,12-dimethylbenz[a]anthracene. J. Nutr. 2005;135(12 Suppl):2978S-2986S. Exclusion code: 4. [pmid: 16317158].
Gurmankin Levy A, Micco E, Putt M, Armstrong K. Value for the future and breast cancer-preventive health behavior. Cancer Epidemiol. Biomarkers Prev. 2006;15(5):955-960. Exclusion code: 8. [pmid: 16702376].
Gutierrez-Enriquez S, de la Hoya M, Martinez-Bouzas C, et al. Screening for large rearrangements of the BRCA2 gene in Spanish families with breast/ovarian cancer. Breast Cancer Res. Treat. 2007;103(1):103-107. Exclusion code: 3. [pmid: 17063271].
Haakensen VD, Biong M, Lingjaerde OC, et al. Expression levels of uridine 5'-diphospho-glucuronosyltransferase genes in breast tissue from healthy women are associated with mammographic density. Breast Cancer Res. 2010;12(4):R65. Exclusion code: 8. [pmid: 20799965].
Haas JS, Kaplan CP, Des Jarlais G, Gildengoin V, Perez-Stable EJ, Kerlikowske K. Perceived risk of breast cancer among women at average and increased risk. J Womens Health. 2005;14(9):845-851. Exclusion code: 8. [pmid: 16313212].
Hadley DW, Ashida S, Jenkins JF, et al. Generation after generation: exploring the psychological impact of providing genetic services through a cascading approach. Genet Med. 2010;12(12):808-815. Exclusion code: 3. [pmid: 20921894].
Haffty BG, Choi DH, Goyal S, et al. Breast cancer in young women (YBC): prevalence of BRCA1/2 mutations and risk of secondary malignancies across diverse racial groups. Ann. Oncol. 2009;20(10):1653-1659. Exclusion code: 3. [pmid: 19491284].
Haffty BG, Silber A, Matloff E, Chung J, Lannin D. Racial differences in the incidence of BRCA1 and BRCA2 mutations in a cohort of early onset breast cancer patients: African American compared to white women. J. Med. Genet. 2006;43(2):133-137. Exclusion code: 3. [pmid: 15983021].
Hagoel L, Neter E, Dishon S, Barnett O, Rennert G. BRCA1/2 mutation carriers: living with susceptibility. Community Genet. 2003;6(4):242-248. Exclusion code: 3. [pmid: 15331870].
Haile RW, Thomas DC, McGuire V, et al. BRCA1 and BRCA2 mutation carriers, oral contraceptive use, and breast cancer before age 50. Cancer Epidemiol. Biomarkers Prev. 2006;15(10):1863-1870. Exclusion code: 3. [pmid: 17021353].
Haiman CA, Hankinson SE, Spiegelman D, et al. Polymorphic repeat in AIB1 does not alter breast cancer risk. Breast Cancer Res. 2000;2(5):378-385. Exclusion code: 8. [pmid: 11056690].
Halapy E, Chiarelli AM, Klar N, Knight JA. Accuracy of breast screening among women with and without a family history of breast and/or ovarian cancer. Breast Cancer Res. Treat. 2005;90(3):299-305. Exclusion code: 3. [pmid: 15830144].
Halbert C, Kessler L, Collier A, Paul Wileyto E, Brewster K, Weathers B. Psychological functioning in African American women at an increased risk of hereditary breast and ovarian cancer. Clin. Genet. 2005;68(3):222-227. Exclusion code: 3. [pmid: 16098010].
Halbert CH. Decisions and outcomes of genetic testing for inherited breast cancer risk. Ann. Oncol. 2004;15(Suppl 1):I35-I39. Exclusion code: 8. [pmid: 15280185].
Halbert CH. Genetic counseling and testing for breast cancer risk in African Americans. LDI Issue Brief. 2006;12(1):1-4. Exclusion code: 5. [pmid: 17302016].
Halbert CH, Kessler L, Stopfer JE, Domchek S, Wileyto EP. Low rates of acceptance of BRCA1 and BRCA2 test results among African American women at increased risk for hereditary breast-ovarian cancer. Genet Med. 2006;8(9):576-582. Exclusion code: 8. [pmid: 16980814].
Halbert CH, Kessler L, Troxel AB, Stopfer JE, Domchek S. Effect of genetic counseling and testing for BRCA1 and BRCA2 mutations in African American women: a randomized trial. Public Health Genomics. 2010;13(7-8):440-448. Exclusion code: 3. [pmid: 20234119].
Halbert CH, Kessler L, Wileyto EP, et al. Breast cancer screening behaviors among African American women with a strong family history of breast cancer. Prev. Med. 2006;43(5):385-388. Exclusion code: 8. [pmid: 16860380].
Halbert CH, Kessler LJ, Mitchell E. Genetic testing for inherited breast cancer risk in African Americans. Cancer Invest. 2005;23(4):285-295. Exclusion code: 6. [pmid: 16100940].
Halbert CH, Schwartz MD, Wenzel L, et al. Predictors of cognitive appraisals following genetic testing for BRCA1 and BRCA2 mutations. J. Behav. Med. 2004;27(4):373-392. Exclusion code: 3. [pmid: 15559734].
Halbert CH, Stopfer JE, McDonald J, et al. Long-Term Reactions to Genetic Testing for BRCA1 and BRCA2 Mutations: Does Time Heal Women's Concerns. J. Clin. Oncol. 2011;29(32):4302-4306. Exclusion code: 3. [pmid: 21990416].
Halbert CH, Wenzel L, Lerman C, et al. Predictors of participation in psychosocial telephone counseling following genetic testing for BRCA1 and BRCA2 mutations. Cancer Epidemiol. Biomarkers Prev. 2004;13(5):875-881. Exclusion code: 8. [pmid: 15159322].
Haldar K, Crawford R. Risk-reducing salpingo-oophorectomy for BRCA mutation carriers. Maturitas. 2010;67(3):290. Exclusion code: 5. [pmid: 20869823].
Hall J, Gray S, A'Hern R, et al. Genetic testing for BRCA1: effects of a randomised study of knowledge provision on interest in testing and long term test uptake; implications for the NICE guidelines. Fam Cancer. 2009;8(1):5-13. Exclusion code: 8. [pmid: 18679829].
Hall MJ, Reid JE, Burbidge LA, et al. BRCA1 and BRCA2 mutations in women of different ethnicities undergoing testing for hereditary breast-ovarian cancer. Cancer. 2009;115(10):2222-2233. Exclusion code: 2. [pmid: 19241424].
Hallowell N, Baylock B, Heiniger L, et al. Looking different, feeling different: women's reactions to risk-reducing breast and ovarian surgery. Fam Cancer. 2012;11(2):215-224. Exclusion code: 8. [pmid: 22198037].
Hamann HA, Somers TJ, Smith AW, Inslicht SS, Baum A. Posttraumatic stress associated with cancer history and BRCA1/2 genetic testing. Psychosom. Med. 2005;67(5):766-772. Exclusion code: 3. [pmid: 16204436].
Hamann U, Sinn HP. Survival and tumor characteristics of German hereditary breast cancer patients. Breast Cancer Res. Treat. 2000;59(2):185-192. Exclusion code: 6. [pmid: 10817354].
Hamilton JG, Lobel M, Moyer A. Emotional distress following genetic testing for hereditary breast and ovarian cancer: a meta-analytic review. Health Psychol. 2009;28(4):510-518. Exclusion code: 3. [pmid: 19594276].
Hamilton R, William JK, Bowers BJ, Calzone K. Life trajectories, genetic testing, and risk reduction decisions in 18-39 year old women at risk for hereditary breast and ovarian cancer. J Genet Couns. 2009;18(2):147-159. Exclusion code: 3. [pmid: 18979190].
Hamilton R, Williams JK, Skirton H, Bowers BJ. Living with genetic test results for hereditary breast and ovarian cancer. J Nurs Scholarsh. 2009;41(3):276-283. Exclusion code: 2. [pmid: 19723276].
Hamilton RJ, Bowers BJ, Williams JK. Disclosing genetic test results to family members. J Nurs Scholarsh. 2005;37(1):18-24. Exclusion code: 8. [pmid: 15813582].
Hampel H, Sweet K, Westman JA, Offit K, Eng C. Referral for cancer genetics consultation: a review and compilation of risk assessment criteria. J. Med. Genet. 2004;41:81-91. Exclusion code: 2. [pmid: 14757853].
Hankinson SE, Colditz GA, Hunter DJ, Spencer TL, Rosner B, Stampfer MJ. A quantitative assessment of oral contraceptive use and risk of ovarian cancer. Obstet. Gynecol. 1992;80(4):708-714. Exclusion code: 6. [pmid: 1407899].
Hanoch Y, Miron-Shatz T, Himmelstein M. Genetic testing and risk interpretation: How do women understand lifetime risk results. Judgment and Decision Making. 2010;5(2):116-123. Exclusion code: 8.
Harlid S, Ivarsson MIL, Butt S, et al. Combined effect of low-penetrant SNPs on breast cancer risk. Br. J. Cancer. 2012;106(2):389-396. Exclusion code: 4. [pmid: 22045194].
Harris H, Nippert I, Julian-Reynier C, et al. Familial breast cancer: is it time to move from a reactive to a proactive role. Fam Cancer. 2011;10(3):501-503. Exclusion code: 5. [pmid: 21400222].
Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am. J. Prev. Med. 2001;20(3, Supplement 1):21-35. Exclusion code: 2. [pmid: 11306229].
Hartmaier RJ, Tchatchou S, Richter AS, et al. Nuclear receptor coregulator SNP discovery and impact on breast cancer risk. BMC Cancer. 2009;9. Exclusion code: 4. [pmid: 20003447].
Hartman AR, Daniel BL, Kurian AW, et al. Breast Magnetic Resonance Image Screening and Ductal Lavage in Women at High Genetic Risk for Breast Carcinoma. Cancer. 2004;100(3):479-489. Exclusion code: 3. [pmid: 14745863].
Hartmann LC, Degnim A, Schaid DJ. Prophylactic mastectomy for BRCA1/2 carriers: Progress and more questions. J. Clin. Oncol. 2004;22(6):981-983. Exclusion code: 5. [pmid: 14981099].
Hashemian AH, Hajizadeh E, Kazemnejad A, Atri M, Mehdipour P. Penetrance of BRCA1/BRCA2 specific gene mutations in Iranian women with breast cancer. Saudi Med J. 2009;30(1):41-44. Exclusion code: 3. [pmid: 19139771].
Hatcher MB, Fallowfield L, A'Hern R. The psychosocial impact of bilateral prophylactic mastectomy: prospective study using questionnaires and semistructured interviews. BMJ. 2001;322(7278):76. Exclusion code: 5. [pmid: 11154619].
Hay JL, McCaul KD, Magnan RE. Does worry about breast cancer predict screening behaviors? A meta-analysis of the prospective evidence. Prev. Med. 2006;42(6):401-408. Exclusion code: 8. [pmid: 16626796].
Genetic testing for susceptibility to ovarian cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000101. Exclusion code: 5.
Breast cancer susceptibility 1 and 2 (BRCA1/2) sequence variant testing for susceptibility to hereditary breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000063. Exclusion code: 5.
Comprehensive screening for large rearrangements in BRCA1/2 for assessment of breast cancer risk (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000070. Exclusion code: 5.
Gene expression profiling for prognosis of recurrence of primary breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000100. Exclusion code: 5.
BRCA1 and BRCA2 sequence variant analysis for susceptibility to hereditary ovarian cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000959. Exclusion code: 5.
MammaPrint for prognosis of breast cancer recurrence (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32011001341. Exclusion code: 5.
Impact of intensive screening in women with an increased risk of breast cancer because of a familiar predisposition - primary research (Brief record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32005000528. Exclusion code: 5.
Mammography in women under 50 by GP in families with hereditary breast cancer - primary research (Brief record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32005000531. Exclusion code: 5.
Evaluation of mammographic surveillance services in women under 50 with a family history of breast cancer (Project record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32003000271. Exclusion code: 5.
Heemskerk-Gerritsen BAM, Brekelmans CTM, Menke-Pluymers MBE, et al. Prophylactic mastectomy in BRCA1/2 mutation carriers and women at risk of hereditary breast cancer: long-term experiences at the Rotterdam Family Cancer Clinic. Ann. Surg. Oncol. 2007;14(12):3335-3344. Exclusion code: 3. [pmid: 17541692].
Heijnsdijk EAM, Warner E, Gilbert FJ, et al. Differences in natural history between breast cancers in BRCA1 and BRCA2 mutation carriers and effects of MRI screening-MRISC, MARIBS, and Canadian studies combined. Cancer Epidemiol. Biomarkers Prev. 2012;21(9):1458-1468. Exclusion code: 2. [pmid: 22744338].
Helmes AW, Bowen DJ, Bowden R, Bengel J. Predictors of participation in genetic research in a primary care physician network. Cancer Epidemiol. Biomarkers Prev. 2000;9(12):1377-1379. Exclusion code: 8. [pmid: 11142425].
Herman J. Evaluating women with ovarian cancer for BRCA1 and BRCA2 mutations: missed opportunities. Obstet. Gynecol. 2010;116(2 Pt 1):440-441. author reply 441. Exclusion code: 5. [pmid: 20664408].
Herman JD, Appelbaum H. Hereditary breast and ovarian cancer syndrome and issues in pediatric and adolescent practice. J. Pediatr. Adolesc. Gynecol. 2010;23(4):253-258. Exclusion code: 3. [pmid: 20632459].
Herrinton LJ, Barlow WE, Yu O, et al. Efficacy of prophylactic mastectomy in women with unilateral breast cancer: A cancer research network project. J. Clin. Oncol. 2005;23(19):4275-4286. Exclusion code: 3. [pmid: 15795415].
Heshka JT, Palleschi C, Howley H, Wilson B, Wells PS. A systematic review of perceived risks, psychological and behavioral impacts of genetic testing. Genet Med. 2008;10(1):19-32. Exclusion code: 2. [pmid: 18197053].
Higgins J, Thompson S. Quantifying heterogeneity in a meta-analysis. Stat. Med. 2002;21:1539-1558. Exclusion code: 2. [pmid: 12111919].
Hilgart JS, Coles B, Iredale R. Cancer genetic risk assessment for individuals at risk of familial breast cancer. Cochrane Database Syst Rev. 2012;2:CD003721. Exclusion code: 5. [pmid: 22336791].
Ho L, Fivecoat H, Wang J, Pasinetti GM. Alzheimer's disease biomarker discovery in symptomatic and asymptomatic patients: Experimental approaches and future clinical applications. Exp. Gerontol. 2010;45(1):15-22. Exclusion code: 3. [pmid: 19796674].
Hofman KJ, Tambor ES, Chase GA, Geller G, Faden RR, Holtzman NA. Physicians' knowledge of genetics and genetic tests. Acad. Med. 1993;68(8):625-632. Exclusion code: 6. [pmid: 8352875].
Holloway S, Porteous M, Cetnarskyj R, et al. Patient satisfaction with two different models of cancer genetic services in south-east Scotland. Br. J. Cancer. 2004;90(3):582-589. Exclusion code: 6. [pmid: 14760368].
Holloway SM, Bernhard B, Campbell H, Lam WWK. Uptake of testing for BRCA1/2 mutations in South East Scotland. Eur. J. Hum. Genet. 2008;16(8):906-912. Exclusion code: 8. [pmid: 18285832].
Hooker GW, Leventhal KG, DeMarco T, et al. Longitudinal changes in patient distress following interactive decision aid use among BRCA1/2 carriers: a randomized trial. Med. Decis. Making. 2011;31(3):412-421. Exclusion code: 3. [pmid: 20876346].
Hopwood P. Psychosocial aspects of risk communication and mutation testing in familial breast-ovarian cancer. Curr. Opin. Oncol. 2005;17(4):340-344. Exclusion code: 8. [pmid: 15933464].
Hopwood P, Fletcher I, Lee A, Al Ghazal S. A body image scale for use with cancer patients. Eur. J. Cancer. 2001;37(2):189-197. Exclusion code: 2. [pmid: 11166145].
Hopwood P, Howell A, Lalloo F, Evans G. Do women understand the odds? Risk perceptions and recall of risk information in women with a family history of breast cancer. Community Genet. 2003;6(4):214-223. Exclusion code: 6. [pmid: 15331867].
Hopwood P, Shenton A, Lalloo F, Evans DGR, Howell A. Risk perception and cancer worry: An exploratory study of the impact of genetic risk counselling in women with a family history of breast cancer [12]. J. Med. Genet. 2001;38(2):139-142. Exclusion code: 6. [pmid: 11288719].
Hopwood P, van Asperen CJ, Borreani G, et al. Cancer genetics service provision: a comparison of seven European centres. Community Genet. 2003;6(4):192-205. Exclusion code: 8. [pmid: 15331865].
Hopwood P, Watson M. Genetic susceptibility to breast/ovarian cancer. Psycho-Oncology. 2nd ed. New York, NY. Oxford University Press, US. 2010:105-109. Exclusion code: 5.
Horowitz M, Wilner N, Alvarez W. Impact of event scale: A measure of subjective stress. Psychosom. Med. 1979;41(3):209-218. Exclusion code: 6. [pmid: 472086].
Horsman D, Wilson BJ, Avard D, et al. Clinical management recommendations for surveillance and risk-reduction strategies for hereditary breast and ovarian cancer among individuals carrying a deleterious BRCA1 or BRCA2 mutation. J Obstet Gynaecol Can. 2007;29(1):45-60. Exclusion code: 5. [pmid: 17346477].
Hoskins LM. Negotiation of health risks and risk management for young adult brca1/2-positive women: Implications for partnering and family formation. Hoskins, Lindsey M. U Maryland. Coll Park, US. 2011. Exclusion code: 5.
Hoskins LM, Roy K, Peters JA, Loud JT, Greene MH. Disclosure of positive BRCA1/2-mutation status in young couples: The journey from uncertainty to bonding through partner support. Fam Syst Health. 2008;26(3):296-316. Exclusion code: 8.
Hoskins LM, Roy KM, Greene MH. Toward a new understanding of risk perception among young female BRCA1/2 “previvors”. Fam Syst Health. 2012;30(1):32-46. Exclusion code: 5. [pmid: 22429077].
Howard A, Balneaves LG, Bottorff JL. Women's decision making about risk-reducing strategies in the context of hereditary breast and ovarian cancer: A systematic review. J Genet Couns. 2009;18(6):578-597. Exclusion code: 8. [pmid: 19802692].
Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2008. 2011. http://seer.cancer.gov/csr/1975_2008/. 16 Oct, 2012. Exclusion code: 2.
Hu Z, Song CG, Lu JS, et al. A multigenic study on breast cancer risk associated with genetic polymorphisms of ER Alpha, COMT and CYP19 gene in BRCA1/BRCA2 negative Shanghai women with early onset breast cancer or affected relatives. J Cancer Res Clin Oncol. 2007;133(12):969-978. Exclusion code: 8. [pmid: 17562079].
Hu Z, Wu J, Lu JS, et al. Analysis of BRCA1 mutations in Chinese patients with early onset breast cancer and affected relatives. Zhonghua Zhong Liu Za Zhi. 2004;26(11):657-659. Exclusion code: 7. [pmid: 15777502].
Hughes DJ. Use of association studies to define genetic modifiers of breast cancer risk in BRCA1 and BRCA2 mutation carriers. Fam Cancer. 2008;7(3):233-244. Exclusion code: 8. [pmid: 18283561].
Hughes DJ, Ginolhac SM, Coupier I, et al. Breast cancer risk in BRCA1 and BRCA2 mutation carriers and polyglutamine repeat length in the AIB1 gene. Int. J. Cancer. 2005;117(2):230-233. Exclusion code: 8. [pmid: 15900600].
Hulbert-Williams N, Neal R, Morrison V, Hood K, Wilkinson C. Anxiety, depression and quality of life after cancer diagnosis: What psychosocial variables best predict how patients adjust. Psychooncology. 2012;21(8):857-867. Exclusion code: 3. [pmid: 21695744].
Huo D, Senie RT, Daly M, et al. Prediction of BRCA Mutations Using the BRCAPRO Model in Clinic-Based African American, Hispanic, and Other Minority Families in the United States. J. Clin. Oncol. 2009;27(8):1184-1190. Exclusion code: 3. [pmid: 19188678].
Huo X, Hu Z, Zhai X, et al. Common non-synonymous polymorphisms in the BRCA1 Associated RING Domain (BARD1) gene are associated with breast cancer susceptibility: a case-control analysis. Breast Cancer Res. Treat. 2007;102(3):329-337. Exclusion code: 8. [pmid: 17028982].
Huo X, Lu C, Huang X, et al. Polymorphisms in BRCA1, BRCA1-interacting genes and susceptibility of breast cancer in Chinese women. J. Cancer Res. Clin. Oncol. 2009;135(11):1569-1575. Exclusion code: 8. [pmid: 19484476].
Huys I, Van Overwalle G, Matthijs G. Gene and genetic diagnostic method patent claims: a comparison under current European and US patent law. Eur. J. Hum. Genet. 2011;19(10):1104-1107. Exclusion code: 5. [pmid: 21654725].
Hwang ES, McLennan JL, Moore DH, Crawford BB, Esserman LJ, Ziegler JL. Ductal carcinoma in situ in BRCA mutation carriers. J. Clin. Oncol. 2007;25(6):642-647. Exclusion code: 3. [pmid: 17210933].
IBIS Investigators. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002;360(9336):817-824. Exclusion code: 2. [pmid: 12243915].
Ibrahim SS, Hafez EE, Hashishe MM. Presymptomatic breast cancer in Egypt: role of BRCA1 and BRCA2 tumor suppressor genes mutations detection. J. Exp. Clin. Cancer Res. 2010;29:82. Exclusion code: 3. [pmid: 20579331].
Ikeda N, Miyoshi Y, Yoneda K, et al. Frequency of BRCA1 and BRCA2 germline mutations in Japanese breast cancer families. Int. J. Cancer. 2001;91(1):83-88. Exclusion code: 8. [pmid: 11149425].
Infante M, Durán M, Acedo A, et al. BRCA1 5272-1G>A and BRCA2 5374delTATG are founder mutations of high relevance for genetic counselling in breast/ovarian cancer families of Spanish origin. Clin. Genet. 2010;77(1):60-69. Exclusion code: 4. [pmid: 19912264].
Inumaru LE, Silveira EA, Naves MM. Risk and protective factors for breast cancer: a systematic review. Cad. Saude Publica. 2011;27(7):1259-1270. Exclusion code: 7. [pmid: 21808811].
Iredale R, Rapport F, Sivell S, et al. Exploring the requirements for a decision aid on familial breast cancer in the UK context: a qualitative study with patients referred to a cancer genetics service. J. Eval. Clin. Pract. 2008;14(1):110-115. Exclusion code: 8. [pmid: 18211652].
Jackson C. The General Health Questionnaire. Occup. Med. 2007;57(1):79. Exclusion code: 2.
Jacobi CE, de Bock GH, Siegerink B, van Asperen CJ. Differences and similarities in breast cancer risk assessment models in clinical practice: which model to choose. Breast Cancer Res. Treat. 2009;115(2):381-390. Exclusion code: 6. [pmid: 18516672].
Jacobs I. Screening for familial ovarian cancer: The need for well-designed prospective studies. J. Clin. Oncol. 2005;23(24):5443-5445. Exclusion code: 5. [pmid: 16110006].
Jager M, Oosterwijk J, Middel B, Hoekstra-Weebers J. Motivation to participate in genetic counseling and cancer worry of women with a high family risk for hereditary breast/ovarian cancer: Differences between women who choose for DNA research and those who decline. Gedrag & Gezondheid: Tijdschrift voor Psychologie en Gezondheid. 2004;32(1):18-27. Exclusion code: 7.
Jakubowska A, Gronwald J, Menkiszak J, et al. BRCA1-associated breast and ovarian cancer risks in Poland: no association with commonly studied polymorphisms. Breast Cancer Res. Treat. 2010;119(1):201-211. Exclusion code: 8. [pmid: 19360465].
Jakubowska A, Jaworska K, Cybulski C, et al. Do BRCA1 modifiers also affect the risk of breast cancer in non-carriers. Eur. J. Cancer. 2009;45(5):837-842. Exclusion code: 3. [pmid: 19071013].
Janiszewska H, Haus O, Lauda-Œwieciak A, et al. Frequency of three BRCA1 gene founder mutations in breast/ovarian cancer families from the Pomerania-Kujawy region of Poland. Clin. Genet. 2003;64(6):502-508. Exclusion code: 4. [pmid: 14986830].
Jara L, Ampuero S, Santibanez E, et al. BRCA1 and BRCA2 mutations in a South American population. Cancer Genet. Cytogenet. 2006;166(1):36-45. Exclusion code: 3. [pmid: 16616110].
Jhanwar SM. Influence of body image on intentions for prophylactic mastectomy. Jhanwar, Sabrina M. Yeshiva U. US. 2012. Exclusion code: 8.
John E, Miron A, Gong G, et al. Prevalence of pathogenic BRCA1 mutation carriers in 5 U.S. racial/ethnic groups. JAMA. 2007;298(24):2869-2876. Exclusion code: 2. [pmid: 18159056].
Johnson N, Lancaster T, Fuller A. The prevalence of a family history of cancer in general practice. Fam. Pract. 1995;12(3):287-289. Exclusion code: 2. [pmid: 8536831].
Jones AL. Chemoprevention of breast cancer (The British tamoxifen trials). Canadian Journal of Infectious Diseases. 1995;6(Suppl C):193C. Exclusion code: 5.
Jones JL, Hughes KS, Kopans DB, et al. Evaluation of hereditary risk in a mammography population. Clin Breast Cancer. 2005;6(1):38-44. Exclusion code: 8. [pmid: 15899071].
Joo JG, Csanad M, Toth K, Mate S, Nagy BZ. Risk assessment in familial breast cancer. Orv. Hetil. 2011;152(19):758-762. Exclusion code: 7. [pmid: 21498166].
Joo JG, Ladi S, Nagy BZ, Langmar Z. Management of hereditary ovarian cancer. Orv. Hetil. 2011;152(40):1596-1608. Exclusion code: 7. [pmid: 21945869].
Joo JG, Ladi S, Nagy BZ, Langmar Z. Managment of herediatry ovarian cancer. Orv. Hetil. 2011;152(40):1596-1608. Exclusion code: 7. [pmid: 21945869].
Joosse SA, van Beers EH, Tielen IHG, et al. Prediction of BRCA1-association in hereditary non-BRCA1/2 breast carcinomas with array-CGH. Breast Cancer Res. Treat. 2009;116(3):479-489. Exclusion code: 3. [pmid: 18704682].
Jorgensen TJ, Helzlsouer KJ, Clipp SC, Bolton JH, Crum RM, Visvanathan K. DNA repair gene variants associated with benign breast disease in high cancer risk women. Cancer Epidemiol. Biomarkers Prev. 2009;18(1):346-350. Exclusion code: 8. [pmid: 19124519].
Joseph G, Beattie MS, Lee R, et al. Precounseling education for low literacy women at risk of Hereditary Breast and Ovarian Cancer (HBOC): patient experiences using the Cancer Risk Education Intervention Tool (CREdIT). J Genet Couns. 2010;19(5):447-462. Exclusion code: 8. [pmid: 20490636].
Julian-Reynier C. Genetic predisposition to breast and ovarian cancer: importance of test results. Med Sci (Paris). 2011;27(6-7):657-661. Exclusion code: 7. [pmid: 21718651].
Julian-Reynier C, Bouhnik AD, Mouret-Fourme E, et al. Time to prophylactic surgery in BRCA1/2 carriers depends on psychological and other characteristics. Genet Med. 2010;12(12):801-807. Exclusion code: 8. [pmid: 20921896].
Kadouri L, Hubert A, Rotenberg Y, et al. Cancer risks in carriers of the BRCA1/2 Ashkenazi founder mutations. J. Med. Genet. 2007;44(7):467-471. Exclusion code: 3. [pmid: 17307836].
Kadouri L, Kote-Jarai Z, Easton DF, et al. Polyglutamine repeat length in the AIB1 gene modifies breast cancer susceptibility in BRCA1 carriers. Int. J. Cancer. 2004;108(3):399-403. Exclusion code: 8. [pmid: 14648706].
Kalfoglou EA, Faikoglu R, Ozcan S, Petridis G, Yukseloglu H, Atasoy S. DNA analysis as a tool for breast cancer malpractice determination: an interdisciplinary approach. Oncol. Rep. 2006;16(1):203-206. Exclusion code: 5. [pmid: 16786147].
Kandel MJ, Stadler Z, Masciari S, et al. Prevalence of BRCA1 mutations in triple negative breast cancer (BC). Journal of Clinical Oncology: ASCO annual meeting proceedings. 2006;24:508. Exclusion code: 3.
Kang HH, Williams R, Leary J, et al. Evaluation of models to predict BRCA germline mutations. Br. J. Cancer. 2006;95(7):914-920. Exclusion code: 3. [pmid: 17016486].
Kang P, Mariapun S, Phuah SY, et al. Large BRCA1 and BRCA2 genomic rearrangements in Malaysian high risk breast-ovarian cancer families. Breast Cancer Res. Treat. 2010;124(2):579-584. Exclusion code: 3. [pmid: 20617377].
Kaphingst KA, McBride CM. Patient responses to genetic information: Studies of patients with hereditary cancer syndromes identify issues for use of genetic testing in nephrology practice. Semin. Nephrol. 2010;30(2):203-214. Exclusion code: 8. [pmid: 20347649].
Karlan BY, Baldwin RL, Lopez-Luevanos E, et al. Peritoneal serous papillary carcinoma, a phenotypic variant of familial ovarian cancer: Implications for ovarian cancer screening. Am. J. Obstet. Gynecol. 1999;180(4):917-928. Exclusion code: 3. [pmid: 10203660].
Karlan BY, Berchuck A, Mutch D. The role of genetic testing for cancer susceptibility in gynecologic practice. Obstet. Gynecol. 2007;110(1):155-167. Exclusion code: 5. [pmid: 17601911].
Karliner LS, Napoles-Springer A, Kerlikowske K, Haas JS, Gregorich SE, Kaplan CP. Missed opportunities: family history and behavioral risk factors in breast cancer risk assessment among a multiethnic group of women. J. Gen. Intern. Med. 2007;22(3):308-314. Exclusion code: 8. [pmid: 17356960].
Kasparian NA, Wakefield CE, Meiser B. Assessment of psychosocial outcomes in genetic counseling research: an overview of available measurement scales. J Genet Couns. 2007;16(6):693-712. Exclusion code: 5. [pmid: 17694397].
Katapodi MC, Aouizerat BE. Do women in the community recognize hereditary and sporadic breast cancer risk factors. Oncol. Nurs. Forum. 2005;32(3):617-623. Exclusion code: 8. [pmid: 15897936].
Katapodi MC, Dodd MJ, Lee KA, Facione NC. Underestimation of breast cancer risk: influence on screening behavior. Oncol. Nurs. Forum. 2009;36(3):306-314. Exclusion code: 4. [pmid: 19403452].
Katapodi MC, Northouse L, Pierce P, Milliron KJ, Liu C, Merajver SD. Differences between women who pursued genetic testing for hereditary breast and ovarian cancer and their at-risk relatives who did not. Oncol. Nurs. Forum. 2011;38(5):572-581. Exclusion code: 8. [pmid: 21875844].
Kauff ND, Barakat RR. Risk-reducing salpingo-oophorectomy in patients with germline mutations in BRCA1 or BRCA2. J. Clin. Oncol. 2007;25(20):2921-2927. Exclusion code: 5. [pmid: 17617523].
Kauff ND, Domcheck SM, Friebel TM, et al. Multi-center prospective analysis of risk-reducing salpingo-oophorectomy to prevent BRCA-associated breast and ovarian cancer. Journal of Clinical Oncology : ASCO annual meeting proceedings. 2006;24:1003. Exclusion code: 5.
Kauff ND, Domchek SM, Friebel TM, et al. Risk-reducing salpingo-oophorectomy for the prevention of BRCA1- and BRCA2-associated breast and gynecologic cancer: a multicenter, prospective study. J. Clin. Oncol. 2008;26(8):1331-1337. Exclusion code: 3. [pmid: 18268356].
Kauff ND, Offit K. Modeling genetic risk of breast cancer. JAMA. 2007;297(23):2637-2639. Exclusion code: 5. [pmid: 17579233].
Kauff ND, Satagopan JM, Robson ME, et al. Risk-reducing salpingo-oophorectomy in women with a BRCA1 or BRCA2 mutation. N. Engl. J. Med. 2002;346(21):1609-1615. Exclusion code: 3. [pmid: 12023992].
Keating NL, Stoeckert KA, Regan MM, DiGianni L, Garber JE. Physicians' experiences with BRCA1/2 testing in community settings. J. Clin. Oncol. 2008;26(35):5789-5796. Exclusion code: 3. [pmid: 19001322].
Kelly K, Leventhal H, Andrykowski M, et al. The decision to test in women receiving genetic counseling for BRCA1 and BRCA2 mutations. J Genet Couns. 2004;13(3):237-257. Exclusion code: 3. [pmid: 15604634].
Kelly K, Leventhal H, Andrykowski M, et al. Using the common sense model to understand perceived cancer risk in individuals testing for BRCA1/2 mutations. Psychooncology. 2005;14(1):34-48. Exclusion code: 3. [pmid: 15386791].
Kelly K, Leventhal H, Marvin M, Toppmeyer D, Baran J, Schwalb M. Cancer genetics knowledge and beliefs and receipt of results in Ashkenazi Jewish individuals receiving counseling for BRCA1/2 mutations. Cancer Control. 2004;11(4):236-244. Exclusion code: 3. [pmid: 15284715].
Kelly K, Leventhal H, Marvin M, et al. Subjective and objective risk of breast cancer in Ashkenazi Jewish individuals at risk for BRCA1/2 mutations. Genet Test. 2004;8(2):139-147. Exclusion code: 8. [pmid: 15345111].
Kenen R, Ardern-Jones A, Eeles R. Family stories and the use of heuristics: women from suspected hereditary breast and ovarian cancer (HBOC) families. Sociol. Health Illn. 2003;25(7):838-865. Exclusion code: 8. [pmid: 19774749].
Kenen R, Ardern-Jones A, Lynch E, Eeles R. Ownership of uncertainty: healthcare professionals counseling and treating women from hereditary breast and ovarian cancer families who receive an inconclusive BRCA1/2 genetic test result. Genet Test Mol Biomarkers. 2011;15(4):243-250. Exclusion code: 3. [pmid: 21254913].
Keogh LA, Hopper JL, Rosenthal D, Phillips K. Australian clinicians and chemoprevention for women at high familial risk for breast cancer. Hered Cancer Clin Pract. 2009;7(1). Exclusion code: 3. [pmid: 19409108].
Keogh LA, Southey MC, Maskiell J, et al. Uptake of offer to receive genetic information about BRCA1 and BRCA2 mutations in an Australian population-based study. Cancer Epidemiol. Biomarkers Prev. 2004;13(12):2258-2263. Exclusion code: 8. [pmid: 15598789].
Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am. J. Epidemiol. 1997;146(3):244-248. Exclusion code: 2. [pmid: 9247008].
Kerlikowske K, Carney PA, Geller B, et al. Performance of screening mammography among women with and without a first-degree relative with breast cancer. Ann. Intern. Med. 2000;133(11):855-863. Exclusion code: 2. [pmid: 11103055].
Kerlikowske K, Grady D, Barclay J, Sickles EA, Ernster V. Effect of age, breast density, and family history on the sensitivity of first screening mammography. JAMA. 1996;276(1):33-38. Exclusion code: 2. [pmid: 8667536].
Keshavarzi F, Javadi GR, Zeinali S. BRCA1 and BRCA2 germline mutations in 85 Iranian breast cancer patients. Fam Cancer. 2012;11(1):57-67. Exclusion code: 3. [pmid: 21918854].
Kessler L, Collier A, Brewster K, et al. Attitudes about genetic testing and genetic testing intentions in African American women at increased risk for hereditary breast cancer. Genet Med. 2005;7(4):230-238. Exclusion code: 3. [pmid: 15834240].
Kessler L, Domchek S, Stopfer J, Halbert CH. BRCA1 and BRCA2 risk perceptions among African American women at increased risk for hereditary breast-ovarian cancer. Community Genet. 2008;11(4):193-200. Exclusion code: 3. [pmid: 18417966].
Kets CM, Niermeijer MF, Massuger LFAG, Hoogerbrugge N. In cases of familial ovarian cancer, always consider the risk of breast cancer. Ned. Tijdschr. Geneeskd. 2004;148(35):1709-1711. Exclusion code: 7. [pmid: 15468897].
Khoury MJ, Feero WG, Reyes M, et al. The genomic applications in practice and prevention network. Genet Med. 2009;11(7):488-494. Exclusion code: 5. [pmid: 19471162].
Kiechle M. Genetic testing in patients at risk for carcinoma of the breast. Dtsch. Med. Wochenschr. 2006;131(43):2420-2422. Exclusion code: 7. [pmid: 17054060].
Kiely BE, Jenkins MA, McKinley JM, et al. Contralateral risk-reducing mastectomy in BRCA1 and BRCA2 mutation carriers and other high-risk women in the Kathleen Cuningham Foundation Consortium for Research into Familial Breast Cancer (kConFab). Breast Cancer Res. Treat. 2010;120(3):715-723. Exclusion code: 3. [pmid: 19669874].
King HM. Risk reduction decision making in women with BRCA1/2 gene mutations. King, Heidi M. U South Florida. US. 2009. Exclusion code: 4.
King MC, Marks JH, Mandell JB. Breast and ovarian cancer risks due to inherited mutations in BRCA1 and BRCA2. Science. 2003;302(5645):643-646. Exclusion code: 2. [pmid: 14576434].
King MC, Wieand S, Hale K, et al. Tamoxifen and breast cancer incidence among women with inherited mutations in brca1 and brca2 national surgical adjuvant breast and bowel project (nsabp-p1) breast cancer prevention trial. JAMA. 2001;286(18):2251-2256. Exclusion code: 5. [pmid: 11710890].
Kinney AY, Gammon A, Coxworth J, Simonsen SE, Arce-Laretta M. Exploring attitudes, beliefs, and communication preferences of Latino community members regarding BRCA1/2 mutation testing and preventive strategies. Genet Med. 2010;12(2):105-115. Exclusion code: 3. [pmid: 20061960].
Kinney AY, Simonsen SE, Baty BJ, et al. Risk reduction behaviors and provider communication following genetic counseling and BRCA1 mutation testing in an African American kindred. J Genet Couns. 2006;15(4):293-305. Exclusion code: 8. [pmid: 16865561].
Kinney AY, Simonsen SE, Baty BJ, et al. Acceptance of genetic testing for hereditary breast ovarian cancer among study enrollees from an African American kindred. Am J Med Genet A. 2006;140(8):813-826. Exclusion code: 8. [pmid: 16523520].
Kirova YM, Stoppa-Lyonnet D, Savignoni A, Sigal-Zafrani B, Fabre N, Fourquet A. Risk of breast cancer recurrence and contralateral breast cancer in relation to BRCA1 and BRCA2 mutation status following breast-conserving surgery and radiotherapy. Eur. J. Cancer. 2005;41(15):2304-2311. Exclusion code: 2. [pmid: 16140006].
Kleibl Z, Havranek O, Kormunda S, et al. The AIB1 gene polyglutamine repeat length polymorphism and the risk of breast cancer development. J. Cancer Res. Clin. Oncol. 2011;137(2):331-338. Exclusion code: 8. [pmid: 20422428].
Klitzman R. Genetic testing creates new versions of ancient dilemmas. NY Times. 2006:F5. Exclusion code: 5. [pmid: 16429628].
Kodl MM, Lee JW, Matthews AK, Cummings SA, Olopade OI. Correlates of depressive symptoms among women seeking cancer genetic counseling and risk assessment at a high-risk cancer clinic. J Genet Couns. 2006;15(4):267-276. Exclusion code: 4. [pmid: 16897360].
Kollias J, Sibbering DM, Blarney RW, et al. Screening women aged less than 50 years with a family history of breast cancer. Eur. J. Cancer. 1998;34(6):878-883. Exclusion code: 8. [pmid: 9797701].
Kolor K, Duquette D, Zlot A, et al. Public awareness and use of direct-to-consumer personal genomic tests from four state population-based surveys, and implications for clinical and public health practice. Genet Med. 2012;14(10):860-867. Exclusion code: 2. [pmid: 22814860].
Komenaka IK, Ditkoff BA, Joseph KA, et al. The Development of Interval Breast Malignancies in Patients with BRCA Mutations. Cancer. 2004;100(10):2079-2083. Exclusion code: 8. [pmid: 15139048].
Kong CY, Lee JM, McMahon PM, et al. Using radiation risk models in cancer screening simulations: important assumptions and effects on outcome projections. Radiology. 2012;262(3):977-984. Exclusion code: 5. [pmid: 22357897].
Konstantopoulou I, Rampias T, Ladopoulou A, et al. Greek BRCA1 and BRCA2 mutation spectrum: Two BRCA1 mutations account for half the carriers found among high-risk breast/ovarian cancer patients. Breast Cancer Res. Treat. 2008;107(3):431-441. Exclusion code: 3. [pmid: 17453335].
Kopans DB. The U.S. Preventive Services Task Force guidelines are not supported by the scientific evidence. Radiology. 2010;257(1):294-295. author reply 295. Exclusion code: 5. [pmid: 20851947].
Kotalik J, Silverman M. Genetic medicine: ethical and practical issues of application of the new technology. Clin Invest Med. 2004;27(1):14-15. Exclusion code: 5. [pmid: 15061580].
Kote-Jarai Z, Powles TJ, Mitchell G, et al. BRCA1/BRCA2 mutation status and analysis of cancer family history in participants of the Royal Marsden Hospital tamoxifen chemoprevention trial. Cancer Lett. 2007;247(2):259-265. Exclusion code: 8. [pmid: 16777318].
Kotsopoulos J, Lubinski J, Lynch HT, et al. Oophorectomy after menopause and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. Cancer Epidemiol. Biomarkers Prev. 2012;21(7):1089-1096. Exclusion code: 2. [pmid: 22564871].
Kotsopoulos J, Lubinski J, Lynch HT, et al. Age at first birth and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. Breast Cancer Res. Treat. 2007;105(2):221-228. Exclusion code: 8. [pmid: 17245541].
Kotsopoulos J, Lubinski J, Lynch HT, et al. Age at menarche and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. Cancer Causes Control. 2005;16(6):667-674. Exclusion code: 8. [pmid: 16049805].
Kowalska E, Narod SA, Huzarski T, et al. Increased rates of chromosome breakage in BRCA1 carriers are normalized by oral selenium supplementation. Cancer Epidemiol. Biomarkers Prev. 2005;14(5):1302-1306. Exclusion code: 8. [pmid: 15894690].
Kram V, Peretz T, Sagi M. Acceptance of preventive surgeries by Israeli women who had undergone BRCA testing. Fam Cancer. 2006;5(4):327-335. Exclusion code: 8. [pmid: 16724248].
Kramer R, Brown P. Should tamoxifen be used in breast cancer prevention. Drug Saf. 2004;27(13):979-989. Exclusion code: 5. [pmid: 15471505].
Kriege M, Brekelmans CTM, Boetes C, et al. MRI screening for breast cancer in women with familial or genetic predisposition: Design of the Dutch National Study (MRISC). Fam Cancer. 2001;1(3-4):163-168. Exclusion code: 2. [pmid: 14574173].
Kriege M, Brekelmans CTM, Peterse H, et al. Tumor characteristics and detection method in the MRISC screening program for the early detection of hereditary breast cancer. Breast Cancer Res. Treat. 2007;102(3):357-363. Exclusion code: 5. [pmid: 17051427].
Kriege M, Jager A, Hooning MJ, et al. The efficacy of taxane chemotherapy for metastatic breast cancer in BRCA1 and BRCA2 mutation carriers. Cancer. 2012;118(4):899-907. Exclusion code: 3. [pmid: 21761396].
Kroiss R, Winkler V, Bikas D, et al. Younger birth cohort correlates with higher breast and ovarian cancer risk in European BRCA1 mutation carriers. Hum. Mutat. 2005;26(6):583-589. Exclusion code: 8. [pmid: 16287141].
Kroiss R, Winkler V, Kalteis K, et al. Prevalence of pre-malignant and malignant lesions in prophylactic mastectomy specimens of BRCA1 mutation carriers: comparison with a control group. J. Cancer Res. Clin. Oncol. 2008;134(10):1113-1121. Exclusion code: 4. [pmid: 18392852].
Kuhl CK. High-risk screening: Multi-modality surveillance of women at high risk for breast cancer (proven or suspected carriers of a breast cancer susceptibility gene). J. Exp. Clin. Cancer Res. 2002;21(3 SUPPL.):103-106. Exclusion code: 6. [pmid: 12585663].
Kuhl CK. Familial breast cancer: what the radiologist needs to know. Rofo. 2006;178(7):680-687. Exclusion code: 7. [pmid: 16817122].
Kuhl CK, Kuhn W, Schild H. Management of women at high risk for breast cancer: New imaging beyond mammography. Breast. 2005;14(6):480-486. Exclusion code: 5. [pmid: 16185869].
Kuhl CK, Schmutzler RK, Leutner CS, et al. Breast MR imaging screening in 192 women proved or suspected to be carriers of a breast cancer susceptibility gene: preliminary results. Radiology. 2000;215(1):267-279. Exclusion code: 2. [pmid: 10751498].
Kuhl CK, Schrading S, Leutner CC, et al. Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J. Clin. Oncol. 2005;23(33):8469-8476. Exclusion code: 3. [pmid: 16293877].
Kuijper TM, Ruigrok-Ritstier K, Verhoef-Post M, et al. LH receptor gene expression is essentially absent in breast tumor tissue: Implications for treatment. Mol. Cell. Endocrinol. 2009;302(1):58-64. Exclusion code: 3. [pmid: 19356624].
Kurian AW, Gong GD, John EM, et al. Performance of prediction models for BRCA mutation carriage in three racial/ethnic groups: findings from the Northern California Breast Cancer Family Registry. Cancer Epidemiol. Biomarkers Prev. 2009;18(4):1084-1091. Exclusion code: 3. [pmid: 19336551].
Kurian AW, Hartman AR, Mills MA, Ford JM, Daniel BL, Plevritis SK. Opinions of women with high inherited breast cancer risk about prophylactic mastectomy: an initial evaluation from a screening trial including magnetic resonance imaging and ductal lavage. Health Expect. 2005;8(3):221-233. Exclusion code: 3. [pmid: 16098152].
Kurian AW, Mills MA, Jaffee M, et al. Ductal lavage of fluid-yielding and non-fluid-yielding ducts in BRCA1 and BRCA2 mutation carriers and other women at high inherited breast cancer risk. Cancer Epidemiol. Biomarkers Prev. 2005;14(5):1082-1089. Exclusion code: 8. [pmid: 15894656].
Kurian AW, Munoz DF, Rust P, et al. Online tool to guide decisions for BRCA1/2 mutation carriers. J. Clin. Oncol. 2012;30(5):497-506. Exclusion code: 5. [pmid: 22231042].
Kurian AW, Sigal BM, Plevritis SK. Survival analysis of cancer risk reduction strategies for BRCA1/2 mutation carriers. J. Clin. Oncol. 2010;28(2):222-231. Exclusion code: 5. [pmid: 19996031].
Kuusisto KM, Bebel A, Vihinen M, Schleutker J, Sallinen S. Screening for BRCA1, BRCA2, CHEK2, PALB2, BRIP1, RAD50, and CDH1 mutations in high-risk Finnish BRCA1/2-founder mutation-negative breast and/or ovarian cancer individuals. Breast Cancer Res. 2011;13(1). Exclusion code: 3. [pmid: 21356067].
Kwiatkowski F, Dessenne P, Laquet C, Petit MF, Bignon YJ. Permanence of the information given during oncogenetic counseling to persons at familial risk of breast/ovarian and/or colon cancer. Eur. J. Hum. Genet. 2012;20(2):141-147. Exclusion code: 3. [pmid: 21934710].
Kwon JS, Daniels MS, Sun CC, Lu KH. Preventing future cancers by testing women with ovarian cancer for BRCA mutations. J. Clin. Oncol. 2010;28(4):675-682. Exclusion code: 3. [pmid: 19841329].
Kwon JS, Gutierrez-Barrera AM, Young D, et al. Expanding the criteria for BRCA mutation testing in breast cancer survivors. J. Clin. Oncol. 2010;28(27):4214-4220. Exclusion code: 3. [pmid: 20733129].
Kwon JS, Lenehan J, Carey M, Ainsworth P. Prolonged survival among women with BRCA germline mutations and advanced endometrial cancer: a case series. Int J Gynecol Cancer. 2008;18(3):546-549. Exclusion code: 3. [pmid: 17645508].
Kwong A, Ng EKO, Law FBF, et al. High-resolution melting analysis for rapid screening of BRCA2 founder mutations in Southern Chinese breast cancer patients. Breast Cancer Res. Treat. 2010;122(2):605-607. Exclusion code: 5. [pmid: 20396944].
Kwong A, Wong CHN, Shea C, Suen DTK, Choi CLY. Choice of management of southern Chinese BRCA mutation carriers. World J. Surg. 2010;34(7):1416-1426. Exclusion code: 8. [pmid: 20182723].
Kwong A, Wong CHN, Suen DTK, et al. Accuracy of BRCA1/2 mutation prediction models for different ethnicities and genders: experience in a southern Chinese cohort. World J. Surg. 2012;36(4):702-713. Exclusion code: 8. [pmid: 22290208].
Lacey JV, Greene MH, Buys SS, et al. Ovarian cancer screening in women with a family history of breast or ovarian cancer. Obstet. Gynecol. 2006;108(5):1176-1184. Exclusion code: 8. [pmid: 17077240].
Lacour RA, Westin SN, Meyer LA, et al. Improved survival in non-Ashkenazi Jewish ovarian cancer patients with BRCA1 and BRCA2 gene mutations. Gynecol. Oncol. 2011;121(2):358-363. Exclusion code: 3. [pmid: 21276604].
Lacroix M, Nycum G, Godard B, Knoppers BM. Should physicians warn patients' relatives of genetic risks. CMAJ. 2008;178(5):593-595. Exclusion code: 5. [pmid: 18299550].
Lagos VI, Perez MA, Ricker CN, et al. Social-cognitive aspects of underserved Latinas preparing to undergo genetic cancer risk assessment for hereditary breast and ovarian cancer. Psychooncology. 2008;17(8):774-782. Exclusion code: 3. [pmid: 18646245].
Lai M, Yen M, Kuo H, et al. Efficacy of breast-cancer screening for female relatives of breast-cancer-index cases: Taiwan multicentre cancer screening (TAMCAS). Int. J. Cancer. 1998;78:21-26. Exclusion code: 8. [pmid: 9724089].
Laitman Y, Kaufman B, Lahad EL, Papa MZ, Friedman E. Germline CHEK2 mutations in Jewish Ashkenazi women at high risk for breast cancer. Isr Med Assoc J. 2007;9(11):791-796. Exclusion code: 3. [pmid: 18085035].
Lakhani S, Manek S, Penault-Llorca F. Pathology of ovarian cancers in BRCA1 and BRCA2 carriers. Clin. Cancer Res. 2004;10(7):2473-2481. Exclusion code: 2. [pmid: 15073127].
Laki F, Kirova YM, This P, et al. Prophylactic salpingo-oophorectomy in a series of 89 women carrying a BRCA1 or a BRCA2 mutation. Cancer. 2007;109(9):1784-1790. Exclusion code: 3. [pmid: 17351952].
Lalloo F, Boggis CR, Evans DG, Shenton A, Threlfall AG, Howell A. Screening by mammography, women with a family history of breast cancer. Eur. J. Cancer. 1998;34(6):937-940. Exclusion code: 8. [pmid: 9797712].
Lancaster DR. Coping with appraised breast cancer risk among women with family histories of breast cancer. Res. Nurs. Health. 2005;28(2):144-158. Exclusion code: 8. [pmid: 15779052].
Lancaster JM, Powell CB, Kauff ND, et al. Society of Gynecologic Oncologists Education Committee statement on risk assessment for inherited gynecologic cancer predispositions. Gynecol. Oncol. 2007;107(2):159-162. Exclusion code: 2. [pmid: 17950381].
Lancastle D, Brain K, Phelps C. Illness representations and distress in women undergoing screening for familial ovarian cancer. Psychol Health. 2011;26(12):1659-1677. Exclusion code: 8. [pmid: 21736431].
Lanceley A, Eagle Z, Ogden G, et al. Family history and women with ovarian cancer: is it asked and does it matter?: An observational study. Int J Gynecol Cancer. 2012;22(2):254-259. Exclusion code: 4. [pmid: 22274317].
Land SR, Wickerham D, Costantino JP, et al. Patient-Reported Symptoms and Quality of Life During Treatment With Tamoxifen or Raloxifene for Breast Cancer Prevention: The NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 Trial. JAMA. 2006;295(23):2742-2751. Exclusion code: 3. [pmid: 16754728].
Landon G, Stewart J, Deavers M, Lu K, Sneige N. Peritoneal washing cytology in patients with BRCA1 or BRCA2 mutations undergoing risk-reducing salpingo-oophorectomies: a 10-year experience and reappraisal of its clinical utility. Gynecol. Oncol. 2012;125(3):683-686. Exclusion code: 8. [pmid: 22425664].
Landsbergen K, Verhaak C, Kraaimaat F, Hoogerbrugge N. Genetic uptake in BRCA-mutation families is related to emotional and behavioral communication characteristics of index patients. Fam Cancer. 2005;4(2):115-119. Exclusion code: 8. [pmid: 15951961].
Landsbergen KM, Brunner HG, Manders P, Hoogerbrugge N, Prins JB. Educational-support groups for BRCA mutation carriers satisfy need for information but do not affect emotional distress. Genet. Couns. 2010;21(4):423-437. Exclusion code: 4. [pmid: 21290972].
Landsbergen KM, Prins JB, Kamm YJL, Brunner HG, Hoogerbrugge N. Female BRCA mutation carriers with a preference for prophylactic mastectomy are more likely to participate an educational-support group and to proceed with the preferred intervention within 2 years. Fam Cancer. 2010;9(2):213-220. Exclusion code: 8. [pmid: 19967456].
Lapointe J, Abdous B, Camden S, et al. Influence of the family cluster effect on psychosocial variables in families undergoing BRCA1/2 genetic testing for cancer susceptibility. Psychooncology. 2012;21(5):515-523. Exclusion code: 3. [pmid: 21370312].
Lapointe J, Bouchard K, Patenaude AF, Maunsell E, Simard J, Dorval M. Incidence and predictors of positive and negative effects of BRCA1/2 genetic testing on familial relationships: A 3-year follow-up study. Genet Med. 2012;14(1):60-68. Exclusion code: 3. [pmid: 22237432].
Larouche G, Bouchard K, Chiquette J, Desbiens C, Simard J, Dorval M. Self-reported mammography use following BRCA1/2 genetic testing may be overestimated. Fam Cancer. 2012;11(1):27-32. Exclusion code: 8. [pmid: 22080962].
Leach MO, Eeles RA, Turnbull LW, et al. The UK national study of magnetic resonance imaging as a method of screening for breast cancer (MARIBS). J. Exp. Clin. Cancer Res. 2002;21(3 SUPPL.):107-114. Exclusion code: 6. [pmid: 12585664].
Leblond D, Bredart A, Dolbeault S, et al. Cognitive, emotional and behavioral impact of an uncertain outcome after study of BRCA1/2: review of the literature. Bull. Cancer (Paris). 2011;98(2):184-198. Exclusion code: 7. [pmid: 21382771].
Lech R, Przemyslaw O. Epidemiological models for breast cancer risk estimation. Ginekol. Pol. 2011;82(6):451-454. Exclusion code: 5. [pmid: 21853936].
Lee E, Ma H, McKean-Cowdin R, et al. Effect of reproductive factors and oral contraceptives on breast cancer risk in BRCA1/2 mutation carriers and noncarriers: results from a population-based study. Cancer Epidemiol. Biomarkers Prev. 2008;17(11):3170-3178. Exclusion code: 3. [pmid: 18990759].
Lee EH, Park SK, Park B, et al. Effect of BRCA1/2 mutation on short-term and long-term breast cancer survival: a systematic review and meta-analysis. Breast Cancer Res. Treat. 2010;122(1):11-25. Exclusion code: 3. [pmid: 20376556].
Lee EO, Ahn SH, You C, et al. Determining the main risk factors and high-risk groups of breast cancer using a predictive model for breast cancer risk assessment in South Korea. Cancer Nurs. 2004;27(5):400-406. Exclusion code: 2. [pmid: 15525868].
Lee JS, John EM, McGuire V, et al. Breast and ovarian cancer in relatives of cancer patients, with and without BRCA mutations. Cancer Epidemiol. Biomarkers Prev. 2006;15(2):359-363. Exclusion code: 3. [pmid: 16492929].
Lee R, Beattie M, Crawford B, et al. Recruitment, genetic counseling, and BRCA testing for underserved women at a public hospital. Genet Test. 2005;9(4):306-312. Exclusion code: 4. [pmid: 16379544].
Leeflang MMG, Deeks JJ, Gatsonis C, Bossuyt PMM, Cochrane Diagnostic Test Accuracy Working G. Systematic reviews of diagnostic test accuracy. Ann. Intern. Med. 2008;149(12):889-897. Exclusion code: 2. [pmid: 19075208].
Lehman CD, Blume JD, Weatherall P, et al. Screening women at high risk for breast cancer with mammography and magnetic resonance imaging. Cancer. 2005;103(9):1898-1905. Exclusion code: 8. [pmid: 15800894].
Lehman CD, Isaacs C, Schnall MD, et al. Cancer yield of mammography, MR, and US in high-risk women: prospective multi-institution breast cancer screening study. Radiology. 2007;244(2):381-388. Exclusion code: 3. [pmid: 17641362].
Lerman C, Hughes C, Lemon SJ, et al. What you don't know can hurt you: Adverse psychologic effects in members of BRCA1-linked and BRCA2-linked families who decline genetic testing. J. Clin. Oncol. 1998;16(5):1650-1654. Exclusion code: 3. [pmid: 9586874].
Lerman C, Narod S, Schulman K, et al. BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996;275(24):1885-1892. Exclusion code: 8. [pmid: 8648868].
Lessick M. Genetic testing for breast and ovarian cancer: ethical, legal, and psychosocial considerations. Nurs Womens Health. 2007;11(4):390-399. quiz 400-391. Exclusion code: 5. [pmid: 17883756].
Leunen K, Drijkoningen M, Neven P, et al. Prophylactic mastectomy in familial breast carcinoma. What do the pathologic findings learn us. Breast Cancer Res. Treat. 2008;107(1):79-86. Exclusion code: 8. [pmid: 17431765].
Levine D, Argenta P, Yee C. Fallopian tube and primary perirtoneal carcinomas associated with BRCA mutations. J. Clin. Oncol. 21(22):4222-4227. Exclusion code: 2. [pmid: 14615451].
Levy D, Garber J, Shields A. Guidelines for Genetic Risk Assessment of Hereditary Breast and Ovarian Cancer: Early Disagreements and Low Utilization. J. Gen. Intern. Med. 2009;24(7):822-828. Exclusion code: 3. [pmid: 19455369].
Levy DE, Byfield SD, Comstock CB, et al. Underutilization of BRCA1/2 testing to guide breast cancer treatment: black and Hispanic women particularly at risk. Genet Med. 2011;13(4):349-355. Exclusion code: 3. [pmid: 21358336].
Lewis MJ, Peterson SK. Perceptions of genetic testing for cancer predisposition among Ashkenazi Jewish women. Community Genet. 2007;10(2):72-81. Exclusion code: 4. [pmid: 17380056].
Li WF, Hu Z, Rao NY, et al. The prevalence of BRCA1 and BRCA2 germline mutations in high-risk breast cancer patients of Chinese Han nationality: two recurrent mutations were identified. Breast Cancer Res Treat. 2008;110(1):99-109. Exclusion code: 3. [pmid: 17851763].
Lidén A, Berglund G, Hansson MG, Rosenquist R, Sjödén PO, Nordin K. Genetic Counselling for Cancer and Risk Perception. Acta Oncol. 2003;42(7):726-734. Exclusion code: 6. [pmid: 14690158].
Liede A, Karlan BY, Narod SA. Cancer risks for male carriers of germline mutations in BRCA1 or BRCA2: a review of the literature. J. Clin. Oncol. 2004;22(4):735-742. Exclusion code: 2. [pmid: 14966099].
Lifford KJ, Fraser L, Rosenthal AN, et al. Withdrawal from familial ovarian cancer screening for surgery: findings from a psychological evaluation study (PsyFOCS). Gynecol. Oncol. 2012;124(1):158-163. Exclusion code: 8. [pmid: 21999920].
Lim J, Macluran M, Price M, Bennett B, Butow P, kConFab Psychosocial G. Short- and long-term impact of receiving genetic mutation results in women at increased risk for hereditary breast cancer. J Genet Couns. 2004;13(2):115-133. Exclusion code: 6. [pmid: 15612172].
Lindberg NM, Wellisch DK. Identification of Traumatic Stress Reactions in Women at Increased Risk for Breast Cancer. Psychosomatics. 2004;45(1):7-16. Exclusion code: 4. [pmid: 14709756].
Lindor NM, Greene MH, Mayo Familial Cancer Program. The concise handbook of family cancer syndromes. J. Natl. Cancer Inst. 1998;90(14):1039-1071. Exclusion code: 2. [pmid: 9672254].
Lindor NM, Guidugli L, Wang X, et al. A review of a multifactorial probability-based model for classification of BRCA1 and BRCA2 variants of uncertain significance (VUS). Hum. Mutat. 2012;33(1):8-21. Exclusion code: 5. [pmid: 21990134].
Lindor NM, Johnson KJ, Harvey H, et al. Predicting BRCA1 and BRCA2 gene mutation carriers: comparison of PENN II model to previous study. Fam Cancer. 2010;9(4):495-502. Exclusion code: 3. [pmid: 20512419].
Litton JK, Westin SN, Ready K, et al. Perception of screening and risk reduction surgeries in patients tested for a BRCA deleterious mutation. Cancer. 2009;115(8):1598-1604. Exclusion code: 3. [pmid: 19280625].
Lo SH, Chernoff H, Cong L, Ding Y, Zheng T. Discovering interactions among BRCA1 and other candidate genes associated with sporadic breast cancer. Proc. Natl. Acad. Sci. U. S. A. 2008;105(34):12387-12392. Exclusion code: 5. [pmid: 18711133].
Loader S, Shields CG, Rowley PT. Impact of genetic testing for breast-ovarian cancer susceptibility. Genet Test. 2004;8(1):1-12. Exclusion code: 6. [pmid: 15140369].
Lobb E, Butow P, Meiser B, et al. The use of audiotapes in consultations with women from high risk breast cancer families: A randomised trial. J. Med. Genet. 2002;39(9):697-703. Exclusion code: 3. [pmid: 12205117].
Lobb E, Meiser B. Genetic counselling and prophylactic surgery in women from families with hereditary breast or ovarian cancer. Lancet. 2004;363(9424):1-4. Exclusion code: 5. [pmid: 14723980].
Lobb EA, Barlow-Stewart K, Suthers G, Hallowell N. Treatment-focused DNA testing for newly diagnosed breast cancer patients: some implications for clinical practice. Clin. Genet. 2010;77(4):350-354. Exclusion code: 5. [pmid: 19930416].
Lobb EA, Butow P, Barratt A, Meiser B, Tucker K. Differences in individual approaches: communication in the familial breast cancer consultation and the effect on patient outcomes. J Genet Couns. 2005;14(1):43-53. Exclusion code: 8. [pmid: 15789155].
Locke I, Kote-Jarai Z, Bancroft E, et al. Loss of heterozygosity at the BRCA1 and BRCA2 loci detected in ductal lavage fluid from BRCA gene mutation carriers and controls. Cancer Epidemiol. Biomarkers Prev. 2006;15(7):1399-1402. Exclusion code: 5. [pmid: 16835343].
Loescher LJ, Lim KH, Leitner O, Ray J, D'Souza J, Armstrong CM. Cancer surveillance behaviors in women presenting for clinical BRCA genetic susceptibility testing. Oncol. Nurs. Forum. 2009;36(2):E57-67. Exclusion code: 8. [pmid: 19273395].
Loizidou M, Marcou Y, Anastasiadou V, Newbold R, Hadjisavvas A, Kyriacou K. Contribution of BRCA1 and BRCA2 germline mutations to the incidence of early-onset breast cancer in Cyprus. Clin. Genet. 2007;71(2):165-170. Exclusion code: 3. [pmid: 17250666].
Loizidou MA, Cariolou MA, Neuhausen SL, et al. Genetic variation in genes interacting with BRCA1/2 and risk of breast cancer in the Cypriot population. Breast Cancer Res. Treat. 2010;121(1):147-156. Exclusion code: 4. [pmid: 19714462].
Loman N, Borg A. Improving surveillance and quality of life of BRCA mutation carriers. J. Clin. Oncol. 2010;28(22):e376-377. Exclusion code: 5. [pmid: 20458044].
Lorenzo Bermejo J, Hemminki K. A population-based assessment of the clustering of breast cancer in families eligible for testing of BRCA1 and BRCA2 mutations. Ann. Oncol. 2005;16(2):322-329. Exclusion code: 3. [pmid: 15668291].
Lostumbo L, Carbine NE, Wallace J. Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database Syst Rev. 2010;(11):CD002748. Exclusion code: 3. [pmid: 21069671].
Love RR. Population health, global bioethics and breast cancer treatment. Oncology (Williston Park). 2006;20(7):675. Exclusion code: 5. [pmid: 16841793].
Lowenfels AB, Maisonneuve P, Whitcomb DC. Risk factors for cancer in hereditary pancreatitis. Med. Clin. North Am. 2000;84(3):565-573. Exclusion code: 5. [pmid: 10872414].
Lowery JT, Byers T, Axell L, Ku L, Jacobellis J. The impact of direct-to-consumer marketing of cancer genetic testing on women according to their genetic risk. Genet Med. 2008;10(12):888-894. Exclusion code: 2. [pmid: 19092441].
Lubinski J, Korzen M, Gorski B, et al. Breast cancer susceptibility genes. Journal of B.U.ON. Suppl 1. 2007;12:S23-29. Exclusion code: 5. [pmid: 17935274].
Lubitz RJ, Komaromy M, Crawford B, et al. Development and pilot evaluation of novel genetic educational materials designed for an underserved patient population. Genet Test. 2007;11(3):276-290. Exclusion code: 5. [pmid: 17949289].
Lucassen A, Watson E, Harcourt J, Rose P, O'Grady J. Guidelines for referral to a regional genetics service: GPs respond by referring more appropriate cases. Fam. Pract. 2001;18(2):135-140. Exclusion code: 2. [pmid: 11264262].
Lux MP, Ackermann S, Bani MR, et al. Age of uptake of early cancer detection facilities by low-risk and high-risk patients with familial breast and ovarian cancer. Eur. J. Cancer Prev. 2005;14(6):503-511. Exclusion code: 8. [pmid: 16284494].
Lux MP, Ackermann S, Nestle-Kramling C, et al. Use of intensified early cancer detection in high-risk patients with familial breast and ovarian cancer. Eur. J. Cancer Prev. 2005;14(4):399-411. Exclusion code: 3. [pmid: 16030432].
Lux MP, Bani MR, Fasching PA, Beckmann MW. Prophylactic surgery of mammary and ovarian carcinoma. Chirurg. 2005;76(12):1145-1154. Exclusion code: 7. [pmid: 16237564].
Lux MP, Fasching PA, Beckmann MW. Hereditary breast and ovarian cancer: review and future perspectives. J. Mol. Med. 2006;84(1):16-28. Exclusion code: 5. [pmid: 16283147].
Lynch HT, Silva E, Snyder C, Lynch JF. Hereditary breast cancer: part I. Diagnosing hereditary breast cancer syndromes. Breast J. 2008;14(1):3-13. Exclusion code: 5. [pmid: 18086272].
Lynch HT, Snyder C, Lynch J. Hereditary breast cancer: practical pursuit for clinical translation. Ann. Surg. Oncol. 2012;19(6):1723-1731. Exclusion code: 5. [pmid: 22434244].
Lynch HT, Snyder C, Lynch JF, et al. Patient responses to the disclosure of BRCA mutation tests in hereditary breast-ovarian cancer families. Cancer Genet. Cytogenet. 2006;165(2):91-97. Exclusion code: 3. [pmid: 16527602].
Lynch HT, Snyder CL, Lynch JF, Ghate S, Narod SA, Gong G. Family information service participation increases the rates of mutation testing among members of families with BRCA1/2 mutations. Breast J. Suppl 1. 2009;15:S20-24. Exclusion code: 8. [pmid: 19775326].
MacDonald DJ, Sarna L, Weitzel JN, Ferrell B. Women's perceptions of the personal and family impact of genetic cancer risk assessment: focus group findings. J Genet Couns. 2010;19(2):148-160. Exclusion code: 8. [pmid: 19902342].
Machackova E, Foretova L, Lukesova M, et al. Spectrum and characterisation of BRCA1 and BRCA2 deleterious mutations in high-risk Czech patients with breast and/or ovarian cancer. BMC Cancer. 2008;8:140. Exclusion code: 3. [pmid: 18489799].
Mackay J, Schulz P, Rubinelli S, Pithers A. Online patient education and risk assessment: project OPERA from Cancerbackup. Putting inherited breast cancer risk information into context using argumentation theory. Patient Educ. Couns. 2007;67(3):261-266. Exclusion code: 5. [pmid: 17590305].
Mackenzie A, Patrick-Miller L, Bradbury AR. Controversies in communication of genetic risk for hereditary breast cancer. Breast J. Suppl 1. 2009;15:S25-32. Exclusion code: 5. [pmid: 19775327].
MacNew HG, Rudolph R, Brower ST, Beck AN, Meister EA. Assessing the knowledge and attitudes regarding genetic testing for breast cancer risk in our region of southeastern Georgia. Breast J. 2010;16(2):189-192. Exclusion code: 3. [pmid: 20030654].
Madalinska JB, Hollenstein J, Bleiker E, et al. Quality-of-life effects of prophylactic salpingo-oophorectomy versus gynecologic screening among women at increased risk of hereditary ovarian cancer. J. Clin. Oncol. 2005;23(28):6890-6898. Exclusion code: 3. [pmid: 16129845].
Madalinska JB, van Beurden M, Bleiker EMA, et al. The impact of hormone replacement therapy on menopausal symptoms in younger high-risk women after prophylactic salpingo-oophorectomy. J. Clin. Oncol. 2006;24(22):3576-3582. Exclusion code: 3. [pmid: 16877724].
Maheu C. Implications of living with a strong family history of breast cancer. Can. J. Nurs. Res. 2009;41(2):100-112. Exclusion code: 8. [pmid: 19650516].
Maheu C, Thorne S. Receiving inconclusive genetic test results: an interpretive description of the BRCA1/2 experience. Res. Nurs. Health. 2008;31(6):553-562. Exclusion code: 3. [pmid: 18449940].
Mahfoudh W, Bouaouina N, Ahmed SB, et al. Hereditary breast cancer in Middle Eastern and North African (MENA) populations: identification of novel, recurrent and founder BRCA1 mutations in the Tunisian population. Mol. Biol. Rep. 2012;39(2):1037-1046. Exclusion code: 8. [pmid: 21603858].
Mahon SM. Managing families with a hereditary cancer syndrome. Oncol. Nurs. Forum. 2011;38(6):641-644. Exclusion code: 5. [pmid: 22037327].
Mahoney MC. Breast cancer risk reduction and counseling: lifestyle, chemoprevention, and surgery. J Natl Compr Canc Netw. 2007;5(8):702-710. Exclusion code: 5. [pmid: 17927927].
Mai PL, Garceau AO, Graubard BI, et al. Confirmation of family cancer history reported in a population-based survey. J. Natl. Cancer Inst. 2011;103(10):788-797. Exclusion code: 2. [pmid: 21562245].
Mai PL, Lagos VI, Palomares MR, Weitzel JN. Contralateral risk-reducing mastectomy in young breast cancer patients with and without genetic cancer risk assessment. Ann. Surg. Oncol. 2008;15(12):3415-3421. Exclusion code: 3. [pmid: 18836779].
Mai PL, Wideroff L, Greene MH, Graubard BI. Prevalence of family history of breast, colorectal, prostate, and lung cancer in a population-based study. Public Health Genomics. 2010;13(7-8):495-503. Exclusion code: 8. [pmid: 20389042].
Majdak EJ, Debniak J, Milczek T, et al. Prognostic impact of BRCA1 pathogenic and BRCA1/BRCA2 unclassified variant mutations in patients with ovarian carcinoma. Cancer. 2005;104(5):1004-1012. Exclusion code: 3. [pmid: 16047333].
Majdak-Paredes EJ, Fatah F. Hereditary breast cancer syndromes and clinical implications. J Plast Reconstr Aesthet Surg. 2009;62(2):181-189. Exclusion code: 5. [pmid: 19027378].
Gene expression profiling tests for breast cancer (Project record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010001443. Exclusion code: 5.
Malacrida S, Agata S, Callegaro M, et al. BRCA1 p.Val1688del is a deleterious mutation that recurs in breast and ovarian cancer families from Northeast Italy. J. Clin. Oncol. 2008;26(1):26-31. Exclusion code: 3. [pmid: 18165637].
Malone KE, Begg CB, Haile RW, et al. Population-based study of the risk of second primary contralateral breast cancer associated with carrying a mutation in BRCA1 or BRCA2. J. Clin. Oncol. 2010;28(14):2404-2410. Exclusion code: 3. [pmid: 20368571].
Malone KE, Daling JR, Doody DR, et al. Prevalence and predictors of BRCA1 and BRCA2 mutations in a population-based study of breast cancer in white and black American women ages 35 to 64 years. Cancer Res. 2006;66(16):8297-8308. Exclusion code: 2. [pmid: 16912212].
Maloney E, Edgerson S, Robson M, et al. What women with breast cancer discuss with clinicians about risk for their adolescent daughters. J Psychosoc Oncol. 2012;30(4):484-502. Exclusion code: 3. [pmid: 22747109].
Malpas P. The right to remain in ignorance about genetic information--can such a right be defended in the name of autonomy. N. Z. Med. J. 2005;118(1220):U1611. Exclusion code: 5. [pmid: 16132072].
Manchanda R, Burnell M, Abdelraheim A, et al. Factors influencing uptake and timing of risk reducing salpingo-oophorectomy in women at risk of familial ovarian cancer: a competing risk time to event analysis. Bjog. 2012;119(5):527-536. Exclusion code: 8. [pmid: 22260402].
Mancini J, Nogues C, Adenis C, et al. Impact of an information booklet on satisfaction and decision-making about BRCA genetic testing. Eur. J. Cancer. 2006;42(7):871-881. Exclusion code: 8. [pmid: 16563745].
Manders P, Pijpe A, Hooning MJ, et al. Body weight and risk of breast cancer in BRCA1/2 mutation carriers. Breast Cancer Res. Treat. 2011;126(1):193-202. Exclusion code: 8. [pmid: 20730487].
Mangerich B, Stichler JF. Breast and ovarian cancer: a new model for educating women. Nurs Womens Health. 2008;12(6):490-499. Exclusion code: 5. [pmid: 19121054].
Manguoglu E, Guran S, Yamac D, et al. Germline mutations of BRCA1 and BRCA2 genes in Turkish breast, ovarian, and prostate cancer patients. Cancer Genet. Cytogenet. 2010;203(2):230-237. Exclusion code: 3. [pmid: 21156238].
Manguoglu E, Guran S, Yamac D, et al. Genomic large rearrangement screening of BRCA1 and BRCA2 genes in high-risk Turkish breast/ovarian cancer patients by using multiplex ligation-dependent probe amplification assay. Cancer Invest. 2011;29(1):73-77. Exclusion code: 3. [pmid: 20919953].
Manne S, Audrain J, Schwartz M, Main D, Finch C, Lerman C. Associations between relationship support and psychological reactions of participants and partners to BRCA1 and BRCA2 testing in a clinic-based sample. Ann. Behav. Med. 2004;28(3):211-225. Exclusion code: 8. [pmid: 15576260].
Mannis G, Fehniger J, Creasman J, Jacoby VL, Beattie MS. Risk-Reducing Salpingo-oophorectomy and Ovarian Cancer Screening in 1077 Women After BRCA Testing. JAMA. 2013;173(2):96-103. Exclusion code: 2. [pmid: 23247828].
Marchbanks PA, McDonald JA, Wilson HG, et al. The NICHD Women's Contraceptive and Reproductive Experiences Study: Methods and operational results. Ann. Epidemiol. 2002;12(4):213-221. Exclusion code: 3. [pmid: 11988408].
Marchetti P, Di Rocco CZ, Ricevuto E, et al. Reducing breast cancer incidence in familial breast cancer: overlooking the present panorama. Ann. Oncol. 2004;15(Suppl 1):I27-I34. Exclusion code: 5. [pmid: 15280184].
Marchina E, Fontana MG, Speziani M, et al. BRCA1 and BRCA2 genetic test in high risk patients and families: counselling and management. Oncol. Rep. 2010;24(6):1661-1667. Exclusion code: 3. [pmid: 21042765].
Impact of gene expression profiling tests on breast cancer outcomes (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32008000072. Exclusion code: 5.
Margolin S, Lindblom A. Familial breast cancer, underlying genes, and clinical implications: a review. Crit. Rev. Oncog. 2006;12(1-2):75-113. Exclusion code: 5. [pmid: 17078207].
Margolin S, Werelius B, Fornander T, Lindblom A. BRCA1 mutations in a population-based study of breast cancer in Stockholm County. Genet Test. 2004;8(2):127-132. Exclusion code: 3. [pmid: 15345109].
Markopoulos C, Tsaroucha AK, Kouskos E, Mantas D, Antonopoulou Z, Karvelis S. Impact of breast cancer surgery on the self-esteem and sexual life of female patients. J. Int. Med. Res. 2009;37(1):182-188. Exclusion code: 3. [pmid: 19215689].
Marpeau O, Ancel PY, Antoine M, Uzan S, Barranger E. Synchronous bilateral breast cancer: risk factors, diagnosis, histology and treatment. Gynecol Obstet Fertil. 2008;36(1):35-44. Exclusion code: 7. [pmid: 18178120].
Diagnostic performance of digital mammography in breast cancer screening (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000799. Exclusion code: 5.
Marshall E. European patents. BRCA2 claim faces new challenge. Science. 2005;308(5730):1851. Exclusion code: 5. [pmid: 15976277].
Marshall E. Patents. U.S. appeals court hears gene patent arguments. Science. 2012;337(6092):277-278. Exclusion code: 2. [pmid: 22822118].
Marshall M, Solomon S. Hereditary breast-ovarian cancer: clinical findings and medical management. Plast. Surg. Nurs. 2007;27(3):124-127. Exclusion code: 5. [pmid: 17901820].
Effects of communicating DNA-based disease risk estimates on risk-reducing behaviours. 2011. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=coch&AN=00075320-100000000-05884. Exclusion code: 5.
Martin W, Degner L. Perception of risk and surveillance practices of women with a family history of breast cancer. Cancer Nurs. 2006;29(3):227-235. Exclusion code: 8. [pmid: 16783123].
Marzo Castillejo M. Prevention of breast cancer 2007. New evidence?. Aten. Primaria. 2007;39(3):115-117. Exclusion code: 7. [pmid: 17386201].
Masood S. The knowledge about risk for breast cancer: the patients' right to know. Breast J. 2008;14(3):219-220. Exclusion code: 5. [pmid: 18476881].
Matalqah LM, Radaideh KM, Yusoff ZM, Awaisu A. Health-related quality of life using EQ-5D among breast cancer survivors in comparison with age-matched peers from the general population in the state of Penang, Malaysia. Journal of Public Health. 2011;19(5):475-480. Exclusion code: 2.
Matloff E, Caplan A. Direct to confusion: lessons learned from marketing BRCA testing. Am J Bioeth. 2008;8(6):5-8. Exclusion code: 5. [pmid: 18726769].
Matloff ET, Brierley KL. The double-helix derailed: the story of the BRCA patent. Lancet. 2010;376(9738):314-315. Exclusion code: 5. [pmid: 20674708].
Matthijs G. The European opposition against the BRCA gene patents. Fam Cancer. 2006;5(1):95-102. Exclusion code: 5. [pmid: 16528613].
Maurice A, Evans DGR, Shenton A, et al. Screening younger women with a family history of breast cancer--does early detection improve outcome. Eur. J. Cancer. 2006;42(10):1385-1390. Exclusion code: 3. [pmid: 16750910].
Mavaddat N, Barrowdale D, Andrulis I. Pathology of breast and ovarian cancers among BRCA1 and BRCA2 mutation carriers: results from the Consortium of Investigators of Modifiers of BRCA1/2 (CIMBA). Cancer Epidemiol. Biomarkers Prev. 2012;21(1):134-147. Exclusion code: 2. [pmid: 22144499].
McClain MR, Nathanson KL, Palomaki GE, Haddow JE. An evaluation of BRCA1 and BRCA2 founder mutations penetrance estimates for breast cancer among Ashkenazi Jewish women. Genet Med. 2005;7(1):34-39. Exclusion code: 5. [pmid: 15654226].
McClain MR, Palomaki GE, Nathanson KL, Haddow JE. Adjusting the estimated proportion of breast cancer cases associated with BRCA1 and BRCA2 mutations: public health implications. Genet Med. 2005;7(1):28-33. Exclusion code: 8. [pmid: 15654225].
McDaniel SH. The psychotherapy of genetics. Fam. Process. 2005;44(1):25-44. Exclusion code: 5. [pmid: 15807076].
BRCA1 and BRCA2 predictive genetic testing for breast and ovarian cancers: a systematic review of clinical evidence (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000281. Exclusion code: 5.
A clinical systematic review of BRCA1 and BRCA2 genetic testing for breast and ovarian cancers (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000282. Exclusion code: 5.
McGaughey A. Body image after bilateral prophylactic mastectomy: An integrative literature review. J Midwifery Womens Health. 2006;51(6):e45-e49. Exclusion code: 5. [pmid: 17081926].
McGuire V, Felberg A, Mills M, et al. Relation of contraceptive and reproductive history to ovarian cancer risk in carriers and noncarriers of BRCA1 gene mutations. Am. J. Epidemiol. 2004;160(7):613-618. Exclusion code: 6. [pmid: 15383404].
McHorney CA, Ware JE Jr, Lu JF, Sherbourne CD. The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med. Care. 1994;32(1):40-66. Exclusion code: 2. [pmid: 8277801].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. Am J Med Genet A. 2004;130A(3):221-227. Exclusion code: 3. [pmid: 15378542].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families II: impact on relationships. Am J Med Genet A. 2005;133A(2):165-169. Exclusion code: 8. [pmid: 15633195].
McInerney-Leo A, Hadley D, Kase RG, Giambarresi TR, Struewing JP, Biesecker BB. BRCA1/2 testing in hereditary breast and ovarian cancer families III: risk perception and screening. Am J Med Genet A. 2006;140(20):2198-2206. Exclusion code: 8. [pmid: 16969872].
McKinnon W, Naud S, Ashikaga T, Colletti R, Wood M. Results of an intervention for individuals and families with BRCA mutations: a model for providing medical updates and psychosocial support following genetic testing. J Genet Couns. 2007;16(4):433-456. Exclusion code: 8. [pmid: 17594133].
McLaughlin JR, Risch HA, Lubinski J, et al. Reproductive risk factors for ovarian cancer in carriers of BRCA1 or BRCA2 mutations: a case-control study. Lancet Oncol. 2007;8(1):26-34. Exclusion code: 8. [pmid: 17196508].
McPherson E. Genetic diagnosis and testing in clinical practice. Clin Med Res. 2006;4(2):123-129. Exclusion code: 5. [pmid: 16809405].
Mealiffe ME, Stokowski RP, Rhees BK, Prentice RL, Pettinger M, Hinds DA. Assessment of clinical validity of a breast cancer risk model combining genetic and clinical information. J. Natl. Cancer Inst. 2010;102(21):1618-1627. Exclusion code: 3. [pmid: 20956782].
Medeiros F, Muto M, Lee Y, et al. The tubal fimbria is a preferred site for early adenocarcinoma in women with familial ovarian cancer syndrome. Am. J. Surg. Pathol. 2006;30(2):230-236. Exclusion code: 2. [pmid: 16434898].
Meeuwissen PAM, Seynaeve C, Brekelmans CTM, Meijers-Heijboer HJ, Klijn JGM, Burger CW. Outcome of surveillance and prophylactic salpingo-oophorectomy in asymptomatic women at high risk for ovarian cancer. Gynecol. Oncol. 2005;97(2):476-482. Exclusion code: 3. [pmid: 15863147].
Mefford H, Baumbach L, Panguluri R. Evidence for BRCA1 founder mutation in families of West African ancestry. Am J Hum Genet. 1999;65(2):575-578. Exclusion code: 2. [pmid: 10417303].
Meijers-Heijboer H, van Geel B, van Putten WLJ, et al. Breast cancer after prophylactic bilateral mastectomy in women with a BRCA1 or BRCA2 mutation. N. Engl. J. Med. 2001;345(3):159-164. Exclusion code: 3. [pmid: 11463009].
Meilleur KG, Littleton-Kearney MT. Interventions to improve patient education regarding multifactorial genetic conditions: a systematic review. Am J Med Genet A. 2009;149A(4):819-830. Exclusion code: 8. [pmid: 19291763].
Meindl A. Comprehensive analysis of 989 patients with breast or ovarian cancer provides BRCA1 and BRCA2 mutation profiles and frequencies for the German population. Int. J. Cancer. 2002;97(4):472-480. Exclusion code: 8. [pmid: 11802209].
Meiser B. Psychological impact of genetic testing for cancer susceptibility: an update of the literature. Psychooncology. 2005;14(12):1060-1074. Exclusion code: 6. [pmid: 15937976].
Meiser B, Gaff C, Julian-Reynier C, et al. International perspectives on genetic counseling and testing for breast cancer risk. Breast Dis. 2006;27:109-125. Exclusion code: 5. [pmid: 17917143].
Mellon S, Gold R, Janisse J, et al. Risk perception and cancer worries in families at increased risk of familial breast/ovarian cancer. Psychooncology. 2008;17(8):756-766. Exclusion code: 3. [pmid: 18613300].
Menon U, Harper J, Sharma A, et al. Views of BRCA gene mutation carriers on preimplantation genetic diagnosis as a reproductive option for hereditary breast and ovarian cancer. Hum. Reprod. 2007;22(6):1573-1577. Exclusion code: 8. [pmid: 17428877].
Menon U, Skates SJ, Lewis S, et al. Prospective study using the risk of ovarian cancer algorithm to screen for ovarian cancer. J. Clin. Oncol. 2005;23(31):7919-7926. Exclusion code: 3. [pmid: 16258091].
Metcalfe A, Werrett J, Burgess L, Clifford C. Psychosocial impact of the lack of information given at referral about familial risk for cancer. Psychooncology. 2007;16(5):458-465. Exclusion code: 4. [pmid: 16933207].
Metcalfe K, Gershman S, Lynch HT, et al. Predictors of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. Br. J. Cancer. 2011;104(9):1384-1392. Exclusion code: 3. [pmid: 21487411].
Metcalfe K, Lynch HT, Ghadirian P, et al. Contralateral breast cancer in BRCA1 and BRCA2 mutation carriers. J. Clin. Oncol. 2004;22(12):2328-2335. Exclusion code: 3. [pmid: 15197194].
Metcalfe KA, Birenbaum-Carmeli D, Lubinski J, et al. International variation in rates of uptake of preventive options in BRCA1 and BRCA2 mutation carriers. Int. J. Cancer. 2008;122(9):2017-2022. Exclusion code: 8. [pmid: 18196574].
Metcalfe KA, Foulkes WD, Kim-Sing C, et al. Family history as a predictor of uptake of cancer preventive procedures by women with a BRCA1 or BRCA2 mutation. Clin. Genet. 2008;73(5):474-479. Exclusion code: 8. [pmid: 18341607].
Metcalfe KA, Poll A, Llacuachaqui M, et al. Patient satisfaction and cancer-related distress among unselected Jewish women undergoing genetic testing for BRCA1 and BRCA2. Clin. Genet. 2010;78(5):411-417. Exclusion code: 3. [pmid: 20653694].
Metcalfe KA, Poll A, O'Connor A, et al. Development and testing of a decision aid for breast cancer prevention for women with a BRCA1 or BRCA2 mutation. Clin. Genet. 2007;72(3):208-217. Exclusion code: 8. [pmid: 17718858].
Metcalfe KA, Semple JL, Narod SA. Satisfaction with breast reconstruction in women with bilateral prophylactic mastectomy: A descriptive study. Plast. Reconstr. Surg. 2004;114(2):360-366. Exclusion code: 8. [pmid: 15277800].
Michigan Department of Community Health (MDCH). BRCA 1/2 Surveillance in Michigan, 2008-2012. Lansing, MI. 2012. Exclusion code: 2.
Miki Y, Swensen J, Shattuck-Eidens D, et al. A Strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994;266(5182):66-71. Exclusion code: 2. [pmid: 7545954].
Mikkelsen EM, Sunde L, Johansen C, Johnsen SP. Psychosocial conditions of women awaiting genetic counseling: a population-based study. J Genet Couns. 2008;17(3):242-251. Exclusion code: 3. [pmid: 18256912].
Miller SM, Fleisher L, Roussi P, et al. Facilitating informed decision making about breast cancer risk and genetic counseling among women calling the NCI's Cancer Information Service. J Health Commun. Suppl 1. 2005;10:119-136. Exclusion code: 3. [pmid: 16377604].
Miller SM, Roussi P, Daly MB, et al. Enhanced counseling for women undergoing BRCA1/2 testing: impact on subsequent decision making about risk reduction behaviors. Health Educ. Behav. 2005;32(5):654-667. Exclusion code: 3. [pmid: 16148211].
Milne RL, Antoniou AC. Genetic modifiers of cancer risk for BRCA1 and BRCA2 mutation carriers. Ann. Oncol. 2011;22(SUPPL. 1):i11-i17. Exclusion code: 2. [pmid: 21285145].
Milne RL, Knight JA, John EM, et al. Oral contraceptive use and risk of early-onset breast cancer in carriers and noncarriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol. Biomarkers Prev. 2005;14(2):350-356. Exclusion code: 3. [pmid: 15734957].
Minckwitz GV, Prieshof B, Jackisch C, et al. First experience with gosereline and ibandronate as medical prevention in premenopausal patients with increased familiary breast cancer risk: The GISS study. [abstract]. Third International Conference and Ninth Annual Meeting of the International Society of Cancer Chemoprevention. 2004;2. Exclusion code: 5.
Miramar MD, Calvo MT, Rodriguez A, et al. Genetic analysis of BRCA1 and BRCA2 in breast/ovarian cancer families from Aragon (Spain): two novel truncating mutations and a large genomic deletion in BRCA1. Breast Cancer Res. Treat. 2008;112(2):353-358. Exclusion code: 4. [pmid: 18176857].
Miser WF. Cancer screening in the primary care setting: the role of the primary care physician in screening for breast, cervical, colorectal, lung, ovarian, and prostate cancers. Prim. Care. 2007;34(1):137-167. Exclusion code: 5. [pmid: 17481991].
Mislowsky A, Domchek S, Stroede C, et al. Breast cancer surgery trend changes since the introduction of BRCA1/2 mutation screening: a retrospective cohort analysis of 158 mutation carriers treated at a single institution. Ann. Surg. Oncol. 2011;18(3):745-751. Exclusion code: 8. [pmid: 20972632].
Mitchell RJ, Farrington SM, Dunlop MG, Campbell H. Mismatch repair genes hMLH1 and hMSH2 and colorectal cancer: A HuGE review. Am. J. Epidemiol. 2002;156(10):885-902. Exclusion code: 6. [pmid: 12419761].
Moatter T, Aban M, Khan S, Azam I, Pervez S. BRCA1 status in Pakistani breast cancer patients with moderate family history. J Coll Physicians Surg Pak. 2011;21(11):680-684. Exclusion code: 3. [pmid: 22078348].
Modan B, Hartge P, Hirsh-Yechezkel G, et al. Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N. Engl. J. Med. 2001;345(4):235-240. Exclusion code: 3. [pmid: 11474660].
Møller P, Borg A, Gareth Evans D, et al. Survival in prospectively ascertained familial breast cancer: Analysis of a series stratified by tumour characteristics, BRCA mutations and oophorectomy. Int. J. Cancer. 2002;101(6):555-559. Exclusion code: 6. [pmid: 12237897].
Moller P, Evans DG, Reis MM, et al. Surveillance for familial breast cancer: Differences in outcome according to BRCA mutation status. Int. J. Cancer. 2007;121(5):1017-1020. Exclusion code: 3. [pmid: 17471561].
Moller P, Evans G, Haites N, et al. Guidelines for follow-up of women at high risk for inherited breast cancer: consensus statement from the Biomed 2 Demonstration Programme on Inherited Breast Cancer. Dis. Markers. 1999;15(1-3):207-211. Exclusion code: 2. [pmid: 10595280].
Møller P, Hagen AI, Apold J, et al. Genetic epidemiology of BRCA mutations - family history detects less than 50% of the mutation carriers. Eur. J. Cancer. 2007;43(11):1713-1717. Exclusion code: 3. [pmid: 17574839].
Moller P, Maehle L, Heimdal K, et al. Inherited breast carcinoma--prospective findings in 1,194 women at risk. Acta Oncol. Suppl 8. 1996;35:7-11. Exclusion code: 8. [pmid: 9073043].
Moller P, Reis MM, Evans G, et al. Efficacy of early diagnosis and treatment in women with a family history of breast cancer. Dis. Markers. 1999;15(1-3):179-186. Exclusion code: 6. [pmid: 10595275].
Montgomery KG, Chang JH, Gertig DM, et al. The AIB1 glutamine repeat polymorphism is not associated with risk of breast cancer before age 40 years in Australian women. Breast Cancer Res. 2005;7(3):R353-356. Exclusion code: 3. [pmid: 15987430].
Moorman PG, Iversen ES, Marcom PK, et al. Evaluation of established breast cancer risk factors as modifiers of BRCA1 or BRCA2: a multi-center case-only analysis. Breast Cancer Res. Treat. 2010;124(2):441-451. Exclusion code: 5. [pmid: 20309627].
Moorman PG, Skinner CS, Evans JP, et al. Racial differences in enrolment in a cancer genetics registry. Cancer Epidemiol. Biomarkers Prev. 2004;13(8):1349-1354. Exclusion code: 5. [pmid: 15298957].
Mor P, Oberle K. Ethical issues related to BRCA gene testing in orthodox Jewish women. Nurs. Ethics. 2008;15(4):512-522. Exclusion code: 5. [pmid: 18515440].
Mora S, Robertson C, Guerrieri GA, et al. A randomized 2 × 2 biomarker trial of low-dose tamoxifen and fenretinide in premenopausal women at high risk for breast cancer. [abstract P41]. Third International Conference and Ninth Annual Meeting of the International Society of Cancer Chemoprevention. 2004;2. Exclusion code: 5.
Morgan D, Sylvester H, Lucas FL, Miesfeldt S. Cancer prevention and screening practices among women at risk for hereditary breast and ovarian cancer after genetic counseling in the community setting. Fam Cancer. 2009;8(4):277-287. Exclusion code: 8. [pmid: 19347608].
Morgan D, Sylvester H, Lucas FL, Miesfeldt S. Hereditary breast and ovarian cancer: referral source for genetic assessment and communication regarding assessment with nongenetic clinicians in the community setting. Genet Med. 2010;12(1):25-31. Exclusion code: 3. [pmid: 20027114].
Morgan D, Sylvester H, Lucas FL, Miesfeldt S. Perceptions of high-risk care and barriers to care among women at risk for hereditary breast and ovarian cancer following genetic counseling in the community setting. J Genet Couns. 2010;19(1):44-54. Exclusion code: 8. [pmid: 19809867].
Morris EA, Liberman L, Ballon DJ, et al. MRI of occult breast carcinoma in a high-risk population. Am. J. Roentgenol. 2003;181(3):619-626. Exclusion code: 2. [pmid: 12933450].
Morrison V, Henderson BJ, Taylor C, A'Ch Dafydd N, Unwin A. The impact of information order on intentions to undergo predictive genetic testing: an experimental study. J Health Psychol. 2010;15(7):1082-1092. Exclusion code: 8. [pmid: 20472604].
Mosca L, Barrett-Connor E, Wenger NK, et al. Design and methods of the Raloxifene Use for The Heart (RUTH) study. Am. J. Cardiol. 2001;88(4):392-395. Exclusion code: 2. [pmid: 11545760].
Moslehi R, Chu W, Karlan B, et al. BRCA1 and BRCA2 mutation analysis of 208 Ashkenazi Jewish women with ovarian cancer. Am. J. Hum. Genet. 2000;66(4):1259-1272. Exclusion code: 2. [pmid: 10739756].
Mouchawar J, Hensley-Alford S, Laurion S, et al. Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005;7(3):191-197. Exclusion code: 2. [pmid: 15775755].
Mouchawar J, Laurion S, Ritzwoller DP, Ellis J, Kulchak-Rahm A, Hensley-Alford S. Assessing controversial direct-to-consumer advertising for hereditary breast cancer testing: reactions from women and their physicians in a managed care organization. Am. J. Manag. Care. 2005;11(10):601-608. Exclusion code: 2. [pmid: 16232001].
Mouchawar J, Valentine Goins K, Somkin C, et al. Guidelines for breast and ovarian cancer genetic counseling referral: Adoption and implementation in HMOs. Genet Med. 2003;5(6):444-450. Exclusion code: 2. [pmid: 14614396].
MRI screening for breast cancer in genetically high-risk women (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000584. Exclusion code: 5.
MRI screening for breast cancer: screening for breast cancer with MRI in genetically high-risk women. Horizon Scanning Prioritising Summary - Volume 3 (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000592. Exclusion code: 5.
Murday V, Pears R, Ball J, Eeles R, Hodgson S. An audit of screening for familial breast cancer before 50 years in the South Thames Region - Have we got it right. Fam Cancer. 2004;3(1):29-34. Exclusion code: 8. [pmid: 15131403].
Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-1489. Exclusion code: 2. [pmid: 15383520].
Murray ML, Cerrato F, Bennett RL, Jarvik GP. Follow-up of carriers of BRCA1 and BRCA2 variants of unknown significance: variant reclassification and surgical decisions. Genet Med. 2011;13(12):998-1005. Exclusion code: 3. [pmid: 21811163].
Genomic tests for ovarian cancer detection and management (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006001022. Exclusion code: 5.
Myers MF, Chang MH, Jorgensen C, et al. Genetic testing for susceptibility to breast and ovarian cancer: evaluating the impact of a direct-to-consumer marketing campaign on physicians' knowledge and practices. Genet Med. 2006;8(6):361-370. Exclusion code: 2. [pmid: 16778598].
Myriad. BRAC Analysis. 2010. www.myriad.com/products/brcanalysis.php. 24 Oct, 2012. Exclusion code: 2.
Myriad. Myriad PRO BRCA1 and BRCA2 Prevalence Tables. 2012. https://www.myriadpro.com/bracanalysis-prevalence-tables. 26 Feb 2013. Exclusion code: 2.
Myriad Genetic Laboratories. BRACAnalysis Technical Specifications. 2011. Exclusion code: 2.
Nagy Z, Csanad M, Toth K, Mate S, Joo JG. Clinical-genetic care of BRCA-mutation carrier women: prevention, diagnosis and therapy. Orv. Hetil. 2011;152(23):913-918. Exclusion code: 7. [pmid: 21592951].
Narod SA. Modifiers of risk of hereditary breast cancer. Oncogene. 2006;25(43):5832-5836. Exclusion code: 5. [pmid: 16998497].
Narod SA. Testing for CHEK2 in the cancer genetics clinic: ready for prime time. Clin. Genet. 2010;78(1):1-7. Exclusion code: 3. [pmid: 20597917].
Narod SA. BRCA mutations in the management of breast cancer: the state of the art. Nat Rev Clin Oncol. 2010;7(12):702-707. Exclusion code: 5. [pmid: 20956982].
Narod SA. The impact of contralateral mastectomy on mortality in BRCA1 and BRCA2 mutation carriers with breast cancer. Breast Cancer Res. Treat. 2011;128(2):581-583. Exclusion code: 3. [pmid: 21455666].
Narod SA. Genetic variants associated with breast-cancer risk. Lancet Oncol. 2011;12(5):415-416. Exclusion code: 5. [pmid: 21514220].
Narod SA. Screening of women at high risk for breast cancer. Prev. Med. 2011;53(3):127-130. Exclusion code: 5. [pmid: 21745498].
Narod SA, Brunet JS, Ghadirian P, et al. Tamoxifen and risk of contralateral breast cancer in BRCA1 and BRCA2 mutation carriers: A case-control study. Lancet. 2000;356(9245):1876-1881. Exclusion code: 3. [pmid: 11130383].
Narod SA, Dubé MP, Klijn J, et al. Oral contraceptives and the risk of breast cancer in BRCA1 and BRCA2 mutation carriers. J. Natl. Cancer Inst. 2002;94(23):1773-1779. Exclusion code: 8. [pmid: 12464649].
Narod SA, Lubinski J, Ghadirian P, et al. Screening mammography and risk of breast cancer in BRCA1 and BRCA2 mutation carriers: a case-control study. Lancet Oncol. 2006;7(5):402-406. Exclusion code: 4. [pmid: 16648044].
Narod SA, Offit K. Prevention and management of hereditary breast cancer. J. Clin. Oncol. 2005;23(8):1656-1663. Exclusion code: 5. [pmid: 15755973].
Narod SA, Risch H, Moslehi R, et al. Oral contraceptives and the risk of hereditary ovarian cancer. N. Engl. J. Med. 1998;339(7):424-428. Exclusion code: 6. [pmid: 9700175].
Narod SA, Sun P, Ghadirian P, et al. Tubal ligation and risk of ovarian cancer in carriers of BRCA1 or BRCA2 mutations: A case-control study. Lancet. 2001;357(9267):1467-1470. Exclusion code: 6. [pmid: 11377596].
National Breast Cancer Center. Advice about familial aspects of breast cancer and ovarian cancer - A guide for health professionals. Sydney. National Breast Cancer Center. 2000. Exclusion code: 2.
National Cancer Institute. Cancer Statistics Review. 1975–2005. http://seer.cancer.gov/csr/1975_2005/index.html. 10 October 2012. Exclusion code: 2.
National Cancer Institute. PDQ® Cancer Information Summary. 2009. http://www.cancer.gov/cancertopics/pdq/genetics/breast-and-ovarian/healthprofessional. 10 October 2012. Exclusion code: 2.
National Cancer Institute. Breast Cancer. 2012. http://www.cancer.gov/cancertopics/types/breast. 10 October 2012. Exclusion code: 2.
National Cancer Institute. Ovarian Cancer. 2012. http://www.cancer.gov/cancertopics/types/ovarian. 10 October 2012. Exclusion code: 2.
National Cancer Institute. (PDQ®) Breast Cancer Screening. 2013. http://www.cancer.gov/cancertopics/pdq/screening/breast/healthprofessional/page1/AllPages. 20 Feb, 2013. Exclusion code: 2.
National Cancer Institute. Breast Cancer. 2013. http://www.cancer.gov/cancertopics/types/breast. 4 March 2013. Exclusion code: 2.
National Cancer Institute. Ovarian Cancer. 2013. http://www.cancer.gov/cancertopics/types/ovarian. 4 March 2013. Exclusion code: 2.
National Cancer Institute. PDQ® Breast Cancer Treatment. 2013. http://www.cancer.gov/cancertopics/pdq/treatment/breast/healthprofessional. 6 Mar, 2013. Exclusion code: 2.
National Cancer Institute. Ovarian Epithelial Cancer Treatment (PDQ®). 2013. http://cancer.gov/cancertopics/pdq/treatment/ovarianepithelial/HealthProfessional. 06 Mar, 2013. Exclusion code: 2.
NCCN Clinical Practice Guidelines in Oncology: Breast Cancer Screening and Diagnosis. 2011. http://www.nccn.org/professionals/physician_gls/pdf/breast-screening.pdf. 16 Oct 2012. Exclusion code: 5.
National Comprehensive Cancer Network. Genetic/Familial High-Risk Assessment Breast and Ovarian. 2012. http://www.nccn.org/professionals/physician_gls/pdf/genetics_screening.pdf. 27 Feb, 2013. Exclusion code: 2.
MammaPrint (gene test) for breast cancer - prognostic test: horizon scanning technology briefing (Project record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32008100372. Exclusion code: 5.
Oncotype DX prognostic and predictive test for early breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010000622. Exclusion code: 5.
Familial breast cancer: the classification and care of women at risk of familial breast cancer in primary, secondary and tertiary care (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32004000675. Exclusion code: 5.
Negura L, Uhrhammer N, Negura A, Artenie V, Carasevici E, Bignon YJ. Complete BRCA mutation screening in breast and ovarian cancer predisposition families from a North-Eastern Romanian population. Fam Cancer. 2010;9(4):519-523. Exclusion code: 3. [pmid: 20567915].
Nelson H, Huffman L, Fu R, Harris E, Walker M, Bougatsos C. Genetic Risk Assessment and BRCA Mutation Testing for Breast and Ovarian Cancer Susceptibility: Evidence Synthesis. Rockville, MD. Agency for Healthcare Research and Quality. 2005. Exclusion code: 2.
Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: evidence synthesis (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32005001123. Exclusion code: 5.
Nelson H, Smith M, Griffin J, Fu R. Use of Medications to Reduce Risk for Primary Breast Cancer: Systematic Review for the 1 U.S. Preventive Services Task Force. [in press]. Ann. Intern. Med. 2013. Exclusion code: 2.
Nelson H, Smith M, Griffin J, Fu R. Use of Medications to Reduce Risk for Primary Breast Cancer: Systematic Review for the U.S. Preventive Services Task Force. Ann. Intern. Med. 2012. (In press). Exclusion code: 2. [pmid: 20722176].
Screening for breast cancer: systematic evidence review update for the U.S. Preventive Services Task Force (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32011000569. Exclusion code: 5.
Nelson HD, Fu R, Griffin JC, Nygren P, Smith MEB, Humphrey L. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann. Intern. Med. 2009;151(10):703-715. W-226. 735. Exclusion code: 2. [pmid: 19920271].
Nelson HD, Fu R, Humphrey L, Smith M, Griffin JC, Nygren P. Comparative Effectiveness of Medications to Reduce Risk of Primary Breast Cancer in Women. Agency for Healthcare Research and Quality. 2009. Exclusion code: 2.
Nelson HD, Zakher B, Cantor A, et al. Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann. Intern. Med. 2012;156(9):635-648. Exclusion code: 2. [pmid: 22547473].
Nelson NJ. Breast cancer prevention in high-risk women: searching for new options. J. Natl. Cancer Inst. 2011;103(9):710-711. Exclusion code: 5. [pmid: 21515834].
Neuhausen S, Gilewski T, Norton L, et al. Recurrent BRCA2 6174delT mutations in Ashkenazi Jewish women affected by breast cancer. Nat. Genet. 1996;13(1):126-128. Exclusion code: 2. [pmid: 8673092].
Neuman B. The Neuman Systems Model. 3 ed. Norwalk, Conn. Appleton & Lange. 1995. Exclusion code: 5.
The early detection and diagnosis of breast cancer: a literature review - an update (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-31998009908. Exclusion code: 5.
Newman LA. Applicability of the Gail model for breast cancer risk assessment in Turkish female population and evaluation of breastfeeding as a risk factor. Breast Cancer Res. Treat. 2010;120(2):425-426. Exclusion code: 5. [pmid: 19967560].
NIH Consensus Development Panel. NIH Consensus conference. Ovarian cancer: Screening, treatment, and follow-up. JAMA. 1995;273(6):491-497. Exclusion code: 2. [pmid: 7837369].
Nisker JA. The need for public education: “Surveillance and risk reduction strategies” for women at risk for carrying BRCA gene mutations. J Obstet Gynaecol Can. 2007;29(6):510-511. Exclusion code: 5. [pmid: 17568484].
Predictive genetic testing for breast and prostate cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-31999008425. Exclusion code: 5.
Nordin K, Roshanai A, Bjorvatn C, et al. Is genetic counseling a stressful event?. Acta Oncol. 2011;50(7):1089-1097. Exclusion code: 3. [pmid: 21864049].
Notaridou M, Quaye L, Dafou D, et al. Common alleles in candidate susceptibility genes associated with risk and development of epithelial ovarian cancer. Int. J. Cancer. 2011;128(9):2063-2074. Exclusion code: 4. [pmid: 20635389].
Nusbaum R, Isaacs C. Management updates for women with a BRCA1 or BRCA2 mutation. Mol Diagn Ther. 2007;11(3):133-144. Exclusion code: 5. [pmid: 17570734].
Obdeijn IMA, Loo CE, Rijnsburger AJ, et al. Assessment of false-negative cases of breast MR imaging in women with a familial or genetic predisposition. Breast Cancer Res. Treat. 2010;119(2):399-407. Exclusion code: 5. [pmid: 19876732].
Ockhuysen-Vermey CF, Henneman L, van Asperen CJ, Oosterwijk JC, Menko FH, Timmermans DRM. Design of the BRISC study: a multicentre controlled clinical trial to optimize the communication of breast cancer risks in genetic counselling. BMC Cancer. 2008;8:283. Exclusion code: 5. [pmid: 18834503].
O'Connell G, Arnold A. Tamoxifen and cancer of the endometrium. Canadian Medical Association Journal = Journal de l'Association Medicale Canadienne. 1993;148:2113-2114. Exclusion code: 5. [pmid: 8324682].
O'Doherty K. Agency and choice in genetic counseling: Acknowledging patients' concerns. J Genet Couns. 2009;18(5):464-474. Exclusion code: 8. [pmid: 19714455].
O'Doherty K, Suthers GK. Risky communication: pitfalls in counseling about risk, and how to avoid them. J Genet Couns. 2007;16(4):409-417. Exclusion code: 5. [pmid: 17473963].
Oei AL, Massuger LF, Bulten J, Ligtenberg MJ, Hoogerbrugge N, De Hullu JA. Surveillance of women at high risk for hereditary ovarian cancer is inefficient. Br. J. Cancer. 2006;94(6):814-819. Exclusion code: 3. [pmid: 16495917].
Oestreicher N, Ramsey SD, Linden HM, et al. Gene expression profiling and breast cancer care: what are the potential benefits and policy implications. Genet Med. 2005;7(6):380-389. Exclusion code: 5. [pmid: 16024969].
Offit K. BRCA Mutation Frequency and Penetrance: New Data, Old Debate. J. Natl. Cancer Inst. 2006;98(23):1675-1677. Exclusion code: 5. [pmid: 17148764].
Offit K, Groeger E, Turner S, Wadsworth EA, Weiser MA. The “duty to warn” a patient's family members about hereditary disease risks. JAMA. 2004;292(12):1469-1473. Exclusion code: 2. [pmid: 15383518].
Olaya W, Esquivel P, Wong JH, et al. Disparities in BRCA testing: when insurance coverage is not a barrier. Am. J. Surg. 2009;198(4):562-565. Exclusion code: 8. [pmid: 19800469].
Olivier RI, Lubsen-Brandsma MAC, Verhoef S, Van Beurden M. CA125 and transvaginal ultrasound monitoring in high-risk women cannot prevent the diagnosis of advanced ovarian cancer. Gynecol. Oncol. 2006;100(1):20-26. Exclusion code: 8. [pmid: 16188302].
Olivier RI, Van Beurden M, Lubsen MAC, et al. Clinical outcome of prophylactic oophorectomy in BRCA1/BRCA2 mutation carriers and events during follow-up. Br. J. Cancer. 2004;90(8):1492-1497. Exclusion code: 3. [pmid: 15083174].
Olopade OI. Using genetic analysis to individualize preventive measures for breast and ovarian cancers. Nat Clin Pract Oncol. 2006;3(4):182-183. Exclusion code: 5. [pmid: 16596140].
Olopade OI, Artioli G. Efficacy of Risk-Reducing Salpingo-Oophorectomy in Women with BRCA-1 and BRCA-2 Mutations. Breast J. 2004;10(1 SUPPL.):S5-S9. Exclusion code: 5. [pmid: 14984481].
Onay VU, Briollais L, Knight JA, et al. SNP-SNP interactions in breast cancer susceptibility. BMC Cancer. 2006;6:114. Exclusion code: 3. [pmid: 16672066].
O'Neill SC, DeMarco T, Peshkin BN, et al. Tolerance for uncertainty and perceived risk among women receiving uninformative BRCA1/2 test results. Am J Med Genet C Semin Med Genet. 2006;142(4):251-259. Exclusion code: 3. [pmid: 17024668].
O'Neill SC, Rini C, Goldsmith RE, Valdimarsdottir H, Cohen LH, Schwartz MD. Distress among women receiving uninformative BRCA1/2 results: 12-month outcomes. Psychooncology. 2009;18(10):1088-1096. Exclusion code: 3. [pmid: 19214961].
O'Neill SC, Valdimarsdottir HB, Demarco TA, et al. BRCA1/2 test results impact risk management attitudes, intentions, and uptake. Breast Cancer Res. Treat. 2010;124(3):755-764. Exclusion code: 8. [pmid: 20383578].
O'Neill SM, Peters JA, Vogel VG, Feingold E, Rubinstein WS. Referral to cancer genetic counseling: are there stages of readiness. Am J Med Genet C Semin Med Genet. 2006;142C(4):221-231. Exclusion code: 8. [pmid: 17068804].
O'Quinn C, Steele P, Ludman MD, Kieser K. Hereditary breast ovarian cancer syndromes in the Maritimes. J Obstet Gynaecol Can. 2010;32(2):155-159. Exclusion code: 5. [pmid: 20181317].
Ormondroyd E, Moynihan C, Ardern-Jones A, et al. Communicating genetics research results to families: problems arising when the patient participant is deceased. Psychooncology. 2008;17(8):804-811. Exclusion code: 8. [pmid: 18688787].
Ormondroyd E, Moynihan C, Watson M, et al. Disclosure of genetics research results after the death of the patient participant: a qualitative study of the impact on relatives. J Genet Couns. 2007;16(4):527-538. Exclusion code: 5. [pmid: 17492498].
Hysterectomy versus hysterectomy plus oophorectomy for premenopausal women. 2010. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=coch&AN=00075320-100000000-04582. Exclusion code: 3.
Osorio A, Milne RL, Alonso R, et al. Evaluation of the XRCC1 gene as a phenotypic modifier in BRCA1/2 mutation carriers. Results from the consortium of investigators of modifiers of BRCA1/BRCA2. Br. J. Cancer. 2011;104(8):1356-1361. Exclusion code: 8. [pmid: 21427728].
Ozakinci G. Psychological and behavioral outcomes of genetic testing for BRCA1/2 mutations among Ashkenazi Jewish women. New Brunswick, NJ, Rutgers. The State University of New Jersey. 2004. Exclusion code: 2.
Ozakinci G, Humphris G, Steel M. Provision of breast cancer risk information to women at the lower end of the familial risk spectrum. Community Genet. 2007;10(1):41-44. Exclusion code: 8. [pmid: 17167250].
Ozanne EM, Wittenberg E, Garber JE, Weeks JC. Breast cancer prevention: patient decision making and risk communication in the high risk setting. Breast J. 2010;16(1):38-47. Exclusion code: 3. [pmid: 19889168].
Pal T, Permuth-Wey J, Betts JA, et al. BRCA1 and BRCA2 mutations account for a large proportion of ovarian carcinoma cases. Cancer. 2005;104(12):2807-2816. Exclusion code: 3. [pmid: 16284991].
Pal T, Permuth-Wey J, Holtje T, Sutphen R. BRCA1 and BRCA2 mutations in a study of African American breast cancer patients. Cancer Epidemiol. Biomarkers Prev. 2004;13(11 Pt 1):1794-1799. Exclusion code: 3. [pmid: 15533909].
Paley PJ, Swisher EM, Garcia RL, et al. Occult cancer of the fallopian tube in BRCA-1 germline mutation carriers at prophylactic oophorectomy: a case for recommending hysterectomy at surgical prophylaxis. Gynecol. Oncol. 2001;80:176-180. Exclusion code: 2. [pmid: 11161856].
Palli D, Falchetti M, Masala G, et al. Association between the BRCA2 N372H variant and male breast cancer risk: a population-based case-control study in Tuscany, Central Italy. BMC Cancer. 2007;7:170. Exclusion code: 3. [pmid: 17767707].
Palma MD, Domchek SM, Stopfer J, et al. The relative contribution of point mutations and genomic rearrangements in BRCA1 and BRCA2 in high-risk breast cancer families. Cancer Res. 2008;68(17):7006-7014. Exclusion code: 3. [pmid: 18703817].
Palmer MK, Ribeiro GG. Thirty-four year follow up of patients with breast cancer in clinical trial of postoperative radiotherapy. Br. Med. J. (Clin. Res. Ed). 1985;291(6502):1088-1091. Exclusion code: 3. [pmid: 3931806].
Palmero EI, Ashton-Prolla P, da Rocha JCC, et al. Clinical characterization and risk profile of individuals seeking genetic counseling for hereditary breast cancer in Brazil. J Genet Couns. 2007;16(3):363-371. Exclusion code: 4. [pmid: 17318454].
Palmero EI, Caleffi M, Schüler-Faccini L, et al. Population prevalence of hereditary breast cancer phenotypes and implementation of a genetic cancer risk assessment program in southern Brazil. Genet Mol Biol. 2009;32(3):447-455. Exclusion code: 8. [pmid: 21637504].
Palmieri G, Palomba G, Cossu A, et al. BRCA1 and BRCA2 germline mutations in Sardinian breast cancer families and their implications for genetic counseling. Ann. Oncol. 2002;13(12):1899-1907. Exclusion code: 3. [pmid: 12453858].
Paradise J, Andrews L, Holbrook T. Intellectual property. Patents on human genes: an analysis of scope and claims. Science. 2005;307(5715):1566-1567. Exclusion code: 5. [pmid: 15761140].
Paradiso A, Bruno M, Cicoria O, et al. Analysis of the reasons for accepting or declining participation in genetic research for breast cancer: a hospital-based population study. Tumori. 2004;90(4):435-436. Exclusion code: 8. [pmid: 15510991].
Paradiso A, Muggia F. Familial breast cancer screening: ethical and social implications. Ann. Oncol. Suppl 1. 2004;15:I5-I6. Exclusion code: 5. [pmid: 15280180].
Park NJ, Kang DH, Weaver MT. Objective and subjective breast cancer risk: Relationships with natural killer cell activity and psychological distress in healthy women. Cancer Nurs. 2010;33(6):411-420. Exclusion code: 4. [pmid: 20562616].
Parker WH, Broder MS, Chang E, et al. Ovarian conservation at the time of hysterectomy and long-term health outcomes in the nurses' health study. Obstet. Gynecol. 2009;113(5):1027-1037. Exclusion code: 4. [pmid: 19384117].
Parkerson GR, Broadhead WE, Tse CKJ. Original contributions. Validation of the Duke Social Support and Stress Scale. Fam. Med. 1991;23(5):357-360. Exclusion code: 2. [pmid: 1884930].
Parmigiani G, Chen S, Iversen ES Jr, et al. Validity of models for predicting BRCA1 and BRCA2 mutations. Ann. Intern. Med. 2007;147(7):441-450. Exclusion code: 5. [pmid: 17909205].
Parthasarathy S. Architectures of genetic medicine: comparing genetic testing for breast cancer in the USA and the UK. Soc Stud Sci. 2005;35(1):5-40. Exclusion code: 4. [pmid: 15991444].
Passaperuma K, Warner E, Causer PA, et al. Long-term results of screening with magnetic resonance imaging in women with BRCA mutations. Br. J. Cancer. 2012;107(1):24-30. Exclusion code: 3. [pmid: 22588560].
Patenaude AF. Helping your patients to deal with a predisposition to genetic disease. JAAPA. 2009;22(11):68-69. Exclusion code: 5. [pmid: 19999182].
Patenaude AF. Prophylactic mastectomy: Insights from women how chose to reduce their risk. Santa Barbara, CA. Praeger/ABC-CLIO; US. 2012. [PMID: Book: 2012-03561-000]. Exclusion code: 5.
Patenaude AF, Dorval M, DiGianni LS, Schneider KA, Chittenden A, Garber JE. Sharing BRCA1/2 test results with first-degree relatives: factors predicting who women tell. J. Clin. Oncol. 2006;24(4):700-706. Exclusion code: 8. [pmid: 16446344].
Patenaude AF, Julian-Reynier C. Cancer genetic testing: Current and emerging issues. Psychooncology. 2008;17(8):733-736. Exclusion code: 5. [pmid: 18688786].
Patenaude AF, Orozco S, Li X, et al. Support needs and acceptability of psychological and peer consultation: attitudes of 108 women who had undergone or were considering prophylactic mastectomy. Psychooncology. 2008;17(8):831-843. Exclusion code: 4. [pmid: 18636423].
Patmasiriwat P, Bhothisuwan K, Sinilnikova OM, et al. Analysis of breast cancer susceptibility genes BRCA1 and BRCA2 in Thai familial and isolated early-onset breast and ovarian cancer. Hum. Mutat. 2002;20(3):230. Exclusion code: 8. [pmid: 12203997].
Peacock S, Apicella C, Andrews L, et al. A discrete choice experiment of preferences for genetic counselling among Jewish women seeking cancer genetics services. Br. J. Cancer. 2006;95(10):1448-1453. Exclusion code: 8. [pmid: 17102813].
Peelen T, van Vliet M, Petrij-Bosch A, et al. A high proportion of novel mutations in BRCA1 with strong founder effects among Dutch and Belgian hereditary breast and ovarian cancer families. Am J Hum Genet. 1997;60(5):1041-1049. Exclusion code: 2. [pmid: 9150151].
Pellegrini I, Rapti M, Extra JM, et al. Tailored chemotherapy based on tumour gene expression analysis: breast cancer patients' misinterpretations and positive attitudes. Eur. J Cancer Care. 2012;21(2):242-250. Exclusion code: 3. [pmid: 22070677].
Peng S, Lü B, Ruan W, Zhu Y, Sheng H, Lai M. Genetic polymorphisms and breast cancer risk: Evidence from meta-analyses, pooled analyses, and genome-wide association studies. Breast Cancer Res. Treat. 2011;127(2):309-324. Exclusion code: 2. [pmid: 21445572].
Pennisi VR, Capozzi A. Subcutaneous mastectomy data. Aesthetic Plast. Surg. 1989;13:15-21. Exclusion code: 2. [pmid: 2728994].
Perez GK, Cruess DG, Cruess S, et al. Attitudes toward direct-to-consumer advertisements and online genetic testing among high-risk women participating in a hereditary cancer clinic. J Health Commun. 2011;16(6):607-628. Exclusion code: 2. [pmid: 21432710].
Perez Segura P, Jimenez P, Olivera H, et al. Risk-reduction surgery in BRCA mutation carriers in a Spanish population: adherence and results. Clin Transl Oncol. 2008;10(10):660-664. Exclusion code: 3. [pmid: 18940747].
Perry CE. Managing susceptibility to hereditary breast and ovarian cancer. Perry, Cynthia E. U San Diego. US. 2006. Exclusion code: 5.
Peshkin BN. Breast cancer risk assessment and genetic testing: complexities, conundrums, and community. Breast Dis. 2006;27:1-3. Exclusion code: 5. [pmid: 17917137].
Peshkin BN, Demarco TA, Tercyak KP. On the development of a decision support intervention for mothers undergoing BRCA1/2 cancer genetic testing regarding communicating test results to their children. Fam Cancer. 2010;9(1):89-97. Exclusion code: 5. [pmid: 19609726].
Peshkin BN, Isaacs C. Evaluation and management of women with BRCA1/2 mutations. Oncology (Williston Park). 2005;19(11):1451-1459. discussion 1459-1468 1474. Exclusion code: 5. [pmid: 16370446].
Peshkin BN, Nusbaum RH, DeMarco TA. Genetic counseling about reproductive options for hereditary cancer: what is the standard of care. J. Clin. Oncol. 2007;25(7):911-912. author reply 913. Exclusion code: 5. [pmid: 17327618].
Petersen RW, Quinlivan JA. Preventing anxiety and depression in gynaecological cancer: a randomised controlled trial. Bjog. 2002;109(4):386-394. Exclusion code: 3. [pmid: 12013159].
Peto J, Collins N, Barfoot R, et al. Prevalence of BRCA1 and BRCA2 gene mutations in patients with early-onset breast cancer. J. Natl. Cancer Inst. 1999;91(11):943-949. Exclusion code: 2. [pmid: 10359546].
Petracci E, Decarli A, Schairer C, et al. Risk factor modification and projections of absolute breast cancer risk. J. Natl. Cancer Inst. 2011;103(13):1037-1048. Exclusion code: 2. [pmid: 21705679].
Petrucelli N, Daly MB, Feldman GL. Hereditary breast and ovarian cancer due to mutations in BRCA1 and BRCA2. Genet Med. 2010;12(5):245-259. Exclusion code: 5. [pmid: 20216074].
False-negative results in screening programmes: systematic review of impact and implications (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32000008231. Exclusion code: 5.
Petticrew MP, Sowden AJ, Lister Sharp D, Wright K. False-negative results in screening programmes: systematic review of impact and implications. Health Technol. Assess. 2000;4(5):1-120. Exclusion code: 5. [pmid: 10859208].
Pharoah PD, Day NE, Duffy S, Easton DF, Ponder BA. Family history and the risk of breast cancer: a systematic review and meta-analysis. Int. J. Cancer. 1997;71(5):800-809. Exclusion code: 2. [pmid: 9180149].
Phelps C, Wood F, Bennett P, Brain K, Gray J. Knowledge and expectations of women undergoing cancer genetic risk assessment: a qualitative analysis of free-text questionnaire comments. J Genet Couns. 2007;16(4):505-514. Exclusion code: 4. [pmid: 17318449].
Phillips KA, Jenkins MA, Lindeman GJ, et al. Risk-reducing surgery, screening and chemoprevention practices of BRCA1 and BRCA2 mutation carriers: a prospective cohort study. Clin. Genet. 2006;70(3):198-206. Exclusion code: 8. [pmid: 16922722].
Pichert G, Stahel RA. Organizing cancer genetics programs: the Swiss model. J. Clin. Oncol. 2000;18(21 Suppl):65S-69S. Exclusion code: 2. [pmid: 11060330].
Pierce BL, Carlson CS, Kuszler PC, Stanford JL, Austin MA. The impact of patents on the development of genome-based clinical diagnostics: an analysis of case studies. Genet Med. 2009;11(3):202-209. Exclusion code: 2. [pmid: 19367193].
Pieterse AH, van Dulmen AM, Beemer FA, Bensing JM, Ausems MG. Cancer genetic counseling: Communication and counselees' post-visit satisfaction, cognitions, anxiety, and needs fulfillment. J Genet Couns. 2007;16(1):85-96. Exclusion code: 3. [pmid: 17295054].
Pieterse AH, van Dulmen S, van Dijk S, Bensing JM, Ausems MGEM. Risk communication in completed series of breast cancer genetic counseling visits. Genet Med. 2006;8(11):688-696. Exclusion code: 3. [pmid: 17108760].
Pieterse K, van Dooren S, Seynaeve C, et al. Passive coping and psychological distress in women adhering to regular breast cancer surveillance. Psychooncology. 2007;16(9):851-858. Exclusion code: 8. [pmid: 17219399].
Pietschmann A, Mehdipour P, Atri M, et al. Mutation analysis of BRCA1 and BRCA2 genes in Iranian high risk breast cancer families. J. Cancer Res. Clin. Oncol. 2005;131(8):552-558. Exclusion code: 8. [pmid: 15918047].
Pijpe A, Andrieu N, Easton DF, et al. Exposure to diagnostic radiation and risk of breast cancer among carriers of BRCA1/2 mutations: retrospective cohort study (GENE-RAD-RISK). BMJ. 2012;345. Exclusion code: 3. [pmid: 22956590].
Piver MS, Jishi MF, Tsukada Y, Nava G. Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry. Cancer. 1993;71(9):2751-2755. Exclusion code: 2. [pmid: 8467455].
Pizzichetta MA, Giuliotto N, Calzavara GI, et al. Study of chemoprevention in breast carcinoma with tamoxifen. Tumori. 1994;80(4):110. Exclusion code: 5.
Plon SE, Cooper HP, Parks B, et al. Genetic testing and cancer risk management recommendations by physicians for at-risk relatives. Genet Med. 2011;13(2):148-154. Exclusion code: 8. [pmid: 21224735].
Plon SE, Peterson LE, Friedman LC, Richards CS. Mammography behavior after receiving a negative BRCA1 mutation test result in the Ashkenazim: A community-based study. Genet Med. 2000;2(6):307-311. Exclusion code: 6. [pmid: 11339650].
Posluszny DM, McFeeley S, Hall L, Baum A. Stress, breast cancer risk, and breast self-examination: Chronic effects of risk and worry. Journal of Applied Biobehavioral Research. 2004;9(2):91-105. Exclusion code: 2.
Power TE. The decision to undergo genetic testing for BRCA1/2 in a community sample of Ashkenazi Jewish women: Coping with the risk of cancer or coping with anticipated emotion?. Power, Tara E. U Western Ontario. Canada. 2006. Exclusion code: 8.
Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352(9122):98-101. Exclusion code: 2. [pmid: 9672274].
Powles TJ. Chemoprevention of breast cancer using tamoxifen. Endocr Relat Cancer. 1997;4:255-260. Exclusion code: 5.
Powles TJ, Davey JB, McKinna A. A feasibility trial of tamoxifen chemoprevention of breast cancer in Great Britain. Cancer Invest. 1988;6(5):621-624. Exclusion code: 5. [pmid: 3063341].
Powles TJ, Hickish TF, Kedar R. Update of the Royal Marsden Hospital tamoxifen prevention programme in healthy women at increased risk of breast cancer. Proceedings of American Society of Clincial Oncology. 1994;13. Exclusion code: 5.
Powles TJ, Jones AL, Ashley SE, et al. The Royal Marsden Hospital pilot tamoxifen chemoprevention trial. Breast Cancer Res. Treat. 1994;31(1):73-82. Exclusion code: 5. [pmid: 7981459].
Powles TJ, McKinna A, Davey J. Chemoprevention of breast cancer. J. Endocrinol. 1993;137(3 suppl):S32. Exclusion code: 5.
Press N, Reynolds S, Pinsky L, Murthy V, Leo M, Burke W. ‘That's like chopping off a finger because you're afraid it might get broken’: disease and illness in women's views of prophylactic mastectomy. Soc. Sci. Med. 2005;61(5):1106-1117. Exclusion code: 8. [pmid: 15955410].
Pruthi S, Gostout BS, Lindor NM. Identification and Management of Women With BRCA Mutations or Hereditary Predisposition for Breast and Ovarian Cancer. Mayo Clin. Proc. 2010;85(12):1111-1120. Exclusion code: 5. [pmid: 21123638].
Qiu LX, Yao L, Xue K, et al. BRCA2 N372H polymorphism and breast cancer susceptibility: a meta-analysis involving 44,903 subjects. Breast Cancer Res. Treat. 2010;123(2):487-490. Exclusion code: 5. [pmid: 20135345].
Quach J, Porter K, Leventhal H, Kelly KM. Health behaviors among Ashkenazi Jewish individuals receiving counseling for BRCA1 and BRCA2 mutations. Fam Cancer. 2009;8(3):241-250. Exclusion code: 8. [pmid: 19184534].
Quillin JM, Bodurtha JN, McClish D, Wilson DB. Genetic risk, perceived risk, and cancer worry in daughters of breast cancer patients. J Genet Couns. 2011;20(2):157-164. Exclusion code: 4. [pmid: 21132457].
Quillin JM, Fries E, McClish D, deParedes ES, Bodurtha J. Gail Model Risk Assessment and Risk Perceptions. J. Behav. Med. 2004;27(2):205-214. Exclusion code: 8. [pmid: 15171107].
Quillin JM, Lyckholm LJ. A principle-based approach to ethical issues in predictive genetic testing for breast cancer. Breast Dis. 2007;27:137-148. Exclusion code: 5. [pmid: 17917145].
Quillin JM, McClish DK, Jones RM, Burruss K, Bodurtha JN. Spiritual coping, family history, and perceived risk for breast cancer--can we make sense of it. J Genet Couns. 2006;15(6):449-460. Exclusion code: 4. [pmid: 17013546].
Quinn GP, Vadaparampil ST, Bower B, Friedman S, Keefe DL. Decisions and ethical issues among BRCA carriers and the use of preimplantation genetic diagnosis. Minerva Med. 2009;100(5):371-383. Exclusion code: 5. [pmid: 19910890].
Radner LL. Cancer-free women living with the breast cancer gene mutation: A narrative investigation. Radner, Lori L. Michigan School of Professional Psychology. US. 2012. Exclusion code: 4.
Radtke JV, Terhorst L, Cohen SM. The menopause-specific quality of life questionnaire: Psychometric evaluation among breast cancer survivors. Menopause. 2011;18(3):289-295. Exclusion code: 2. [pmid: 20881889].
Rafnar T, Benediktsdottir KR, Eldon BJ, et al. BRCA2, but not BRCA1, mutations account for familial ovarian cancer in Iceland: a population-based study. Eur. J. Cancer. 2004;40(18):2788-2793. Exclusion code: 3. [pmid: 15571962].
Rahm AK. Direct-to-consumer genetics: Media messages and public perceptions. Denver. Health and Bahvioral Science, University of Colorado. 2010. Exclusion code: 2.
Rahman N, Stratton MR. The genetics of breast cancer susceptibility. Annu. Rev. Genet. 1998;32:95-121. Exclusion code: 2. [pmid: 9928476].
Ramus SJ, Antoniou AC, Kuchenbaecker KB, et al. Ovarian cancer susceptibility alleles and risk of ovarian cancer in BRCA1 and BRCA2 mutation carriers. Hum. Mutat. 2012;33(4):690-702. Exclusion code: 8. [pmid: 22253144].
Ratajska M, Brozek I, Senkus-Konefka E, et al. BRCA1 and BRCA2 point mutations and large rearrangements in breast and ovarian cancer families in Northern Poland. Oncol. Rep. 2008;19(1):263-268. Exclusion code: 8. [pmid: 18097605].
Ray JA, Loescher LJ, Brewer M. Risk-reduction surgery decisions in high-risk women seen for genetic counseling. J Genet Couns. 2005;14(6):473-484. Exclusion code: 8. [pmid: 16388328].
Ready KJ, Vogel KJ, Atchley DP, et al. Accuracy of the BRCAPRO model among women with bilateral breast cancer. Cancer. 2009;115(4):725-730. Exclusion code: 3. [pmid: 19127556].
Rebbeck TR. Prophylactic oophorectomy in BRCA1 and BRCA2 mutation carriers. Eur. J. Cancer. 2002;38(Suppl 6):S15-S17. Exclusion code: 5. [pmid: 12409058].
Rebbeck TR. Inherited predisposition and breast cancer: Modifiers of BRCA1/2-associated breast cancer risk. Environ. Mol. Mutagen. 2002;39(2-3):228-234. Exclusion code: 5. [pmid: 11921193].
Rebbeck TR, Friebel T, Lynch HT, et al. Bilateral Prophylactic Mastectomy Reduces Breast Cancer Risk in BRCA1 and BRCA2 Mutation Carriers: the PROSE Study Group. J. Clin. Oncol. 2004;22(6):1055-1062. Exclusion code: 5. [pmid: 14981104].
Rebbeck TR, Friebel T, Wagner T, et al. Effect of short-term hormone replacement therapy on breast cancer risk reduction after bilateral prophylactic oophorectomy in BRCA1 and BRCA2 mutation carriers: the PROSE Study Group. J. Clin. Oncol. 2005;23(31):7804-7810. Exclusion code: 4. [pmid: 16219936].
Rebbeck TR, Kauff ND, Domchek SM. Meta-analysis of risk reduction estimates associated with risk-reducing salpingo-oophorectomy in BRCA1 or BRCA2 mutation carriers. J. Natl. Cancer Inst. 2009;101(2):80-87. Exclusion code: 5. [pmid: 19141781].
Rebbeck TR, Levin AM, Eisen A, et al. Breast cancer risk after bilateral prophylactic oophorectomy in BRCA1 mutation carriers. J. Natl. Cancer Inst. 1999;91(17):1475-1479. Exclusion code: 5. [pmid: 10469748].
Rebbeck TR, Lynch HT, Neuhausen SL, et al. Prophylactic oophorectomy in carriers of BRCA1 or BRCA2 mutations. N. Engl. J. Med. 2002;346(21):1616-1622. Exclusion code: 5. [pmid: 12023993].
Rebbeck TR, Mitra N, Domchek SM, et al. Modification of BRCA1-Associated Breast and Ovarian Cancer Risk by BRCA1-Interacting Genes. Cancer Res. 2011;71(17):5792-5805. Exclusion code: 4. [pmid: 21799032].
Rebbeck TR, Wang Y, Kantoff PW, et al. Modification of BRCA1- and BRCA2-associated breast cancer risk by AIB1 genotype and reproductive history. Cancer Res. 2001;61(14):5420-5424. Exclusion code: 8. [pmid: 11454686].
Rees G, Fry A, Cull A, Sutton S. Illness perceptions and distress in women at increased risk of breast cancer. Psychol Health. 2004;19(6):749-765. Exclusion code: 4.
Rees G, Gaff C, Young MA, Martin PR. Health beliefs and behaviors of women who have received genetic counseling for breast cancer. J Genet Couns. 2007;16(4):457-468. Exclusion code: 5. [pmid: 17619128].
Reis MM, Tavakoli M, Dewar J, et al. Evaluation of a surveillance programme for women with a family history of breast cancer. J. Med. Genet. 2009;46(5):319-323. Exclusion code: 3. [pmid: 19279022].
Rennert G, Bisland-Naggan S, Barnett-Griness O, et al. Clinical outcomes of breast cancer in carriers of BRCA1 and BRCA2 mutations. N. Engl. J. Med. 2007;357(2):115-123. Exclusion code: 3. [pmid: 17625123].
Rennert G, Dishon S, Rennert HS, Fares F. Differences in the characteristics of families with BRCA1 and BRCA2 mutations in Israel. Eur. J. Cancer Prev. 2005;14(4):357-361. Exclusion code: 8. [pmid: 16030426].
Rhiem K, Foth D, Wappenschmidt B, et al. Risk-reducing salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers. Arch. Gynecol. Obstet. 2011;283(3):623-627. Exclusion code: 3. [pmid: 20428881].
Richardson H, Johnston D, Pater J, Goss P. The National Cancer Institute of Canada Clinical Trials Group MAP.3 trial: An international breast cancer prevention trial. Curr Oncol. 2007;14(3):89-95. Exclusion code: 5. [pmid: 17593981].
Ridge Y, Panabaker K, McCullum M, Portigal-Todd C, Scott J, McGillivray B. Evaluation of group genetic counseling for hereditary breast and ovarian cancer. J Genet Couns. 2009;18(1):87-100. Exclusion code: 8. [pmid: 19127417].
Riedl CC, Ponhold L, Flöry D, et al. Magnetic resonance imaging of the breast improves detection of invasive cancer, preinvasive cancer, and premalignant lesions during surveillance of women at high risk for breast cancer. Clin. Cancer Res. 2007;13(20):6144-6152. Exclusion code: 3. [pmid: 17947480].
Riley BD, Culver JO, Skrzynia C, et al. Essential elements of genetic cancer risk assessment, counseling, and testing: updated recommendations of the National Society of Genetic Counselors. J Genet Couns. 2012;21(2):151-161. Exclusion code: 2. [pmid: 22134580].
Riman T, Persson I, Nilsson S. Hormonal aspects of epithelial ovarian cancer: Review of epidemiological evidence. Clin. Endocrinol. (Oxf). 1998;49(6):695-707. Exclusion code: 5. [pmid: 10209555].
Rimer BK, Sugarman J, Winer E, Bluman LG, Lerman C. Informed consent for BRCA1 and BRCA2 testing. Breast Dis. 1998;10(1-2):99-114. Exclusion code: 6. [pmid: 15687553].
Rimes KA, Salkovskis PM, Jones L, Lucassen AM. Applying a cognitive-behavioral model of health anxiety in a cancer genetics service. Health Psychol. 2006;25(2):171-180. Exclusion code: 3. [pmid: 16569108].
Rini C, O'Neill SC, Valdimarsdottir H, et al. Cognitive and emotional factors predicting decisional conflict among high-risk breast cancer survivors who receive uninformative BRCA1/2 results. Health Psychol. 2009;28(5):569-578. Exclusion code: 3. [pmid: 19751083].
Ripperger T, Gadzicki D, Meindl A, Schlegelberger B. Breast cancer susceptibility: current knowledge and implications for genetic counselling. Eur. J. Hum. Genet. 2009;17(6):722-731. Exclusion code: 5. [pmid: 19092773].
Robertson C, Arcot Ragupathy SK, Boachie C, et al. The clinical effectiveness and costeffectiveness of different surveillance mammography regimens after the treatment for primary breast cancer: Systematic reviews, registry database analyses and economic evaluation. Health Technol. Assess. 2011;15(34):V-136. Exclusion code: 8. [pmid: 21951942].
Robertson L, Hanson H, Seal S, et al. BRCA1 testing should be offered to individuals with triple-negative breast cancer diagnosed below 50 years. Br. J. Cancer. 2012;106(6):1234-1238. Exclusion code: 2. [pmid: 22333603].
Robles-Diaz L, Goldfrank DJ, Kauff ND, Robson M, Offit K. Hereditary ovarian cancer in Ashkenazi Jews. Fam Cancer. 2004;3(3-4):259-264. Exclusion code: 5. [pmid: 15516850].
Robson M. Do women remain at risk even if they do not inherit a familial BRCA1/2 mutation. J. Clin. Oncol. 2011;29(34):4477-4478. Exclusion code: 5. [pmid: 22042956].
Robson M, Gilewski T, et al. BRCA-associated breast cancer in young women. J. Clin. Oncol. 1998;16:1642-1649. Exclusion code: 2. [pmid: 9586873].
Robson M, Offit K. Clinical practice. Management of an inherited predisposition to breast cancer. N. Engl. J. Med. 2007;357(2):154-162. Exclusion code: 5. [pmid: 17625127].
Robson ME, Offit K. Breast MRI for women with hereditary cancer risk. JAMA. 2004;292(11):1368-1370. Exclusion code: 8. [pmid: 15367560].
Robson ME, Storm CD, Weitzel J, Wollins DS, Offit K. American Society of Clinical Oncology Policy Statement update: Genetic and genomic testing for cancer susceptibility. J. Clin. Oncol. 2010;28(5):893-901. Exclusion code: 2. [pmid: 20065170].
Rockhill B, Byrne C, Rosner B, Louie MM, Colditz G. Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J. Clin. Epidemiol. 2003;56(9):856-861. Exclusion code: 2. [pmid: 14505770].
Rockhill B, Spiegelman D, Byrne C, et al. Validation of the Gail, et al model of breast cancer risk prediction and implications for chemoprevention. J. Natl. Cancer Inst. 2001;93:358-366. Exclusion code: 2. [pmid: 11238697].
Rodriguez SR, Osborne D, Jacobellis J. Health Plan Implementation of U.S. Preventive Services Task Force A and B Recommendations -- Colorado, 2010. MMWR. 2011;60(39):1348-1350. Exclusion code: 5. [pmid: 21976117].
Rolnick SJ, Altschuler A, Nekhlyudov L, et al. What women wish they knew before prophylactic mastectomy. Cancer Nurs. 2007;30(4):285-293. Exclusion code: 8. [pmid: 17666977].
Ronckers CM, Erdmann CA, Land CE. Radiation and breast cancer: A review of current evidence. Breast Cancer Res. 2005;7(1):21-32. Exclusion code: 8. [pmid: 15642178].
Rosen B, Kwon J, Fung MFK, Gagliardi A, Chambers A. Systematic review of management options for women with a hereditary predisposition to ovarian cancer. Gynecol. Oncol. 2004;93(2):280-286. Exclusion code: 6. [pmid: 15099934].
Roshanai AH, Rosenquist R, Lampic C, Nordin K. Cancer genetic counselees' self-reported psychological distress, changes in life, and adherence to recommended surveillance programs 3-7 years post counseling. J Genet Couns. 2009;18(2):185-194. Exclusion code: 3. [pmid: 19212811].
Rothemund Y, Paepke S, Flor H. Perception of risk, anxiety, and health behaviors in women at high risk for breast cancer. International Journal of Behavioral Medicine. 2001;8(3):230-239. Exclusion code: 6.
Rothwell E, Kohlmann W, Jasperson K, Gammon A, Wong B, Kinney A. Patient outcomes associated with group and individual genetic counseling formats. Fam Cancer. 2012;11(1):97-106. Exclusion code: 3. [pmid: 22057473].
Roudgari H, Miedzybrodzka ZH, Haites NE. Probability estimation models for prediction of BRCA1 and BRCA2 mutation carriers: COS compares favourably with other models. Fam Cancer. 2008;7(3):199-212. Exclusion code: 8. [pmid: 18097771].
Roussi P, Miller SM. Genetic testing for breast and ovarian cancer: A review of psychological and behavioral outcomes. Hellenic Journal of Psychology. 2005;2(2):135-158. Exclusion code: 5.
Roussi P, Sherman KA, Miller S, et al. Enhanced counselling for women undergoing BRCA1/2 testing: Impact on knowledge and psychological distress-results from a randomised clinical trial. Psychol Health. 2010;25(4):401-415. Exclusion code: 3. [pmid: 20204945].
Roussi P, Sherman KA, Miller SM, et al. Identification of cognitive profiles among women considering BRCA1/2 testing through the utilisation of cluster analytic techniques. Psychol Health. 2011;26(10):1327-1343. Exclusion code: 3. [pmid: 21756124].
Rowan K. Beyond the Gail model: lobular involution may help refine breast cancer risk assessment. J. Natl. Cancer Inst. 2009;101(3):134-135. Exclusion code: 5. [pmid: 19176450].
Rowe J. Health locus of control expectancies and perceived risk for breast cancer in women. Rowe, Jennifer. Yeshiva U. US. 2004. Exclusion code: 8.
Rowe JL, Montgomery GH, Duberstein PR, Bovbjerg DH. Health locus of control and perceived risk for breast cancer in healthy women. Behav. Med. 2005;31(1):33-40. Exclusion code: 4. [pmid: 16078524].
Rubinstein WS, Acheson LS, O'Neill SM, et al. Clinical utility of family history for cancer screening and referral in primary care: a report from the Family Healthware Impact Trial. Genet Med. 2011;13(11):956-965. Exclusion code: 3. [pmid: 22075527].
Rueth NM, McMahon M, Arrington AK, Swenson K, Leach J, Tuttle TM. Preoperative risk assessment among women undergoing bilateral prophylactic mastectomy for cancer risk reduction. Ann. Surg. Oncol. 2011;18(9):2515-2520. Exclusion code: 8. [pmid: 21424371].
Rumiantseva UV, Rumiantsev PO, Kiseleva MV. Peculiarities of diagnosis, treatment and prevention of hereditary cancer of the breast and ovary. Clinical and genetic screening among BRCA1/2 mutation carriers and individuals with high family risk of cancer. Vopr. Onkol. 2008;54(3):251-259. Exclusion code: 7. [pmid: 18652227].
Rutter JL, Wacholder S, Chetrit A, et al. Gynecologic surgeries and risk of ovarian cancer in women with BRCA1 and BRCA2 Ashkenazi founder mutations: An Israeli population-based case-control study. J. Natl. Cancer Inst. 2003;95(14):1072-1078. Exclusion code: 6. [pmid: 12865453].
Saetersdal A, Dorum A, Heimdal K, et al. Inherited predisposition to breast carcinoma. Results of first round examination of 537 women at risk. Anticancer Res. 1996;16(4A):1989-1992. Exclusion code: 8. [pmid: 8712731].
Salhab M, Al Sarakbi W, Joseph A, Sheards S, Travers J, Mokbel K. Skin-sparing mastectomy and immediate breast reconstruction: patient satisfaction and clinical outcome. Int J Clin Oncol. 2006;11(1):51-54. Exclusion code: 3. [pmid: 16508729].
Salhab M, Bismohun S, Mokbel K. Risk-reducing strategies for women carrying BRCA1/2 mutations with a focus on prophylactic surgery. BMC Womens Health. 2010;10:28. Exclusion code: 5. [pmid: 20961453].
Salsman JM, Pavlik E, Boerner LM, Andrykowski MA. Clinical, demographic, and psychological characteristics of new, asymptomatic participants in a transvaginal ultrasound screening program for ovarian cancer. Prev. Med. 2004;39(2):315-322. Exclusion code: 4. [pmid: 15226040].
Salzberg SL, Pertea M. Do-it-yourself genetic testing. Genome Biol. 2010;11(10):404. Exclusion code: 5. [pmid: 20932271].
Samphao S, Wheeler AJ, Rafferty E, et al. Diagnosis of breast cancer in women age 40 and younger: delays in diagnosis result from underuse of genetic testing and breast imaging. Am. J. Surg. 2009;198(4):538-543. Exclusion code: 3. [pmid: 19800464].
Samuel JC, Ollila DW. Prophylaxis and screening options: recommendations for young women with BRCA mutations. Breast Dis. 2005;23:31-35. Exclusion code: 5. [pmid: 16823164].
Sardanelli F, Podo F, D'Agnolo G, et al. Multicenter comparative multimodality surveillance of women at genetic-familial high risk for breast cancer (HIBCRIT study): interim results. Radiology. 2007;242(3):698-715. Exclusion code: 3. [pmid: 17244718].
Saslow D, Boetes C, Burke W, et al. American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography. CA. Cancer J. Clin. 2007;57(2):75-89. Exclusion code: 5. [pmid: 17392385].
Satagopan JM, Offit K, Foulkes W, et al. The lifetime risks of breast cancer in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(5):467-473. Exclusion code: 2. [pmid: 11352856].
Sattin RW, Rubin GL, Webster LA. Family history and the risk of breast cancer. JAMA. 1985;253(13):1908-1913. Exclusion code: 6. [pmid: 3974080].
Saunders KH, Nazareth S, Pressman PI. Case report: BRCA in the Ashkenazi population: Are current testing guidelines too exclusive?. Hered Cancer Clin Pract. 2011;9(1). Exclusion code: 5. [pmid: 21711529].
Scheuer L, Kauff N, Robson M, et al. Outcome of preventive surgery and screening for breast and ovarian cancer in BRCA mutation carriers. J. Clin. Oncol. 2002;20(5):1260-1268. Exclusion code: 3. [pmid: 11870168].
Schiffman SC, Chagpar AB. Does a family history of male breast cancer influence risk perception and use of genetic testing. Am. Surg. 2010;76(8):879-882. Exclusion code: 8. [pmid: 20726421].
Schlebusch CM, Dreyer G, Sluiter MD, Yawitch TM, van den Berg HJ, van Rensburg EJ. Cancer prevalence in 129 breast-ovarian cancer families tested for BRCA1 and BRCA2 mutations. S. Afr. Med. J. 2010;100(2):113-117. Exclusion code: 3. [pmid: 20459916].
Schlich-Bakker KJ, ten Kroode HFJ, Ausems MGEM. A literature review of the psychological impact of genetic testing on breast cancer patients. Patient Educ. Couns. 2006;62(1):13-20. Exclusion code: 3. [pmid: 16242293].
Schmeler KM, Sun CC, Bodurka DC, et al. Prophylactic bilateral salpingo-oophorectomy compared with surveillance in women with BRCA mutations. Obstet. Gynecol. 2006;108(3 Pt 1):515-520. Exclusion code: 8. [pmid: 16946209].
Schmitz N, Hartkamp N, Kiuse J, Franke GH, Reister G, Tress W. The Symptom Check-List-90-R (SCL-90-R): A German validation study. Qual. Life Res. 2000;9(2):185-193. Exclusion code: 2. [pmid: 10983482].
Schneegans SM, Rosenberger A, Engel U, Sander M, Emons G, Shoukier M. Validation of three BRCA1/2 mutation-carrier probability models Myriad, BRCAPRO and BOADICEA in a population-based series of 183 German families. Fam Cancer. 2012;11(2):181-188. Exclusion code: 3. [pmid: 22160602].
Schneider KA, Chittenden AB, Branda KJ, et al. Ethical issues in cancer genetics: I 1) whose information is it. J Genet Couns. 2006;15(6):491-503. Exclusion code: 8. [pmid: 17106632].
Schonfeld SJ, Pee D, Greenlee RT, et al. Effect of changing breast cancer incidence rates on the calibration of the Gail model. J. Clin. Oncol. 2010;28(14):2411-2417. Exclusion code: 2. [pmid: 20368565].
Schrading S, Kuhl CK. Mammographic, US, and MR imaging phenotypes of familial breast cancer. Radiology. 2008;246(1):58-70. Exclusion code: 8. [pmid: 18096529].
Schroevers MJ, Sanderman R, Van Sonderen E, Ranchor AV. The evaluation of the Center for Epidemiologic Studies Depression (CES-D) scale: Depressed and Positive Affect in cancer patients and healthy reference subjects. Qual. Life Res. 2000;9(9):1015-1029. Exclusion code: 2. [pmid: 11332223].
Schwartz MD, Isaacs C, Graves KD, et al. Long-term outcomes of BRCA1/BRCA2 testing: risk reduction and surveillance. Cancer. 2012;118(2):510-517. Exclusion code: 8. [pmid: 21717445].
Segal J, Esplen MJ, Toner B, Baedorf S, Narod S, Butler K. An investigation of the disclosure process and support needs of BRCA1 and BRCA2 carriers. Am J Med Genet A. 2004;125A(3):267-272. Exclusion code: 2(MW used in her draft). [pmid: 14994235].
Seyednoori T, Pakseresht S, Roushan Z. Risk of developing breast cancer by utilizing Gail model. Women Health. 2012;52(4):391-402. Exclusion code: 8. [pmid: 22591234].
Seymour IJ, Casadei S, Zampiga V, et al. Disease family history and modification of breast cancer risk in common BRCA2 variants. Oncol. Rep. 2008;19(3):783-786. Exclusion code: 3. [pmid: 18288416].
Shah P, Rosen M, Stopfer J, et al. Prospective study of breast MRI in BRCA1 and BRCA2 mutation carriers: effect of mutation status on cancer incidence. Breast Cancer Res. Treat. 2009;118(3):539-546. Exclusion code: 3. [pmid: 19609668].
Shannon KM, Rodgers LH, Chan-Smutko G, Patel D, Gabree M, Ryan PD. Which individuals undergoing BRACAnalysis need BART testing. Cancer Genet. 2011;204(8):416-422. Exclusion code: 8. [pmid: 21962891].
Shapiro DE, Rodrigue JR, Boggs SR, Robinson ME. Cluster analysis of the medical coping modes questionnaire: Evidence for coping with cancer styles. J. Psychosom. Res. 1994;38(2):151-159. Exclusion code: 2. [pmid: 8189404].
Shapiro SP, Nunez C. Psammoma bodies in the cervicovaginal smear in association with a papillary tumor of the peritoneum. Obstet. Gynecol. 1983;61(1):130-134. Exclusion code: 6. [pmid: 6823343].
Sharff ME, DeMarco TA, Mays D, et al. Parenting through genetic uncertainty: themes in the disclosure of breast cancer risk information to children. Genet Test Mol Biomarkers. 2012;16(5):376-382. Exclusion code: 2. [pmid: 22085394].
Shattuck-Eidens D, Oliphant A, McClure M, et al. BRCA1 sequence analysis in women at high risk for susceptibility mutations: Risk factor analysis and implications for genetic testing. JAMA. 1997;278(15):1242-1250. Exclusion code: 2. [pmid: 9333265].
Shedlosky-Shoemaker R, Ngo TL, Ferketich AK, Porter K, Leventhal H, Kelly KM. Exploring perceptions of genetic testing: An examination of perceived accuracy over time. Patient Educ. Couns. 2010;78(1):34-39. Exclusion code: 3. [pmid: 19553058].
Sheehan J, Sherman KA, Lam T, Boyages J. Association of information satisfaction, psychological distress and monitoring coping style with post-decision regret following breast reconstruction. Psychooncology. 2007;16(4):342-351. Exclusion code: 3. [pmid: 16874745].
Sheehan J, Sherman KA, Lam T, Boyages J. Regret associated with the decision for breast reconstruction: The association of negative body image, distress and surgery characteristics with decision regret. Psychol Health. 2008;23(2):207-219. Exclusion code: 3.
Sherwin S. BRCA testing: ethics lessons for the new genetics. Clin Invest Med. 2004;27(1):19-22. Exclusion code: 5. [pmid: 15061582].
Shibata A, Hayashi Y, Imai T, Funahashi H, Nakao A, Seo H. Somatic gene alteration of AIB1 gene in patients with breast cancer. Endocr. J. 2001;48(2):199-204. Exclusion code: 3. [pmid: 11456268].
Shiloh S, Avdor O, Goodman RM. Satisfaction with genetic counseling: Dimensions and measurement. Am. J. Med. Genet. 1990;37(4):522-529. Exclusion code: 2. [pmid: 2260600].
Shkedi-Rafid S, Gabai-Kapara E, Grinshpun-Cohen J, Levy-Lahad E. BRCA genetic testing of individuals from families with low prevalence of cancer: experiences of carriers and implications for population screening. Genet Med. 2012;14(7):688-694. Exclusion code: 3. [pmid: 22481128].
Sidon L, Ingham S, Clancy T, et al. Uptake of risk-reducing salpingo-oophorectomy in women carrying a BRCA1 or BRCA2 mutation: evidence for lower uptake in women affected by breast cancer and older women. Br. J. Cancer. 2012;106(4):775-779. Exclusion code: 8. [pmid: 22187038].
Sim LSJ, Hendriks JHCL, Fook-Chong SMC. Breast ultrasound in women with familial risk of breast cancer. Ann. Acad. Med. Singapore. 2004;33(5):600-606. Exclusion code: 3. [pmid: 15531956].
Simard J, Dumont M, Moisan AM, et al. Evaluation of BRCA1 and BRCA2 mutation prevalence, risk prediction models and a multistep testing approach in French-Canadian families with high risk of breast and ovarian cancer. J. Med. Genet. 2007;44(2):107-121. Exclusion code: 8. [pmid: 16905680].
Simon MS, Petrucelli N. Hereditary breast and ovarian cancer syndrome : the impact of race on uptake of genetic counseling and testing. Methods Mol. Biol. 2009;471:487-500. Exclusion code: 5. [pmid: 19109796].
Sinicrope PS, Brockman TA, Patten CA, et al. Factors associated with breast cancer prevention communication between mothers and daughters. J Womens Health. 2008;17(6):1017-1023. Exclusion code: 8. [pmid: 18554093].
Sirgo A, Rubio B, Torres A, Salvat M, Brunet J. Psychosocial impact of genetic testing in patients diagnosed with breast or colorectal cancer and relatives of high risk: The Genetic Counselling Unit in the University Hospital Saint Joan. Psicooncologia. 2005;2(2-3):369-382. Exclusion code: 7.
Siskind V, Green A, Bain C, Purdie D. Beyond ovulation: Oral contraceptives and epithelial ovarian cancer. Epidemiology. 2000;11(2):106-110. Exclusion code: 6. [pmid: 11021605].
Cancer genetic risk assessment for individuals at risk of familial breast cancer. 2010. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=coch&AN=00075320-100000000-02764. Exclusion code: 5.
Skinner CS, Rawl SM, Moser BK, et al. Impact of the Cancer Risk Intake System on patient-clinician discussions of tamoxifen, genetic counseling, and colonoscopy. J. Gen. Intern. Med. 2005;20(4):360-365. Exclusion code: 4. [pmid: 15857495].
Slattery ML, Baumgartner KB, Giuliano AR, Byers T, Herrick JS, Wolff RK. Replication of five GWAS-identified loci and breast cancer risk among Hispanic and non-Hispanic white women living in the Southwestern United States. Breast Cancer Res. Treat. 2011;129(2):531-539. Exclusion code: 8. [pmid: 21475998].
Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993;270(13):1563-1568. Exclusion code: 2. [pmid: 8371466].
A comparison of gene expression profiling tests for breast cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32010001703. Exclusion code: 5.
Smith AW, Dougall AL, Posluszny DM, Somers TJ, Rubinstein WS, Baum A. Psychological distress and quality of life associated with genetic testing for breast cancer risk. Psychooncology. 2008;17(8):767-773. Exclusion code: 3. [pmid: 17992698].
Smith KR, Ellington L, Chan AY, Croyle RT, Botkin JR. Fertility intentions following testing for a BRCA1 gene mutation. Cancer Epidemiol. Biomarkers Prev. 2004;13(5):733-740. Exclusion code: 3. [pmid: 15159303].
Smith KR, West JA, Croyle RT, Botkin JR. Familial context of genetic testing for cancer susceptibility: Moderating effect of siblings' test results on psychological distress one to two weeks after BRCA1 mutation testing. Cancer Epidemiol. Biomarkers Prev. 1999;8(4 II):385-392. Exclusion code: 3. [pmid: 10207644].
Smith LH, Ol RH. Detection of malignant ovarian neoplasms: A review of the literature. I. Detection of the patient at risk; Clinical, radiological and cytological detection. Obstet. Gynecol. Surv. 1984;39(6):313-328. Exclusion code: 6. [pmid: 6374536].
Snyderman R, Langheier J. Prospective health care: The second transformation of medicine. Genome Biol. 2006;7(2). Exclusion code: 5. [pmid: 16522218].
Soegaard M, Kjaer SK, Cox M, et al. BRCA1 and BRCA2 Mutation Prevalence and Clinical Characteristics of a Population-Based Series of Ovarian Cancer Cases from Denmark. Clin. Cancer Res. 2008;(14):3761-3767. Exclusion code: 3. [pmid: 18559594].
Somers TJ. Risk reducing behaviors in a community sample of women with a family history of breast cancer. Somers, Tamara J. U Pittsburgh. US. 2007. Exclusion code: 4.
Son BH, Ahn SH, Kim S-W, et al. Prevalence of BRCA1 and BRCA2 mutations in non-familial breast cancer patients with high risks in Korea: the Korean Hereditary Breast Cancer (KOHBRA) Study. Breast Cancer Res. Treat. 2012;133(3):1143-1152. Exclusion code: 3. [pmid: 22382806].
Song CG, Hu Z, Wu J, et al. The prevalence of BRCA1 and BRCA2 mutations in eastern Chinese women with breast cancer. J. Cancer Res. Clin. Oncol. 2006;132(10):617-626. Exclusion code: 3. [pmid: 16835750].
Soucek P, Borovanova T, Pohlreich P, Kleibl Z, Novotny J. Role of single nucleotide polymorphisms and haplotypes in BRCA1 in breast cancer: Czech case-control study. Breast Cancer Res. Treat. 2007;103(2):219-224. Exclusion code: 8. [pmid: 17039264].
Spear SL, Carter ME, Schwarz K. Prophylactic mastectomy: indications, options, and reconstructive alternatives. Plast. Reconstr. Surg. 2005;115(3):891-909. Exclusion code: 8. [pmid: 15731693].
Spector DJ. Breast cancer risk, risk perception and lifestyle behaviors among women with a family history of the disease: A mixed-method approach. Spector, Denise Jean. U North Carolina at Chapel Hill. US. 2009. Exclusion code: 8.
Spiegel TN, Hill KA, Warner E. The attitudes of women with BRCA1 and BRCA2 mutations toward clinical breast examinations and breast self-examinations. J Womens Health. 2009;18(7):1019-1024. Exclusion code: 8. [pmid: 20377375].
Spitzer E, Abbaszadegan MR, Schmidt F, et al. Detection of BRCA1 and BRCA2 mutations in breast cancer families by a comprehensive two-stage screening procedure. Int. J. Cancer. 2000;85(4):474-481. Exclusion code: 8. [pmid: 10699917].
Spurdle AB, Marquart L, McGuffog L, et al. Common genetic variation at BARD1 is not associated with breast cancer risk in BRCA1 or BRCA2 mutation carriers. Cancer Epidemiol. Biomarkers Prev. 2011;20(5):1032-1038. Exclusion code: 8. [pmid: 21393566].
Spurna Z, Drazan L, Foretova L, Dvorska L. The effect of prophylactic mastectomy with recontruction on quality of life in BRCA positive women. Klin. 2012;25(Suppl):S74-77. Exclusion code: 7. [pmid: 22920211].
Srivastava A, McKinnon W, Wood ME. Risk of breast and ovarian cancer in women with strong family histories. Oncology (Williston Park). 2001;15(7):889-902. Exclusion code: 2. [pmid: 11499690].
Stadler ZK, Salo-Mullen E, Patil SM, et al. Prevalence of BRCA1 and BRCA2 mutations in Ashkenazi Jewish families with breast and pancreatic cancer. Cancer. 2012;118(2):493-499. Exclusion code: 3. [pmid: 21598239].
Stanton AL, Kirk SB, Cameron CL, Danoff-Burg S. Coping through emotional approach: Scale construction and validation. J. Pers. Soc. Psychol. 2000;78(6):1150-1169. Exclusion code: 2. [pmid: 10870915].
Staton AD, Kurian AW, Cobb K, Mills MA, Ford JM. Cancer risk reduction and reproductive concerns in female BRCA1/2 mutation carriers. Fam Cancer. 2008;7(2):179-186. Exclusion code: 8. [pmid: 18026853].
Steed L. Further validity and reliability evidence for Beck Hopelessness Scale scores in a nonclinical sample. Educational and Psychological Measurement. 2001;61(2):303-316. Exclusion code: 2.
Steele SL. Psychological distress, executive cognitive function and mammography utilization among a high-risk African-American sample. Steele, Sharon Lee. Howard U. US. 2007. Exclusion code: 4.
Stefanek ME. Bilateral prophylactic mastectomy: issues and concerns. J Natl Cancer Inst Monogr. 1995;(17):37-42. Exclusion code: 5. [pmid: 8573451].
Stein KD, Jacobsen PB, Blanchard CM, Thors C. Further validation of the multidimensional fatigue symptom inventory-short form. J. Pain Symptom Manage. 2004;27(1):14-23. Exclusion code: 2. [pmid: 14711465].
Stirling D, Evans DGR, Pichert G, et al. Screening for familial ovarian cancer: Failure of current protocols to detect ovarian cancer at an early stage according to the International Federation of Gynecology and Obstetrics System. J. Clin. Oncol. 2005;23(24):5589-5596. Exclusion code: 3. [pmid: 16110018].
Stolier AJ, Corsetti RL. Newly diagnosed breast cancer patients choose bilateral mastectomy over breast-conserving surgery when testing positive for a BRCA1/2 mutation. Am. Surg. 2005;71(12):1031-1033. Exclusion code: 3. [pmid: 16447474].
Stoppa-Lyonnet D, Ansquer Y, Dreyfus H, et al. Familial invasive breast cancers: Worse outcome related to BRCA1 mutations. J. Clin. Oncol. 2000;18(24):4053-4059. Exclusion code: 6. [pmid: 11118466].
Stratton JF, Pharoah P, Smith SK, Easton D, Ponder BA. A systematic review and meta-analysis of family history and risk of ovarian cancer. Br. J. Obstet. Gynaecol. 1998;105(5):493-499. Exclusion code: 2. [pmid: 9637117].
Stroup AM, Smith KR. Familial effects of BRCA1 genetic mutation testing: changes in perceived family functioning. Cancer Epidemiol. Biomarkers Prev. 2007;16(1):135-141. Exclusion code: 3. [pmid: 17220342].
Stuckey A, Dizon D, Scalia Wilbur J, et al. Clinical characteristics and choices regarding risk-reducing surgery in BRCA mutation carriers. Gynecol. Obstet. Invest. 2010;69(4):270-273. Exclusion code: 8. [pmid: 20090358].
Stuppia L, Di Fulvio P, Aceto G, et al. BRCA1 and BRCA2 mutations in breast/ovarian cancer patients from central Italy. Hum. Mutat. 2003;22(2):178-179. Exclusion code: 5. [pmid: 12872265].
Sueta A, Ito H, Kawase T, et al. A genetic risk predictor for breast cancer using a combination of low-penetrance polymorphisms in a Japanese population. Breast Cancer Res. Treat. 2012;132(2):711-721. Exclusion code: 3. [pmid: 22160591].
Sullivan M, Karlsson J, Ware Jr JE. The Swedish SF-36 Health Survey - I. Evaluation of data quality, scaling assumptions, reliability and construct validity across general populations in Sweden. Soc. Sci. Med. 1995;41(10):1349-1358. Exclusion code: 2. [pmid: 8560302].
Surbone A. Social and ethical implications of BRCA testing. Ann. Oncol. Suppl 1. 2011;22:i60-66. Exclusion code: 5. [pmid: 21285154].
Sussner KM, Edwards TA, Thompson HS, et al. Ethnic, racial and cultural identity and perceived benefits and barriers related to genetic testing for breast cancer among at-risk women of African descent in New York City. Public Health Genomics. 2011;14(6):356-370. Exclusion code: 3. [pmid: 21540561].
Sussner KM, Jandorf L, Thompson HS, Valdimarsdottir HB. Interest and beliefs about BRCA genetic counseling among at-risk Latinas in New York City. J Genet Couns. 2010;19(3):255-268. Exclusion code: 3. [pmid: 20151317].
Sussner KM, Thompson HS, Jandorf L, et al. The influence of acculturation and breast cancer-specific distress on perceived barriers to genetic testing for breast cancer among women of African descent. Psychooncology. 2009;18(9):945-955. Exclusion code: 3. [pmid: 19090507].
Sussner KM, Thompson HS, Valdimarsdottir HB, Redd WH, Jandorf L. Acculturation and familiarity with, attitudes towards and beliefs about genetic testing for cancer risk within Latinas in East Harlem, New York City. J Genet Couns. 2009;18(1):60-71. Exclusion code: 8. [pmid: 18686019].
Suthers GK, Armstrong J, McCormack J, Trott D. Letting the family know: balancing ethics and effectiveness when notifying relatives about genetic testing for a familial disorder. J. Med. Genet. 2006;43(8):665-670. Exclusion code: 8. [pmid: 16371501].
Sutton M, Elliott RL. Genetic diseases: is there a duty to a patient's family members. J. Med. Assoc. Ga. 2011;100(3):28-29. Exclusion code: 5. [pmid: 22164651].
Presymptomatic diagnosis of hereditary breast cancer - early assessment briefs (ALERT) (Brief record). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32000001833. Exclusion code: 5.
Syamala V, Syamala VS, Sreeja L, et al. Hereditary breast/ovarian cancer: clinicopathological characteristics and survival of BRCA2 positive and negative cases. J. Exp. Ther. Oncol. 2008;7(3):227-236. Exclusion code: 3. [pmid: 19066131].
Tailor A, Bourne TH, Campbell S, Okokon E, Dew T, Collins WP. Results from an ultrasound-based familial ovarian cancer screening clinic: A 10-year observational study. Ultrasound Obstet. Gynecol. 2003;21(4):378-385. Exclusion code: 6. [pmid: 12704748].
Tamimi RM, Rosner B, Colditz GA. Evaluation of a breast cancer risk prediction model expanded to include category of prior benign breast disease lesion. Cancer. 2010;116(21):4944-4953. Exclusion code: 2. [pmid: 20645399].
Teixeira L, Julien C, Guimiot F. Polygenes, risk prediction, and targeted prevention of breast cancer. N. Engl. J. Med. 2008;359(13):1406-1407. Exclusion code: 5. [pmid: 18822456].
Teixeira RJ, Pereira MdG. Impact of parental cancer in offspring's psychological development: Literature review. Psicologia: Reflexao e Critica. 2011;24(3):513-522. Exclusion code: 7.
Genetic counselling in breast cancer and colon cancer (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32008000097. Exclusion code: 5.
Teraoka SN, Bernstein JL, Reiner AS, et al. Single nucleotide polymorphisms associated with risk for contralateral breast cancer in the Women's Environment, Cancer, and Radiation Epidemiology (WECARE) Study. Breast Cancer Res. 2011;13(6):R114. Exclusion code: 3. [pmid: 22087758].
Tercyak KP, Demarco TA, Mars BD, Peshkin BN. Women's satisfaction with genetic counseling for hereditary breast-ovarian cancer: psychological aspects. Am J Med Genet A. 2004;131(1):36-41. Exclusion code: 3. [pmid: 15389697].
Tercyak KP, Johnson SB, Roberts SF, Cruz AC. Psychological response to prenatal genetic counseling and amniocentesis. Patient Educ. Couns. 2001;43(1):73-84. Exclusion code: 3. [pmid: 11311841].
Tercyak KP, Lerman C, Peshkin BN, et al. Effects of coping style and BRCA1 and BRCA2 test results on anxiety among women participating in genetic counseling and testing for breast and ovarian cancer risk. Health Psychol. 2001;20(3):217-222. Exclusion code: 6. [pmid: 11403219].
Tercyak KP, Peshkin BN, DeMarco TA, Brogan BM, Lerman C. Parent-child factors and their effect on communicating BRCA1/2 test results to children. Patient Educ. Couns. 2002;47(2):145-153. Exclusion code: 8. [pmid: 12191538].
Tercyak KP, Peshkin BN, Demarco TA, et al. Information needs of mothers regarding communicating BRCA1/2 cancer genetic test results to their children. Genet Test. 2007;11(3):249-255. Exclusion code: 8. [pmid: 17949286].
Tercyak KP, Peshkin BN, Streisand R, Lerman C. Psychological issues among children of hereditary breast cancer gene (BRCA1/2) testing participants. Psychooncology. 2001;10(4):336-346. Exclusion code: 2. [pmid: 11462232].
Tereschenko IV, Basham VM, Ponder BA, Pharoah PD. BRCA1 and BRCA2 mutations in Russian familial breast cancer. Hum. Mutat. 2002;19(2):184. Exclusion code: 3. [pmid: 11793480].
Teutsch S, Bradley LA, Palomaki GE, et al. Evaluation of Genomic Applications in Practice and Prevention [EGAPP] Working Group for tests of risk assessment/susceptibility. Genet Med. 2009;11(1):3-14. Exclusion code: 2. [pmid: 18813139].
The 104th Congress. Health Insurance Portability and Accountability Act of 1996. Public Law 104-191. 1996. Exclusion code: 5.
The Lancet. Control of direct-to-consumer genetic testing. Lancet. 2008;372(9647):1360. Exclusion code: 5. [pmid: 18940452].
Thirlaway K, Fallowfield L, Cuzick J. The sexual activity questionnaire: A measure of women's sexual functioning. Qual. Life Res. 1996;5(1):81-90. Exclusion code: 2. [pmid: 8901370].
Thomassen M, Hansen TVO, Borg Å, et al. BRCA1 and BRCA2 mutations in Danish families with hereditary breast and/or ovarian cancer. Acta Oncol. 2008;47(4):772-777. Exclusion code: 8. [pmid: 18465347].
Thombs BD, Arthurs E, El-Baalbaki G, Meijer A, Ziegelstein RC, Steele RJ. Risk of bias from inclusion of patients who already have diagnosis of or are undergoing treatment for depression in diagnostic accuracy studies of screening tools for depression: systematic review. BMJ (Clinical research ed.). 2011;343. Exclusion code: 3. [pmid: 21852353].
Thompson D, Easton DF, The Breast Cancer Linkage Consortium. Cancer Incidence in BRCA1 Mutation Carriers. J. Natl. Cancer Inst. 2002;94(18):1358-1365. Exclusion code: 2. [pmid: 12237281].
Thomsen A, Kolesar JM. Chemoprevention of breast cancer. Am. J. Health. Syst. Pharm. 2008;65(23):2221-2228. Exclusion code: 5. [pmid: 19020189].
Thorlacius S, Olafsdottir G, Tryggvadottir L, et al. A single BRCA2 mutation in male and female breast cancer families from Iceland with varied cancer phenotypes. Nat. Genet. 1996;13(1):117-119. Exclusion code: 2. [pmid: 8673089].
Tice JA, Cummings SR, Smith-Bindman R, Ichikawa L, Barlow WE, Kerlikowske K. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann. Intern. Med. 2008;148(5):337-347. Exclusion code: 2 (included later). [pmid: 18316752].
Tice JA, Cummings SR, Ziv E, Kerlikowske K. Mammographic breast density and the Gail model for breast cancer risk prediction in a screening population. Breast Cancer Res. Treat. 2005;94(2):115-122. Exclusion code: 2. [pmid: 16261410].
Tice JA, Miike R, Adduci K, Petrakis NL, King E, Wrensch MR. Nipple aspirate fluid cytology and the Gail model for breast cancer risk assessment in a screening population. Cancer Epidemiol. Biomarkers Prev. 2005;14(2):324-328. Exclusion code: 4. [pmid: 15734953].
Tilanus-Linthorst MM, Bartels CC, Obdeijn IM, Oudkerk M. Earlier detection of breast cancer by surveillance of women at familiar risk. Eur. J. Cancer. 2000;36:514-519. Exclusion code: 8. [pmid: 10717529].
Tilanus-Linthorst MM, Obdeijn IM, Bartels KCM. MARIBS study. Lancet. 2005;366(9482):291-292. Exclusion code: 8. [pmid: 16039329].
Tilanus-Linthorst MMA, Kriege M, Boetes C, et al. Hereditary breast cancer growth rates and its impact on screening policy. Eur. J. Cancer. 2005;41(11):1610-1617. Exclusion code: 3. [pmid: 15978801].
Tilburt JC, James KM, Sinicrope PS, et al. Factors influencing cancer risk perception in high risk populations: A systematic review. Hered Cancer Clin Pract. 2011;9(1). Exclusion code: 3. [pmid: 21595959].
Tiller K, Meiser B, Butow P, et al. Psychological impact of prophylactic oophorectomy in women at increased risk of developing ovarian cancer: a prospective study. Gynecol. Oncol. 2002;86(2):212-219. Exclusion code: 5. [pmid: 12144830].
Tinley ST, Houfek J, Watson P, et al. Screening Adherence in BRCA1/2 Families Is Associated with Primary Physicians' Behavior. Am. J. Med. Genet. 2004;125 A(1):5-11. Exclusion code: 8. [pmid: 14755459].
Tobacman JK, Tucker MA, Kase RG, MH, Costa J, Fraumeni JF JR. Intra-abdominal carcinomatosis after prophylactic oophorectomy in ovarian-cancer-prone families. Lancet. 1982;2(8302):795-797. Exclusion code: 2. [pmid: 6126666].
Tone A, Begley H, Sharma M, et al. ene expression profiles of luteal phase fallopian tube epithelium from BRCA mutation carriers resemble high-grade serous carcinoma. Clin. Cancer Res. 2008;14(13):4067-4078. Exclusion code: 2. [pmid: 18593983].
Tonin P, Maugard C, Perret C. A review of histopathological subtypes of ovarian cancer in BRCA-related French Canadian cancer families. Fam Cancer. 2007;6(4):491-497. Exclusion code: 2. [pmid: 17636423].
Torrance N, Mollison J, Wordsworth S, et al. Genetic nurse counsellors can be an acceptable and cost-effective alternative to clinical geneticists for breast cancer risk genetic counselling. Evidence from two parallel randomised controlled equivalence trials. Br. J. Cancer. 2006;95(4):435-444. Exclusion code: 3. [pmid: 16832415].
Touboul C, Uzan C, Ichante JL, et al. Factors Associated with Altered Long-Term Well-Being After Prophylactic Salpingo-Oophorectomy Among Women at Increased Hereditary Risk for Breast and Ovarian Cancer. Oncologist. 2011;16:1250-1257. Exclusion code: 3. [pmid: 21765195].
Trainer AH, Thompson E, James PA. BRCA and beyond: a genome-first approach to familial breast cancer risk assessment. Discov Med. 2011;12(66):433-443. Exclusion code: 8. [pmid: 22127114].
Contribution of BRCA1/2 mutation testing to risk assessment for susceptibility to breast and ovarian cancer. Summary report (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32006000246. Exclusion code: 5.
Trecate G, Vergnaghi D, Manoukian S, et al. MRI in the early detection of breast cancer in women with high genetic risk. Tumori. 2006;92(6):517-523. Exclusion code: 3. [pmid: 17260493].
Trepanier A, Ahrens M, McKinnon W, et al. Genetic cancer risk assessment and counseling: Recommendations of the national society of genetic counselors. J Genet Couns. 2004;13(2):83-114. Exclusion code: 5. [pmid: 15604628].
Trivers KF, Baldwin LM, Miller JW, et al. Reported referral for genetic counseling or BRCA 1/2 testing among United States physicians. Cancer. 2011;117(23):5334-5343. Exclusion code: 2. [pmid: 21792861].
Tyrer J, Duffy SW, Cuzick J. A breast cancer prediction model incorporating familial and personal risk factors. Stat. Med. 2004;23(7):1111-1130. Exclusion code: 6. [pmid: 15057881].
U.S. Preventive Services Task Force. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Recommendation Statement. Ann. Intern. Med. 2005;143(5):355-361. Exclusion code: 2. [pmid: 16144894].
U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2007 Incidence and Mortality Web-based Report. 2010. http://apps.nccd.cdc.gov/uscs/toptencancers.aspx. 10 October 2012. Exclusion code: 2.
U.S. Preventive Services Task Force. Chemoprevention of Breast Cancer: Recommendations and Rationale. Ann. Intern. Med. 2002;137(1):56-58. Exclusion code: 2. [pmid: 12093249].
U.S. Preventive Services Task Force. Screening for Ovarian Cancer Recommendation Statement. 2004. http://www.uspreventiveservicestaskforce.org/3rduspstf/ovariancan/ovcanrs.htm. 25 Oct, 2011. Exclusion code: 2.
Ugalde A, Martin P, Rees G. Psychological impact of receiving genetic risk information for breast cancer, with and without lifestyle information. Australian Journal of Psychology. 2008;60(1):1-9. Exclusion code: 3.
Ulusoy C, Kepenekci I, Kose K, Aydintug S, Cam R. Applicability of the Gail model for breast cancer risk assessment in Turkish female population and evaluation of breastfeeding as a risk factor. Breast Cancer Res. Treat. 2010;120(2):419-424. Exclusion code: 2. [pmid: 19760030].
Underhill ML, Dickerson SS. Engaging in medical vigilance: understanding the personal meaning of breast surveillance. Oncol. Nurs. Forum. 2011;38(6):686-694. Exclusion code: 5. [pmid: 22037331].
Unger MA, Nathanson KL, Calzone KA, et al. Screening for genomic rearrangements in families with breast and ovarian cancer identifies BRCA1 mutations previously missed by conformation-sensitive gel electrophoresis or sequencing. Am J Hum Genet. 2000;67(4):841-850. Exclusion code: 2. [pmid: 10978226].
Ustun C, Ceber E. Ethical issues for cancer screenings. Five countries--four types of cancer. Prev. Med. 2004;39(2):223-229. Exclusion code: 5. [pmid: 15226029].
Vacek PM, Skelly JM, Geller BM. Breast cancer risk assessment in women aged 70 and older. Breast Cancer Res. Treat. 2011;130(1):291-299. Exclusion code: 2. [pmid: 21604157].
Vadaparampil S, Quinn G, Dutil J, et al. A pilot study of knowledge and interest of genetic counseling and testing for hereditary breast and ovarian cancer syndrome among Puerto Rican women. J Community Genet. 2011;2(4):211-221. Exclusion code: 4. [pmid: 22109874].
Vadaparampil ST, Malo T, De La Cruz C, Christie J. Do breast cancer patients tested in the oncology care setting share BRCA mutation results with family members and health care providers?. J Cancer Epidemiol. 2012. Exclusion code: 3. [pmid: 2848222].
Vadaparampil ST, Miree CA, Wilson C, Jacobsen PB. Psychosocial and behavioral impact of genetic counseling and testing. Breast Dis. 2006;27:97-108. Exclusion code: 5. [pmid: 17917142].
Vadaparampil ST, Quinn GP, Miree CA, Brzosowicz J, Carter B, Laronga C. Recall of and reactions to a surgeon referral letter for BRCA genetic counseling among high-risk breast cancer patients. Ann. Surg. Oncol. 2009;16(7):1973-1981. Exclusion code: 8. [pmid: 19408048].
Vadaparampil ST, Ropka M, Stefanek ME. Measurement of psychological factors associated with genetic testing for hereditary breast, ovarian and colon cancers. Fam Cancer. 2005;4(2):195-206. Exclusion code: 6. [pmid: 15951974].
Vadaparampil ST, Wey JP, Kinney AY. Psychosocial aspects of genetic counseling and testing. Semin. Oncol. Nurs. 2004;20(3):186-195. Exclusion code: 5. [pmid: 15491028].
Vaidyanathan K, Lakhotia S, Ravishankar HM, Tabassum U, Mukherjee G, Somasundaram K. BRCA1 and BRCA2 germline mutation analysis among Indian women from south India: identification of four novel mutations and high-frequency occurrence of 185delAG mutation. J Biosci. 2009;34(3):415-422. Exclusion code: 8. [pmid: 19805903].
van der Groep P, van der Wall E, van Diest PJ. Pathology of hereditary breast cancer. Cellular oncology (Dordrecht). 2011;34(2):71-88. Exclusion code: 2. [pmid: 21336636].
Van Der Hout AH, Van Den Ouweland AMW, Van Der Luijt RB, et al. A DGGE system for comprehensive mutation screening of BRCA1 and BRCA2: Application in a Dutch cancer clinic setting. Hum. Mutat. 2006;27(7):654-666. Exclusion code: 8. [pmid: 16683254].
van Der Looij M, Wysocka B, Brozek I, Jassem J, Limon J, Olah E. Founder BRCA1 mutations and two novel germline BRCA2 mutations in breast and/or ovarian cancer families from North-Eastern Poland. Hum. Mutat. 2000;15(5):480-481. Exclusion code: 8. [pmid: 10790213].
van der Velde NM, Mourits MJE, Arts HJG, et al. Time to stop ovarian cancer screening in BRCA1/2 mutation carriers. Int. J. Cancer. 2009;124(4):919-923. Exclusion code: 3. [pmid: 19035463].
van Dijk S, Otten W, Tollenaar RAEM, van Asperen CJ, Tibben A. Putting it all behind: long-term psychological impact of an inconclusive DNA test result for breast cancer. Genet Med. 2008;10(10):745-750. Exclusion code: 3. [pmid: 18813137].
van Dijk S, Otten W, van Asperen CJ, et al. Feeling at risk: how women interpret their familial breast cancer risk. Am J Med Genet A. 2004;131(1):42-49. Exclusion code: 3. [pmid: 15382029].
van Dijk S, van Asperen CJ, Jacobi CE, et al. Variants of uncertain clinical significance as a result of BRCA1/2 testing: impact of an ambiguous breast cancer risk message. Genet Test. 2004;8(3):235-239. Exclusion code: 6. [pmid: 15727245].
van Dijk S, van Roosmalen MS, Otten W, Stalmeier PFM. Decision making regarding prophylactic mastectomy: stability of preferences and the impact of anticipated feelings of regret. J. Clin. Oncol. 2008;26(14):2358-2363. Exclusion code: 8. [pmid: 18467728].
van Dooren S, Rijnsburger AJ, Seynaeve C, et al. Psychological distress in women at increased risk for breast cancer: the role of risk perception. Eur. J. Cancer. 2004;40(14):2056-2063. Exclusion code: 6. [pmid: 15341979].
Van Nagell JR Jr, DePriest PD, Puls LE, et al. Ovarian cancer screening in asymptomatic postmenopausal women by transvaginal sonography. Cancer. 1991;68(3):458-462. Exclusion code: 6. [pmid: 2065264].
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, et al. A prospective study of the impact of genetic susceptibility testing for BRCA1/2 or HNPCC on family relationships. Psychooncology. 2007;16(4):320-328. Exclusion code: 3. [pmid: 16909428].
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, et al. Experience of parental cancer in childhood is a risk factor for psychological distress during genetic cancer susceptibility testing. Ann. Oncol. 2006;17(7):1090-1095. Exclusion code: 8. [pmid: 16600981].
van Oostrom I, Meijers-Heijboer H, Duivenvoorden HJ, et al. Family system characteristics and psychological adjustment to cancer susceptibility genetic testing: a prospective study. Clin. Genet. 2007;71(1):35-42. Exclusion code: 3. [pmid: 17204044].
Van Riper M. Genetic testing and the family. J Midwifery Womens Health. 2005;50(3):227-233. Exclusion code: 5. [pmid: 15895001].
Van Roosmalen MS, Stalmeier PFM, Verhoef LCG, et al. Impact of BRCA1/2 Testing and Disclosure of a Positive Test Result on Women Affected and Unaffected with Breast or Ovarian Cancer. Am. J. Med. Genet. 2004;124 A(4):346-355. Exclusion code: 6. [pmid: 14735581].
Vanchieri C. Risk reduction works for BRCA mutation carriers--with heavy costs. J. Natl. Cancer Inst. 2005;97(14):1032-1033. Exclusion code: 5. [pmid: 16030299].
Vargas AC, Silva LD, Lakhani SR. The contribution of breast cancer pathology to statistical models to predict mutation risk in BRCA carriers. Fam Cancer. 2010;9(4):545-553. Exclusion code: 5. [pmid: 20577821].
Vasen HFA, Tesfay E, Boonstra H, et al. Early detection of breast and ovarian cancer in families with BRCA mutations. Eur. J. Cancer. 2005;41(4):549-554. Exclusion code: 3. [pmid: 15737559].
Venne VL, Hamann HA. Successful use of peer educators for sharing genetic information. J Genet Couns. 2007;16(4):515-525. Exclusion code: 3. [pmid: 17597387].
Veronesi U, Costa A. Prevention of breast cancer with tamoxifen: The Italian study in hysterectomized women. Breast. 1995;4(4):267-272. Exclusion code: 5.
Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Lancet. 1998;352(9122):93-97. Exclusion code: 2. [pmid: 9672273].
Veronesi U, Maisonneuve P, Rotmensz N, et al. Italian randomized trial among women with hysterectomy: tamoxifen and hormone-dependent breast cancer in high-risk women. J. Natl. Cancer Inst. 2003;95(2):160-165. Exclusion code: 5. [pmid: 12529349].
Veschi S, Aceto G, Scioletti AP, et al. High prevalence of BRCA1 deletions in BRCAPRO-positive patients with high carrier probability. Ann. Oncol. 2007;18(Suppl 6):vi86-92. Exclusion code: 8. [pmid: 17591842].
Visser A, Prins JB, Hoogerbrugge N, van Laarhoven HWM. Group medical visits in the follow-up of women with a BRCA mutation: design of a randomized controlled trial. BMC Womens Health. 2011;11:39. Exclusion code: 5. [pmid: 21864353].
Vogel KJ, Atchley DP, Erlichman J, et al. BRCA1 and BRCA2 genetic testing in Hispanic patients: mutation prevalence and evaluation of the BRCAPRO risk assessment model. J. Clin. Oncol. 2007;25(29):4635-4641. Exclusion code: 2. [pmid: 17925560].
Vogel VG, Costantino JP, Wickerham DL, et al. Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: The NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. JAMA. 2006;295(23):2727-2741. Exclusion code: 2. [pmid: 16754727].
Vogl FD, Badzioch MD, Steele L, Neuhausen SL, Goldgar DE. Risks of cancer due to a single BRCA1 mutation in an extended Utah kindred. Fam Cancer. 2007;6(1):63-71. Exclusion code: 8. [pmid: 17051349].
Von Minckwitz G, Loibl S, Jackisch C, et al. The GISS trial: A phase II prevention trial of screening plus goserelin, ibandronate, versus screening alone in premenopausal women at increased risk of breast cancer. Cancer Epidemiol. Biomarkers Prev. 2011;20(10):2141-2149. Exclusion code: 4. [pmid: 21795500].
Vos J, Gomez-Garcia E, Oosterwijk JC, et al. Opening the psychological black box in genetic counseling. The psychological impact of DNA testing is predicted by the counselees' perception, the medical impact by the pathogenic or uninformative BRCA 1/2-result. Psychooncology. 2012;21(1):29-42. Exclusion code: 3. [pmid: 21072753].
Vos J, Oosterwijk JC, Gomez-Garcia E, et al. Exploring the short-term impact of DNA-testing in breast cancer patients: The counselees' perception matters, but the actual BRCA1/2 result does not. Patient Educ. Couns. 2012;86(2):239-251. Exclusion code: 3. [pmid: 21684708].
Vos J, Otten W, van Asperen C, Jansen A, Menko F, Tibben A. The counsellees' view of an unclassified variant in BRCA1/2: recall, interpretation, and impact on life. Psychooncology. 2008;17(8):822-830. Exclusion code: 3. [pmid: 18157792].
Vos J, Stiggelbout AM, Oosterwijk J, et al. A counselee-oriented perspective on risk communication in genetic counseling: explaining the inaccuracy of the counselees' risk perception shortly after BRCA1/2 test result disclosure. Genet Med. 2011;13(9):800-811. Exclusion code: 3. [pmid: 21885922].
Wacholder S, Struewing JP, Hartge P, Greene MH, Tucker MA. Breast cancer risks for BRCA1/2 carriers. Science. 2004;306(5705):2187-2191. author reply 2187-2191. Exclusion code: 2. [pmid: 15622558].
Wagner Costalas J, Itzen M, Malick J, et al. Communication of BRCA1 and BRCA2 results to at-risk relatives: a cancer risk assessment program's experience. Am J Med Genet C Semin Med Genet. 2003;119C(1):11-18. Exclusion code: 2. [pmid: 12704633].
Wainberg S, Husted J. Utilization of screening and preventive surgery among unaffected carriers of a BRCA1 or BRCA2 gene mutation. Cancer Epidemiol. Biomarkers Prev. 2004;13(12):1989-1995. Exclusion code: 8. [pmid: 15598752].
Walker MJ, Chiarelli AM, Mirea L, et al. Validity of self-reported mammography use among women with familial history of breast cancer. [abstract]. Am. J. Epidemiol. 2011;173(11 Suppl). Exclusion code: 8.
Walsh T, Casadei S, Coats KH, et al. Spectrum of Mutations in BRCA1, BRCA2, CHEK2, and TP53 in Families at High Risk of Breast Cancer. JAMA. 2006;295(12):1379-1388. Exclusion code: 8. [pmid: 16551709].
Wang C, Gonzalez R, Janz NK, Milliron KJ, Merajver SD. The role of cognitive appraisal and worry in BRCA1/2 testing decisions among a clinic population. Psychol Health. 2007;22(6):719-736. Exclusion code: 3.
Wang C, Gonzalez R, Milliron KJ, Strecher VJ, Merajver SD. Genetic counseling for BRCA1/2: a randomized controlled trial of two strategies to facilitate the education and counseling process. Am J Med Genet A. 2005;134A(1):66-73. Exclusion code: 3. [pmid: 15690408].
Wang F, Fang Q, Ge Z, Yu N, Xu S, Fan X. Common BRCA1 and BRCA2 mutations in breast cancer families: a meta-analysis from systematic review. Mol. Biol. Rep. 2012;39(3):2109-2118. Exclusion code: 5. [pmid: 21643751].
Wapnir IL, Rabinowitz B, Greco RS. A reappraisal of prophylactic mastectomy. Surg. Gynecol. Obstet. 1990;171(2):171-184. Exclusion code: 2. [pmid: 2200150].
Warner E. Intensive radiologic surveillance: a focus on the psychological issues. Ann. Oncol. 2004;15(Suppl 1):I43-I47. Exclusion code: 5. [pmid: 15280187].
Warner E. The role of magnetic resonance imaging in screening women at high risk of breast cancer. Top. Magn. Reson. Imaging. 2008;19(3):163-169. Exclusion code: 5. [pmid: 18941396].
Warner E, Foulkes W, Goodwin P, et al. Prevalence and penetrance of BRCA1 and BRCA2 gene mutations in unselected Ashkenazi Jewish women with breast cancer. J. Natl. Cancer Inst. 1999;91(14):1241-1247. Exclusion code: 2. [pmid: 10413426].
Warner E, Hill K, Causer P, et al. Prospective study of breast cancer incidence in women with a BRCA1 or BRCA2 mutation under surveillance with and without magnetic resonance imaging. J. Clin. Oncol. 2011;29(13):1664-1669. Exclusion code: 3. [pmid: 21444874].
Warner E, Messersmith H, Causer P, Eisen A, Shumak R, Plewes D. Systematic review: using magnetic resonance imaging to screen women at high risk for breast cancer. Ann. Intern. Med. 2008;148(9):671-679. Exclusion code: 3. [pmid: 18458280].
Warner E, Plewes DB, Hill KA, et al. Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA. 2004;292(11):1317-1325. Exclusion code: 3. [pmid: 15367553].
Warren RML, Thompson D, Pointon LJ, et al. Evaluation of a prospective scoring system designed for a multicenter breast MR imaging screening study. Radiology. 2006;239(3):677-685. Exclusion code: 8. [pmid: 16714457].
Waters E, McNeel T, Stevens W, Freedman A. Use of tamoxifen and raloxifene for breast cancer chemoprevention in 2010. Breast Cancer Res. Treat. 2012;134:875-880. Exclusion code: 2. [pmid: 22622807].
Watson M, Foster C, Eeles R, et al. Psychosocial impact of breast/ovarian (BRCA1/2) cancer-predictive genetic testing in a UK multi-centre clinical cohort. Br. J. Cancer. 2004;91(10):1787-1794. Exclusion code: 6. [pmid: 15505627].
Watson M, Kash KM, Homewood J, Ebbs S, Murday V, Eeles R. Does genetic counseling have any impact on management of breast cancer risk. Genet Test. 2005;9(2):167-174. Exclusion code: 8. [pmid: 15943558].
Weber BL. Familial breast cancer. Recent Results Cancer Res. 1996;140:5-16. Exclusion code: 5. [pmid: 8787076].
Weitzel J, Lagos V, Blazer K, et al. Evidence for common ancestral origin of a recurring BRCA1 genomic rearrangement identified in high-risk Hispanic families. Cancer Epidemiol. Biomarkers Prev. 2007;16(8):1615-1620. Exclusion code: 2. [pmid: 17646271].
Weitzel JN, Blazer KR, MacDonald DJ, Culver JO, Offit K. Genetics, genomics, and cancer risk assessment. CA. Cancer J. Clin. 2011;61(5):327-359. Exclusion code: 2. [pmid: 21858794].
Weitzel JN, Robson M, Pasini B, et al. A comparison of bilateral breast cancers in BRCA carriers. Cancer Epidemiol. Biomarkers Prev. 2005;14(6):1534-1538. Exclusion code: 2. [pmid: 15941968].
Wellisch DK, Cohen MM. The special case of complicated grief in women at high risk for breast cancer. Palliat Support Care. 2010;8(1):7-15. Exclusion code: 3. [pmid: 20163755].
Wellisch DK, Gritz ER, Schain W, Wang HJ, Siau J. Psychological functioning of daughters of breast cancer patients - Part II: Characterizing the distressed daughter of the breast cancer patient. Psychosomatics. 1992;33(2):171-179. Exclusion code: 3. [pmid: 1557482].
Werner-Lin A. Beating the biological clock: the compressed family life cycle of young women with BRCA gene alterations. Soc. Work Health Care. 2008;47(4):416-437. Exclusion code: 5. [pmid: 19042494].
Werner-Lin A. Formal and informal support needs of young women with BRCA mutations. J Psychosoc Oncol. 2008;26(4):111-133. Exclusion code: 8. [pmid: 19042275].
Werner-Lin A. Building the cancer family: Family planning in the context of inherited breast and ovarian cancer risk. Journal of the Society for Social Work and Research. 2010;1(1):14-27. Exclusion code: 2.
Werner-Lin A, Rubin LR, Doyle M, et al. “My funky genetics”: BRCA1/2 mutation carriers' understanding of genetic inheritance and reproductive merger in the context of new reprogenetic technologies. Fam Syst Health. 2012;30(2):166-180. Exclusion code: 8. [pmid: 22709328].
Werner-Lin AV. Danger zones: Risk perceptions of young women from families with hereditary breast and ovarian cancer. Fam. Process. 2007;46(3):335-349. Exclusion code: 8. [pmid: 17899857].
West CN, Barton MB, Liu AI, Geiger AM. Bilateral prophylactic mastectomy: Complications and subsequent procedures. Journal of Clinical Oncology : ASCO annual meeting proceedings. 2004;22:6041. Exclusion code: 5.
Wevers MR, Ausems MGEM, Verhoef S, et al. Behavioral and psychosocial effects of rapid genetic counseling and testing in newly diagnosed breast cancer patients: design of a multicenter randomized clinical trial. BMC Cancer. 2011;11:6. Exclusion code: 3. [pmid: 21219598].
Wewers ME, Lowe NK. A critical review of visual analogue scales in the measurement of clinical phenomena. Res. Nurs. Health. 1990;13(4):227-236. Exclusion code: 2. [pmid: 2197679].
White DB, Bonham VL, Jenkins J, Stevens N, McBride CM. Too many referrals of low-risk women for BRCA1/2 genetic services by family physicians. Cancer Epidemiol. Biomarkers Prev. 2008;17(11):2980-2986. Exclusion code: 8. [pmid: 18990739].
Whittemore AS, Balise RR, Pharoah PDP, et al. Oral contraceptive use and ovarian cancer risk among carriers of BRCA1 or BRCA2 mutations. Br. J. Cancer. 2004;91(11):1911-1915. Exclusion code: 3. [pmid: 15545966].
Whittemore AS, Gong G, Itnyre J. Prevalence and contribution of BRCA1 mutations in breast cancer and ovarian cancer: Results from three U.S. population-based case-control studies of ovarian cancer. Am. J. Hum. Genet. 1997;60(3):496-504. Exclusion code: 3. [pmid: 9042908].
Whittemore AS, Gong G, John EM, et al. Prevalence of BRCA1 mutation carriers among U.S. non-Hispanic Whites. Cancer Epidemiol. Biomarkers Prev. 2004;13(12):2078-2083. Exclusion code: 2. [pmid: 15598764].
Wickerham DL, Costantino JP, Vogel V, et al. The study of tamoxifen and raloxifene (STAR): Initial findings from the NSABP P-2 breast cancer prevention study. Journal of Clinical Oncology: ASCO annual meeting proceedings. 2006;24. Exclusion code: 5.
Wickerham DL, Costantino JP, Vogel VG, et al. The use of tamoxifen and raloxifene for the prevention of breast cancer. Recent Results Cancer Res. 2009;181:113-119. Exclusion code: 5. [pmid: 19213563].
Wilkening S, Burwinkel B, Grzybowska E, et al. Polyglutamine repeat length in the NCOA3 does not affect risk in familial breast cancer. Cancer Epidemiol. Biomarkers Prev. 2005;14(1):291-292. Exclusion code: 8. [pmid: 15668512].
Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions (Structured abstract). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=clhta&AN=HTA-32005000090. Exclusion code: 5.
Wilson BJ, Torrance N, Mollison J, et al. Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions. Health Technol. Assess. 2005;9(3):iii-iv. 1. 126. Exclusion code: 3. [pmid: 15694064].
Wilson DB, Quillin J, Bodurtha JN, McClish D. Comparing screening and preventive health behaviors in two study populations: Daughters of mothers with breast cancer and women responding to the Behavioral Risk Factor Surveillance System Survey. J Womens Health. 2011;20(8):1201-1206. Exclusion code: 8. [pmid: 21671767].
Wong N. Investigating the effects of cancer risk and efficacy perceptions on cancer prevention adherence and intentions. Health Commun. 2009;24(2):95-105. Exclusion code: 4. [pmid: 19280453].
Wood ME, Stockdale A, Flynn BS. Interviews with primary care physicians regarding taking and interpreting the cancer family history. Fam. Pract. 2008;25(5):334-340. Exclusion code: 3. [pmid: 18765407].
Woods JE. Breast reconstruction: current state of the art. Mayo Clin. Proc. 1986;61:579-585. Exclusion code: 2. [pmid: 3713262].
Wooster R, Weber BL. Breast and ovarian cancer. N. Engl. J. Med. 2003;348(23):2339-2347. Exclusion code: 2. [pmid: 12788999].
Yang Q, Khoury MJ, Rodriguez C, Calle EE, Tatham LM, Flanders WD. Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am. J. Epidemiol. 1998;147(7):652-659. Exclusion code: 2. [pmid: 9554604].
Yip C-H, Taib NA, Choo WY, Rampal S, Thong MK, Teo SH. Clinical and pathologic differences between BRCA1-, BRCA2-, and non-BRCA-associated breast cancers in a multiracial developing country. World J. Surg. 2009;33(10):2077-2081. Exclusion code: 3. [pmid: 19649760].
Yoon SY, Thong MK, Taib NAM, Yip CH, Teo SH. Genetic counseling for patients and families with hereditary breast and ovarian cancer in a developing Asian country: an observational descriptive study. Fam Cancer. 2011;10(2):199-205. Exclusion code: 8. [pmid: 21318382].
You M. Determinants of risk perception among women with a family history of breast cancer. You, Myoungsoon. U California, Berkeley. US. 2009. Exclusion code: 8.
Young D, McLeish L, Sullivan F, et al. Familial breast cancer: Management of ‘lower risk’ referrals. Br. J. Cancer. 2006;95(8):974-978. Exclusion code: 8. [pmid: 17047645].
Zakaria S, Degnim AC. Prophylactic mastectomy. Surg. Clin. North Am. 2007;87(2):317-331. viii. Exclusion code: 5. [pmid: 17498529].
Zapka J, Fisher G, Lemon S, Clemow L, Fletcher K. Relationship and distress in relatives of breast cancer patients. Fam Syst Health. 2006;24(2):198-212. Exclusion code: 4.
Zelada-Hedman M, Arver BW, Claro A, et al. A screening for BRCA1 mutations in breast and breast-ovarian cancer families from the Stockholm region. Cancer Res. 1997;57(12):2474-2477. Exclusion code: 6. [pmid: 9192828].
Zhang Y, Huang M, Zhu Z. AIB1 polymorphisms with breast cancer susceptibility: a pooled analysis of variation in BRCA1/2 mutation carriers and non-carriers. Mol. Biol. Rep. 2012;39(6):6881-6886. Exclusion code: 5. [pmid: 22307791].
Zigmond AS, Snaith RP. The hospital anxiety and depression scale. Acta Psychiatr. Scand. 1983;67(6):361-370. Exclusion code: 6. [pmid: 6880820].
Zilberg NJ, Weiss DS, Horowitz MJ. Impact of Event Scale: A cross-validation study and some empirical evidence supporting a conceptual model of stress response syndromes. J. Consult. Clin. Psychol. 1982;50(3):407-414. Exclusion code: 2. [pmid: 7096742].
Zilliacus EM, Meiser B, Lobb EA, et al. Are videoconferenced consultations as effective as face-to-face consultations for hereditary breast and ovarian cancer genetic counseling. Genet Med. 2011;13(11):933-941. Exclusion code: 3. [pmid: 21799430].
Ziv E. Genetics of breast cancer: applications to the Mexican population. Salud Publica Mex. 2011;53(5):415-419. Exclusion code: 5. [pmid: 22218795].
Zorn KK, Gardner G, Birrer MJ. Epithelial ovarian cancer. Cancer Chemoprevention: Strategies for Cancer Chemoprevention. 1 ed. 2005;2. Exclusion code: 5.
Zweemer R, van Diest P, Verheijen R, et al. Molecular evidence linking primary cancer of the fallopian tube to BRCA1 germline mutations. Gynecol. Oncol. 2000;76(1):45-50. Exclusion code: 2. [pmid: 10620440].