# References

1 Hiatt WR, Goldstone J, Smith SC Jr, et al. Atherosclerotic Peripheral Vascular Disease Symposium II: nomenclature for vascular diseases. Circulation. 2008;118(25):2826-9. [pmid: 19106403].
2 National Heart Lung and Blood Institute. What Is Peripheral Arterial Disease?. 2011. Accessed at http://www.nhlbi.nih.gov/health/health-topics/topics/pad/ on 19 August 2013.
3 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease): endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; and Vascular Disease Foundation. Circulation. 2006;113(11):e463-e654. [pmid: 16549646].
4 McDermott MM, Greenland P, Liu K, et al. Leg symptoms in peripheral arterial disease: associated clinical characteristics and functional impairment. JAMA. 2001;286(13):1599-606. [pmid: 11585483].
5 A.D.A.M. Medical Encyclopedia. Peripheral Artery Disease—Legs. 2013. PubMed Health. Accessed at http://www.ncbi.nlm.nih.gov/pubmedhealth/PMH0001223/ on 19 August 2013.
6 Rooke TW, Hirsch AT, Misra S, Sidawy AN, Beckman JA, Findeiss LK, et al. 2011 ACCF/AHA focused update of the guideline for the management of patients with peripheral artery disease (updating the 2005 guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2011;58(19):2020-45. [pmid: 21963765].
7 Canadian Cardiovascular Society Consensus Conference on Peripheral Arterial Disease. Ottowa, Canada. Canadian Cardiovascular Society. 2005.
8 Mohler E III, Giri J. Management of peripheral arterial disease patients: comparing the ACC/AHA and TASC-II guidelines. Curr Med Res Opin. 2008;24(9):2509-22. [pmid: 18664318].
9 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Engl J Med. 2001;344(21):1608-21. [pmid: 11372014].
10 Pande RL, Perlstein TS, Beckman JA, et al. Secondary prevention and mortality in peripheral artery disease: National Health and Nutrition Examination Study, 1999 to 2004. Circulation. 2011;124(1):17-23. [pmid: 21690489].
11 Allison MA, Ho E, Denenberg JO, et al. Ethnic-specific prevalence of peripheral arterial disease in the United States. Am J Prev Med. 2007;32(4):328-33. [pmid: 17383564].
12 Menke A, Muntner P, Wildman RP, et al. Relation of borderline peripheral arterial disease to cardiovascular disease risk. Am J Cardiol. 2006;98(9):1226-30. [pmid: 17056334].
13 Ostchega Y, Paulose-Ram R, Dillon CF, et al. Prevalence of peripheral arterial disease and risk factors in persons aged 60 and older: data from the National Health and Nutrition Examination Survey 1999-2004. J Am Geriatr Soc. 2007;55(4):583-9. [pmid: 17397438].
14 Selvin E, Erlinger TP. Prevalence of and risk factors for peripheral arterial disease in the United States: results from the National Health and Nutrition Examination Survey, 1999-2000. Circulation. 2004;110(6):738-43. [pmid: 15262830].
15 Eraso LH, Fukaya E, Mohler ER III, et al. Peripheral arterial disease, prevalence and cumulative risk factor profile analysis. Eur J Prev Cardiol. 2012. Jun. 27.
16 Hirsch AT, Hartman L, Town RJ, et al. National health care costs of peripheral arterial disease in the Medicare population. Vasc Med. 2008;13(3):209-15. [pmid: 18687757].
17 Margolis J, Barron JJ, Grochulski WD. Health care resources and costs for treating peripheral artery disease in a managed care population: results from analysis of administrative claims data. J Manag Care Pharm. 2005;11(9):727-34. [pmid: 16300416].
18 Mahoney EM, Wang K, Keo HH, et al. Vascular hospitalization rates and costs in patients with peripheral artery disease in the United States. Circ Cardiovasc Qual Outcomes. 2010;3(6):642-51. [pmid: 20940249].
19 Bendermacher BL, Teijink JA, Willigendael EM, et al. A clinical prediction model for the presence of peripheral arterial disease—the benefit of screening individuals before initiation of measurement of the ankle-brachial index: an observational study. Vasc Med. 2007;12(1):5-11. [pmid: 17451087].
20 Ramos R, Baena-Diez JM, Quesada M, et al. Derivation and validation of REASON: a risk score identifying candidates to screen for peripheral arterial disease using ankle brachial index. Atherosclerosis. 2011;214(2):474-9. [pmid: 21167488].
21 Mostaza JM, Gonzalez-Juanatey JR, Castillo J, et al. Prevalence of carotid stenosis and silent myocardial ischemia in asymptomatic subjects with a low ankle-brachial index. J Vasc Surg. 2009;49(1):104-8. [pmid: 18829225].
22 Newman AB, Siscovick DS, Manolio TA, et al. Ankle-arm index as a marker of atherosclerosis in the Cardiovascular Health Study. Circulation. 1993;88(3):837-45. [pmid: 8353913].
23 Tsao CW, Gona P, Salton C, et al. Relationship between central and peripheral atherosclerosis and left ventricular dysfunction in a community population. Vasc Med. 2011;16(4):253-9. [pmid: 21708875].
24 Cassar K. Peripheral arterial disease. Clin Evid (Online). 2011;2011.
25 Reed JF III, Eid S, Edris B, et al. Prevalence of peripheral artery disease varies significantly depending upon the method of calculating ankle brachial index. Eur J Cardiovasc Prev Rehabil. 2009;16(3):377-81. [pmid: 19369879].
26 Taylor-Piliae RE, Fair JM, Varady AN, et al. Ankle brachial index screening in asymptomatic older adults. Am Heart J. 2011;161(5):979-85. [pmid: 21570532].
27 Eason SL, Petersen NJ, Suarez-Almazor M, et al. Diabetes mellitus, smoking, and the risk for asymptomatic peripheral arterial disease: whom should we screen?. J Am Board Fam Pract. 2005;18(5):355-61. [pmid: 16148245].
28 Cimminiello C, Kownator S, Wautrecht JC, et al. The PANDORA study: peripheral arterial disease in patients with non-high cardiovascular risk. Intern Emerg Med. 2011;6(6):509-19. [pmid: 21298363].
29 Alzamora MT, Fores R, Baena-Diez JM, et al. The Peripheral Arterial Disease Study (PERART/ARTPER): prevalence and risk factors in the general population. BMC Public Health. 2010;10:38. [pmid: 20529387].
30 Ramos R, Quesada M, Solanas P, et al. Prevalence of symptomatic and asymptomatic peripheral arterial disease and the value of the ankle-brachial index to stratify cardiovascular risk. Eur J Vasc Endovasc Surg. 2009;38(3):305-11. [pmid: 19515589].
31 Hirsch AT, Gotto AM Jr. Undertreatment of dyslipidemia in peripheral arterial disease and other high-risk populations: an opportunity for cardiovascular disease reduction. Vasc Med. 2002;7(4):323-31. [pmid: 12710848].
32 Khan NA, Rahim SA, Anand SS, et al. Does the clinical examination predict lower extremity peripheral arterial disease?. JAMA. 2006;295(5):536-46. [pmid: 16449619].
33 Gornik HL, Garcia B, Wolski K, et al. Validation of a method for determination of the ankle-brachial index in the seated position. J Vasc Surg. 2008;48(5):1204-10. [pmid: 18829231].
34 Hamel JF, Foucaud D, Fanello S. Comparison of the automated oscillometric method with the gold standard Doppler ultrasound method to access the ankle-brachial pressure index. Angiology. 2010;61(5):487-91. [pmid: 20211935].
35 Allison MA, Aboyans V, Granston T, et al. The relevance of different methods of calculating the ankle-brachial index: the Multi-Ethnic Study of Atherosclerosis. Am J Epidemiol. 2010;171(3):368-76. [pmid: 20042436].
36 Lange SF, Trampisch HJ, Pittrow D, et al. Profound influence of different methods for determination of the ankle brachial index on the prevalence estimate of peripheral arterial disease. BMC Public Health. 2007;7:147. [pmid: 18293542].
37 Hirsch AT, Criqui MH, Treat-Jacobson D, et al. Peripheral arterial disease detection, awareness, and treatment in primary care. JAMA. 2001;286(11):1317-24. [pmid: 11560536].
38 O'Hare AM, Katz R, Shlipak MG, et al. Mortality and cardiovascular risk across the ankle-arm index spectrum: results from the Cardiovascular Health Study. Circulation. 2006;113(3):388-93. [pmid: 16432070].
39 Wattanakit K, Folsom AR, Duprez DA, et al. Clinical significance of a high ankle-brachial index: insights from the Atherosclerosis Risk in Communities (ARIC) study. Atherosclerosis. 2007;190(2):459-64. [pmid: 16574125].
40 Allison MA, Hiatt WR, Hirsch AT, et al. A high ankle-brachial index is associated with increased cardiovascular disease morbidity and lower quality of life. J Am Coll Cardiol. 2008;51(13):1292-8. [pmid: 18371562].
41 Signorelli SS, Fiore V, Catanzaro S, et al. Prevalence of high ankle-brachial index (ABI) in general population of Southern Italy, risk factor profiles and systemic cardiovascular co-morbidity: an epidemiological study. Arch Gerontol Geriatr. 2011;53(1):55-9. [pmid: 20591512].
42 Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
43 National Cholesterol Education Program. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III): Executive Summary. Bethesda, MD. National Heart, Lung, and Blood Institute. 2001. Accessed at http://www.nhlbi.nih.gov/guidelines/cholesterol/atp3xsum.pdf on 19 August 2013.
44 Gaziano J, Wilson P. Cardiovascular risk assessment in the 21st century. JAMA. 2012;308(8):816-7. [pmid: 22910761].
45 Lloyd-Jones DM. Cardiovascular risk prediction: basic concepts, current status, and future directions. Circulation. 2010;121(15):1768-77. [pmid: 20404268].
46 Fowkes FG, Murray GD, Butcher I, et al. Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. 2008;300(2):197-208. [pmid: 18612117].
47 Rodondi N, Marques-Vidal P, Butler J, et al. Markers of atherosclerosis and inflammation for prediction of coronary heart disease in older adults. Am J Epidemiol. 2010;171(5):540-9. [pmid: 20110287].
48 Yeboah J, McClelland RL, Polonsky TS, et al. Comparison of novel risk markers for improvement in cardiovascular risk assessment in intermediate-risk individuals. JAMA. 2012;308(8):788-95. [pmid: 22910756].
49 Kavousi M, Elias-Smale S, Rutten JH, et al. Evaluation of newer risk markers for coronary heart disease risk classification: a cohort study. Ann Intern Med. 2012;156(6):438-44. [pmid: 22431676].
50 Lee AJ, Price JF, Russell MJ, et al. Improved prediction of fatal myocardial infarction using the ankle brachial index in addition to conventional risk factors: the Edinburgh Artery Study. Circulation. 2004;110(19):3075-80. [pmid: 15477416].
51 D'Agostino RB Sr, Vasan RS, Pencina MJ, et al. General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743-53. [pmid: 18212285].
52 Hippisley-Cox J, Coupland C, Robson J, et al. Derivation, validation, and evaluation of a new QRISK model to estimate lifetime risk of cardiovascular disease: cohort study using QResearch database. BMJ. 2010;341:c6624. [pmid: 21148212].
53 Collins GS, Altman DG. Predicting the 10 year risk of cardiovascular disease in the United Kingdom: independent and external validation of an updated version of QRISK2. BMJ. 2012;344:e4181. [pmid: 22723603].
54 Ridker PM, Buring JE, Rifai N, et al. Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007;297(6):611-9. [pmid: 17299196].
55 Ridker PM, Paynter NP, Rifai N, et al. C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008;118(22):2243-51. [pmid: 18997194].
56 Rosero EB, Kane K, Clagett GP, et al. A systematic review of the limitations and approaches to improve detection and management of peripheral arterial disease in Hispanics. J Vasc Surg. 2010;51(4 Suppl):27S-35S. [pmid: 19939610].
57 Greenland P, Alpert JS, Beller GA, et al. 2010 ACCF/AHA guideline for assessment of cardiovascular risk in asymptomatic adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2010;56(25):e50-103. [pmid: 21144964].
58 Mohler ER III, Treat-Jacobson D, Reilly MP, et al. Utility and barriers to performance of the ankle-brachial index in primary care practice. Vasc Med. 2004;9(4):253-60. [pmid: 15678616].
59 U.S. Preventive Services Task Force. Screening for Peripheral Arterial Disease: Recommendation Statement. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
60 U.S. Preventive Services Task Force. Screening for peripheral arterial disease: recommendation statement. Am Fam Physician. 2006;73(3):497-500. [pmid: 16477898].
61 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. Washington, DC. U.S. Department of Health and Human Services. 1996.
62 Screening for Peripheral Arterial Disease: A Brief Evidence Update for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Health Research and Quality. 2005.
63 Fowler B, Jamrozik K, Norman P, et al. Improving maximum walking distance in early peripheral arterial disease: randomised controlled trial. Aust J Physiother. 2002;48(4):269-75. [pmid: 12443521].
64 Tornwall M, Virtamo J, Haukka JK, et al. Effect of alpha-tocopherol (vitamin E) and beta-carotene supplementation on the incidence of intermittent claudication in male smokers. Arterioscler Thromb Vasc Biol. 1997;17(12):3475-80. [pmid: 9437195].
65 McDermott MM, Guralnik JM, Greenland P, et al. Statin use and leg functioning in patients with and without lower-extremity peripheral arterial disease. Circulation. 2003;107(5):757-61. [pmid: 12578881].
66 Beckman JA, Jaff MR, Creager MA. The United States Preventive Services Task Force recommendation statement on screening for peripheral arterial disease: more harm than benefit?. Circulation. 2006;114(8):861-6. [pmid: 16923770].
67 U.S. Preventive Services Task Force. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(7):474-82. [pmid: 19805770].
68 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
69 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299(17):926-30. [pmid: 692598].
70 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061-6. [pmid: 10493205].
71 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140(3):189-202. [pmid: 14757617].
72 Rutjes AW, Reitsma JB, Di Nisio M, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469-76. [pmid: 16477057].
73 Leeflang MM, Bossuyt PM, Irwig L. Diagnostic test accuracy may vary with prevalence: implications for evidence-based diagnosis. J Clin Epidemiol. 2009;62(1):5-12. [pmid: 18778913].
74 Pencina MJ, D'Agostino RB Sr, D'Agostino RB Jr, et al. Evaluating the added predictive ability of a new marker: from area under the ROC curve to reclassification and beyond. Stat Med. 2008;27(2):157-72. [pmid: 17569110].
75 Steyerberg EW, Vickers AJ, Cook NR, et al. Assessing the performance of prediction models: a framework for traditional and novel measures. Epidemiology. 2010;21(1):128-38. [pmid: 20010215].
76 Cook NR, Ridker PM. Advances in measuring the effect of individual predictors of cardiovascular risk: the role of reclassification measures. Ann Intern Med. 2009;150(11):795-802. [pmid: 19487714].
77 Cook NR, Paynter NP. Performance of reclassification statistics in comparing risk prediction models. Biom J. 2011;53(2):237-58. [pmid: 21294152].
78 Ioannidis JP, Tzoulaki I. What makes a good predictor? The evidence applied to coronary artery calcium score. JAMA. 2010;303(16):1646-7. [pmid: 20424257].
79 Hlatky MA. Framework for evaluating novel risk markers. Ann Intern Med. 2012;156(6):468-9. [pmid: 22431679].
80 Royston P, Moons KG, Altman DG, et al. Prognosis and prognostic research: developing a prognostic model. BMJ. 2009;338:b604. [pmid: 19336487].
81 Apfel CC, Kranke P, Greim CA, et al. What can be expected from risk scores for predicting postoperative nausea and vomiting?. Br J Anaesth. 2001;86(6):822-7. [pmid: 11573590].
82 U.S. Preventive Services Task Force. U.S Preventive Services Task Force Procedure Manual. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm on 19 August 2013.
83 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2007. Accessed at http://www.nice.org.uk/media/FA1/59/GuidelinesManualChapters2007.pdf on 19 August 2013.
84 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
85 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
86 Wells G, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analyses. Ottawa. Ottawa Hospital Research Institute. 2012.
87 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-37. [pmid: 16549855].
88 Wikstrom J, Hansen T, Johansson L, et al. Ankle brachial index <0.9 underestimates the prevalence of peripheral artery occlusive disease assessed with whole-body magnetic resonance angiography in the elderly. Acta Radiol. 2008;49(2):143-9. [pmid: 18300136].
89 Eldrup N, Sillesen H, Prescott E, et al. Ankle brachial index, C-reactive protein, and central augmentation index to identify individuals with severe atherosclerosis. Eur Heart J. 2006;27(3):316-22. [pmid: 16278227].
90 Simon A, Papoz L, Ponton A, et al. Feasibility and reliability of ankle/arm blood pressure index in preventive medicine. Angiology. 2000;51(6):463-71. [pmid: 10870855].
91 Murphy TP, Dhangana R, Pencina MJ, et al. Ankle-brachial index and cardiovascular risk prediction: an analysis of 11,594 individuals with 10-year followup. Atherosclerosis. 2012;220(1):160-7. [pmid: 22099055].
92 Gaziano JM, Wilson PW. Cardiovascular risk assessment in the 21st century. JAMA. 2012;308(8):816-7. [pmid: 22910761].
93 Sutton-Tyrrell K, Venkitachalam L, Kanaya AM, et al. Relationship of ankle blood pressures to cardiovascular events in older adults. Stroke. 2008;39(3):863-9. [pmid: 18258843].
94 Weatherley BD, Nelson JJ, Heiss G, et al. The association of the ankle-brachial index with incident coronary heart disease: the Atherosclerosis Risk In Communities (ARIC) study, 1987-2001. BMC Cardiovasc Disord. 2007;7:3. [pmid: 17227586].
95 Abbott RD, Petrovitch H, Rodriguez BL, et al. Ankle/brachial blood pressure in men >70 years of age and the risk of coronary heart disease. Am J Cardiol. 2000;86(3):280-4. [pmid: 10922433].
96 Price JF, Tzoulaki I, Lee AJ, et al. Ankle brachial index and intima media thickness predict cardiovascular events similarly and increased prediction when combined. J Clin Epidemiol. 2007;60(10):1067-75. [pmid: 17884603].
97 Hanssen NM, Huijberts MS, Schalkwijk CG, et al. Associations between the ankle-brachial index and cardiovascular and all-cause mortality are similar in individuals without and with type 2 diabetes: nineteen-year followup of a population-based cohort study. Diabetes Care. 2012;35(8):1731-5. [pmid: 22699294].
98 Tsai AW, Folsom AR, Rosamond WD, et al. Ankle-brachial index and 7-year ischemic stroke incidence: the ARIC study. Stroke. 2001;32(8):1721-4. [pmid: 11486096].
99 Abbott RD, Rodriguez BL, Petrovitch H, et al. Ankle-brachial blood pressure in elderly men and the risk of stroke: the Honolulu Heart Program. J Clin Epidemiol. 2001;54(10):973-8. [pmid: 11576807].
100 Fowkes FG, Price JF, Stewart MC, et al. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303:841-8. [pmid: 20197530].
101 McDermott MM, Reed G, Greenland P, et al. Activating peripheral arterial disease patients to reduce cholesterol: a randomized trial. Am J Med. 2011;124(6):557-65. [pmid: 21605733].
102 McDermott MM, Mazor KM, Reed G, et al. Attitudes and behavior of peripheral arterial disease patients toward influencing their physician's prescription of cholesterol-lowering medication. Vasc Med. 2010;15(2):83-90. [pmid: 20118170].
103 Kornitzer M, Dramaix M, Sobolski J, et al. Ankle/arm pressure index in asymptomatic middle-aged males: an independent predictor of ten-year coronary heart disease mortality. Angiology. 1995;46(3):211-9. [pmid: 7879961].
104 Murabito JM, Evans JC, Larson MG, et al. The ankle-brachial index in the elderly and risk of stroke, coronary disease, and death: the Framingham Study. Arch Intern Med. 2003;163(16):1939-42. [pmid: 12963567].
105 Diehm C, Allenberg JR, Pittrow D, et al. Mortality and vascular morbidity in older adults with asymptomatic versus symptomatic peripheral artery disease. Circulation. 2009;120(21):2053-61. [pmid: 19901192].
106 Meves SH, Diehm C, Berger K, et al. Peripheral arterial disease as an independent predictor for excess stroke morbidity and mortality in primary-care patients: 5-year results of the getABI study. Cerebrovasc Dis. 2010;29(6):546-54. [pmid: 20375496].
107 Hooi JD, Kester AD, Stoffers HE, et al. Asymptomatic peripheral arterial occlusive disease predicted cardiovascular morbidity and mortality in a 7-year followup study. J Clin Epidemiol. 2004;57(3):294-300. [pmid: 15066690].
108 Ogren M, Hedblad B, Jungquist G, et al. Low ankle-brachial pressure index in 68-year-old men: prevalence, risk factors and prognosis. Results from prospective population study “Men born in 1914,” Malmo, Sweden. Eur J Vasc Surg. 1993;7(5):500-6. [pmid: 8405492].
109 Merino J, Planas A, De Moner A, et al. The association of peripheral arterial occlusive disease with major coronary events in a mediterranean population with low coronary heart disease incidence. Eur J Vasc Endovasc Surg. 2008;36(1):71-6. [pmid: 18396072].
110 Newman AB, Tyrrell KS, Kuller LH. Mortality over four years in SHEP participants with a low ankle-arm index. J Am Geriatr Soc. 1997;45(12):1472-8. [pmid: 9400557].
111 Helfand M, Buckley D, Fleming C, et al. Screening for Intermediate Risk Factors for Coronary Heart Disease: Systematic Evidence Synthesis. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
112 National Institute for Health and Clinical Excellence. Lower Limb Peripheral Arterial Disease: Diagnosis and Management. London. National Institute for Health and Clinical Excellence. 2012. Accessed at http://www.nice.org.uk/nicemedia/live/13856/60428/60428.pdf on 19 August 2013.
113 Xu D, Li J, Zou L, et al. Sensitivity and specificity of the ankle-brachial index to diagnose peripheral artery disease: a structured review. Vasc Med. 2010;15(5):361-9. [pmid: 20926495].
114 Jones WS, Schmit KM, Vemulapalli S, et al. Treatment Strategies for Patients With Peripheral Artery Disease. Rockville, MD. Agency for Health Research and Quality. 2012.
115 Oksala NK, Viljamaa J, Saimanen E, et al. Modified ankle-brachial index detects more patients at risk in a Finnish primary health care. Eur J Vasc Endovasc Surg. 2010;39(2):227-33. [pmid: 19969474].
116 Aboyans V, Criqui MH, Abraham P, et al. Measurement and interpretation of the ankle-brachial index: a scientific statement from the American Heart Association. Circulation. 2012;126(24):2890-909. [pmid: 23159553].
117 Mehlsen J, Wiinberg N, Bruce C. Oscillometric blood pressure measurement: a simple method in screening for peripheral arterial disease. Clin Physiol Funct Imaging. 2008;28(6):426-9. [pmid: 18803641].
118 Carmo GA, Mandil A, Nascimento BR, et al. Can we measure the ankle-brachial index using only a stethoscope? A pilot study. Fam Pract. 2009;26(1):22-6. [pmid: 19022870].
119 Migliacci R, Nasorri R, Ricciarini P, et al. Ankle-brachial index measured by palpation for the diagnosis of peripheral arterial disease. Fam Pract. 2008;25(4):228-32. [pmid: 18567610].
120 American Medical Association. CPT 2013 Standard Edition. Chicago. American Medical Association. 2013.
121 Bosch J, Yusuf S, Pogue J, et al. Use of ramipril in preventing stroke: double blind randomised trial. BMJ. 2002;324:699-702. [pmid: 11909785].
122 Ostergren J, Sleight P, Dagenais G, et al. Impact of ramipril in patients with evidence of clinical or subclinical peripheral arterial disease. Eur Heart J. 2004;25:17-24. [pmid: 14683738].
123 Collins R, Armitage J, Parish S, et al. Effects of cholesterol-lowering with simvastatin on stroke and other major vascular events in 20,536 people with cerebrovascular disease or other high-risk conditions. Lancet. 2004;363(9411):757-67. [pmid: 15016485].
124 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
125 Cacoub PP, Bhatt DL, Steg PG, et al. Patients with peripheral arterial disease in the CHARISMA trial. Eur Heart J. 2009;30(2):192-201. [pmid: 19136484].
126 CAPRIE Steering Committee. A randomised, blinded trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). Lancet. 1996;348(9038):1329-39. [pmid: 8918275].
127 Koller MT, Leening MJ, Wolbers M, et al. Development and validation of a coronary risk prediction model for older U.S. and European persons in the Cardiovascular Health Study and the Rotterdam Study. Ann Intern Med. 2012;157(6):389-97. [pmid: 22986376].
128 Grondal N, Sogaard R, Henneberg EW, et al. The Viborg Vascular (VIVA) screening trial of 65-74 year old men in the central region of Denmark: study protocol. Trials. 2010;11:67. [pmid: 20507582].
129 Wikstrom J, Hansen T, Johansson L, et al. Lower extremity artery stenosis distribution in an unselected elderly population and its relation to a reduced ankle-brachial index. J Vasc Surg. 2009;50(2):330-4. [pmid: 19446989].
130 Vogt MT, Cauley JA, Newman AB, et al. Decreased ankle/arm blood pressure index and mortality in elderly women. JAMA. 1993;270(4):465-9. [pmid: 8320785].
131 Moneta GL, Strandness DE Jr. Peripheral arterial duplex scanning. J Clin Ultrasound. 1987;15(9):645-51. [pmid: 3119669].
132 Strandness DE, Didisheim P, Clowes AW, et al., editors. Vascular Diseases: Current Research and Clinical Applications. Orlando, FL. Grune & Stratton. 1987.
133 Criqui MH, Fronek A, Klauber MR, et al. The sensitivity, specificity, and predictive value of traditional clinical evaluation of peripheral arterial disease: results from noninvasive testing in a defined population. Circulation. 1985;71(3):516-22. [pmid: 3156007].
134 Barnes RW, Baker WH, Shanik G, et al. Value of concomitant sympathectomy in aortoiliac reconstruction. Results of prospective, randomized study. Arch Surg. 1977;112:1325-30. [pmid: 921531].
135 van der Meer IM, Bots ML, Hofman A, et al. Predictive value of noninvasive measures of atherosclerosis for incident myocardial infarction: the Rotterdam Study. Circulation. 2004;109(9):1089-94. [pmid: 14993130].
136 Murphy TP, Dhangana R, Pencina MJ, et al. Ankle-brachial index and cardiovascular risk prediction: an analysis of 11,594 individuals with 10-year followup. Atherosclerosis. 2012;220(1):160-7. [pmid: 22099055].
137 Murabito JM, Evans JC, Nieto K, et al. Prevalence and clinical correlates of peripheral arterial disease in the Framingham Offspring Study. Am Heart J. 2002;143(6):961-5. [pmid: 12075249].
138 Fowler B, Jamrozik K, Norman P, et al. Prevalence of peripheral arterial disease: persistence of excess risk in former smokers. Aust N Z J Public Health. 2002;26(3):219-24. [pmid: 12141616].
139 Jager A, Kostense PJ, Ruhe HG, et al. Microalbuminuria and peripheral arterial disease are independent predictors of cardiovascular and all-cause mortality, especially among hypertensive subjects: five-year followup of the Hoorn Study. Arterioscler Thromb Vasc Biol. 1999;19(3):617-24. [pmid: 10073965].
140 McDermott MM, Guralnik JM, Albay M, et al. Impairments of muscles and nerves associated with peripheral arterial disease and their relationship with lower extremity functioning: the InCHIANTI Study. J Am Geriatr Soc. 2004;52(3):405-10. [pmid: 14962156].
141 Ogren M, Hedblad B, Isacsson SO, et al. Non-invasively detected carotid stenosis and ischaemic heart disease in men with leg arteriosclerosis. Lancet. 1993;342(8880):1138-41. [pmid: 7901475].
142 Criqui MH, Langer RD, Fronek A, et al. Mortality over a period of 10 years in patients with peripheral arterial disease. N Engl J Med. 1992;326(6):381-6. [pmid: 1729621].
143 Hiatt WR, Hoag S, Hamman RF. Effect of diagnostic criteria on the prevalence of peripheral arterial disease. The San Luis Valley Diabetes Study. Circulation. 1995;91(5):1472-9. [pmid: 7867189].
144 Resnick HE, Lindsay RS, McDermott MM, et al. Relationship of high and low ankle brachial index to all-cause and cardiovascular disease mortality: the Strong Heart Study. Circulation. 2004;109(6):733-9. [pmid: 14970108].
145 McDermott MM, Fried L, Simonsick E, et al. Asymptomatic peripheral arterial disease is independently associated with impaired lower extremity functioning: the Women's Health and Aging Study. Circulation. 2000;101(9):1007-12. [pmid: 10704168].