# Discussion

## Summary of Review Findings

Our review presents new evidence published since the USPSTF's 2005 recommendation on screening for PAD and 2009 recommendation on ABI as a nontraditional risk factor in CAD risk assessment. The majority of evidence we found (18 population-based cohorts) addresses the additional value of ABI to FRS factors in CAD and CVD risk prediction, which was not considered as part of the 2005 and 2009 recommendations. We found very limited evidence to inform the diagnostic accuracy of ABI to detect PAD in primary care (one diagnostic accuracy study) or to treat persons with screen-detected low ABI or largely asymptomatic persons with PAD (two treatment trials) (Table 15).

Table 15 Overall Summary of Evidence

KQ | # and design of studies | Quality | Applicability | Consistency | Diagnostic accuracy or magnitude of association or effect (including precision)
KQ 1 | None | N/A | N/A | N/A | N/A
KQ 2 | 1 (n=306) Dx accuracy | Fair | Fair: asymptomatic, age ≥70 years, Sweden, ABI cutoff of <0.9 | N/A Only one study | Sensitivity: 15%–20%, wide confidence intervals Specificity: 99% Positive predictive value: 82% to 83% Negative predictive value: 80% to 84%
KQ 3 | 1 (n=306) Dx accuracy | Fair | Fair: asymptomatic, age ≥70 years, Sweden, did not directly address harms | N/A Only one study | No potential harms. Diagnostic accuracy study (KQ 2) reported one person had a vasovagal episode prior to receiving contrast for the MRA.
KQ 4 | 14 primary studies, 1 meta-analysis (n=52,510) 18 population-based cohorts | Fair to good | Good: broad range of cohorts with good age, sex, country (Australia, European countries, United States) representation | Inconsistencies in magnitude of risk reclassification and which subgroups will benefit most may be due to study heterogeneity in; 1. populations,; 2. definitions of composite outcomes,; 3. definitions of FRS categories, and; 4. choice of risk reclassification measure | Low ABI (≤0.9) can predict future CAD and CVD events after adjusting for FRS factors. Clinical implications of the incremental prognostic value of ABI to FRS is unclear due to limitations in the existing research and evolving practices in CVD risk assessment. The magnitude for appropriate CAD or CVD risk reclassification for ABI across all risk categories is likely small (at best). However, the total appropriate CAD risk reclassification for ABI may be greater in older persons. Because changes in the absolute magnitude in 10-year risk are likely small, ABI may be most useful for patients who are near the thresholds for different risk categories. The changes in absolute magnitude of 10-year risk may be greater in women. The value of ABI for CVD risk reclassification may be less or nonexistent for adults younger than age 65 years.
KQ 5 | 2 (n=3,705) RCT | Fair to good | Good for aspirin: screen-detected persons, ages 50 to 75 years, Scotland Fair for lipid lowering therapy: very intensive counseling intervention | Inconsistent, different populations and interventions | No benefit for aspirin 100 mg (vs. placebo) in persons with ABI of ≤0.90 to prevent CVD outcomes (8.2 years followup); HR, 1.02 (95% CI, 0.80 to 1.29) Some benefit for intensive telephone counseling intervention (vs. attention control) in persons with PAD; proportion with LDL <100 mg/dL at 12 months, 21.6% vs. 9.0% (p=0.003)
KQ 6 | 1 (n=3,350 RCT | Good | Good: screen-detected persons, ages 50 to 75 years, Scotland | N/A Only one study | Nonstatistically significant trend in major bleeding for aspirin 100 mg (vs. placebo) in persons with low ABI; HR, 1.71 (95% CI, 0.99 to 2.97)

Abbreviations: ABI = ankle-brachial index; CAD = coronary artery disease; CVA = cerebrovascular accident; CVD = cardiovascular disease; Dx = diagnostic; HR = hazard ratio; KQ = key question; LDL = low-density lipoprotein; N/A = not applicable; RCT = randomized, controlled trial.

### ABI for CAD or CVD Risk Prediction

Data from multiple population cohort studies (18 cohorts) show that low ABI (≤0.9) is generally associated with future CAD and CVD events, independent of FRS factors. Overall, we found no clear and consistent association of high ABI (>1.30 or 1.40) and future CAD or CVD events. However, the clinical relevance of the association of low ABI (≤0.9) and the impact on risk reclassification for CAD and CVD events is still uncertain (Table 15). Currently, classifying risk of CAD or CVD into low, intermediate, and high categories is clinically important to communicate risk and guide therapies to reduce CVD risk (e.g., statins). We recognize that CVD risk prediction is a rapidly evolving field. Nonetheless, our review focuses on the current state of evidence most applicable to current practice in the United States. Our included evidence for this KQ addresses two related, yet distinct, clinical questions: 1) should clinicians consider ABI measurement in asymptomatic persons to help clarify CAD or CVD risk, in addition to using the FRS? and 2) should ABI be added to existing risk assessment tools, such as the FRS, to help clarify the risk of CAD or CVD?

The ABI Collaboration's individual patient-level meta-analysis, by far the largest body of evidence, was a pragmatic study that addressed the first question and considered whether clinicians should consider ABI measurement after calculating the FRS to help clarify CAD risk.46 Across 13 population-based cohorts (n=43,919), the ABI Collaboration analyses demonstrate that 19 percent of men and 36 percent of women could be reclassified based on their ABI results when added to the FRS. We cannot determine whether the direction of reclassification is correct, however, because the study does not report NRI, which distinguishes reclassification separately according to whether patients suffered an event. Second, the ABI Collaboration reclassification analysis is based on the 10-year risk of total CAD (CAD death, MI, and angina), as opposed to hard CAD events (CAD death and MI only) that were used in the ATP III FRS algorithm. This difference in composite outcomes may be clinically important because the absolute change in risk (e.g., the change in the 10-year risk for high-risk men with normal ABI changed from 23% to 18%) that currently results in risk reclassification may not be clinically important if the measurements of risk are imprecise (i.e., CIs cross thresholds of risk categories) or if definitions based on total versus hard CAD events are applied.

Four included studies are explanatory models designed to answer the second question regarding whether ABI should be added to the FRS to help improve CAD or CVD risk prediction.47-49,91 In general, these studies (n=22,055) suggest that: 1) the risk reclassification is small for CAD and CVD events, 2) the NRI may be larger for older persons for total or hard CAD events (Health ABC; n=2,191),47 and 3) the NRI is not significant for persons younger than age 65 years for total CVD events (ARIC; n=11,594).91 Due to limitations in the regression models, the apparent incremental prognostic value of ABI in these studies may be higher than if the Framingham investigators were to develop a new risk score that included ABI and all of the ATP III factors.

Unfortunately, making meaningful comparisons across studies is very difficult due to differences in populations, (e.g., age, sex, race/ethnicity), differences in choice of referent group (i.e., definition of normal ABI), differences in the definitions of composite CAD and CVD outcomes (e.g., hard vs. total CAD) and risk categories (e.g., intermediate risk of 10% to 19%, 15% to 25%, or 5% to 20%), and differences in measures of reclassification (i.e., percent reclassified, NRI, difference in AUC). These differences, however, reflect the real-world practice of CVD risk prediction. Despite difficulties in establishing consistency of findings due to differences in methods, we can posit that: 1) the magnitude for appropriate risk reclassification across all risk categories is likely small (at best); 2) because changes in magnitude of risk are likely small, ABI may be most useful for patients who are near the thresholds for different risk categories or near boundaries that affect clinical decisionmaking;92 and 3) the value of ABI for risk reclassification may be less or nonexistent for adults younger than age 65 years. Based on these conclusions, screening ABI (i.e., not in symptomatic persons) should be conducted in targeted populations, as opposed to unselected adults (as with universal screening). For a more detailed discussion of targeted screening, see a later section.

Our review focused only on the additional value of ABI to the FRS, as defined by ATP III. Therefore, we excluded publications from eight cohorts that did not adjust for all the FRS factors: the Belgian Physical Fitness,103 Framingham,104 getABI,105,106 Limburg PAOD,107 Men Born in 1914,^108^ NHANES,10 Casas Artery,109 and SHEP110 studies. Four of these eight cohorts were included in the ABI Collaboration meta-analysis, as the ABI Collaboration investigators had access to patient-level data and were able to conduct de novo analyses. The findings from the four cohort studies not included in the ABI Collaboration were consistent with the findings from studies included in our review (i.e., consistent risk association of low ABI and future CAD or CVD morbidity and/or mortality, as well as all-cause mortality). The getABI cohort was a large (n=6,880) well-conducted prospective study of unselected persons age 65 years or older. This cohort was not included in the ABI Collaboration.105 This study included a subgroup comparison of CAD and CVD risk in symptomatic persons (n=593) versus asymptomatic persons (n=836) with an ABI of less than 0.9. In this cohort, having a low ABI was associated with an elevated risk for CVD events and mortality. There was no significant difference between risk of CVD events and mortality in symptomatic persons with a low ABI.

Our review found four new studies that addressed risk reclassification published since 2006, the final search year for the previous review conducted for the USPSTF on screening for intermediate risk factors for CAD.47-49,91 While this previous review found only three cohort studies that suggested that ABI was predictive of some CVD events, the overall strength of evidence was poor.111 We found no other reviews that addressed the reclassification of CAD or CVD risk using ABI, other than the ABI Collaboration meta-analysis included in our review. The ACCF/AHA 2010 “Guideline for Assessment of Cardiovascular Risk in Asymptomatic Adults” recommended ABI as a reasonable tool for cardiovascular risk assessment among persons at intermediate risk (Class IIa, Level B),57 primarily citing the ABI Collaboration meta-analysis.46 In our summary of this meta-analysis, however, the greatest reclassification was among high-risk men with normal ABI and low- or intermediate-risk women with low ABI. Therefore, ABI is helpful for intermediate-risk women but not necessarily intermediate-risk men, based solely on the ABI Collaboration findings.

Our review focuses on the additional risk discrimination of ABI to the FRS, as defined by ATP III. This risk classification algorithm will be updated in early 2013.^92^ This new algorithm will likely focus on the risk for global CVD events, rather than CAD-specific risk. If the updated algorithm and recommendations change the definition of risk categories (i.e., intermediate risk) or shift the practice paradigm to lower thresholds of treatment (e.g., statins or lower LDL goals for lower-risk individuals), the value of ABI will most certainly change, and possibly render this algorithm less clinically important.

### ABI to Detect PAD in Primary Care

Based on one small, fair-quality study (n=306) in older Swedish adults, it appears that the sensitivity of ABI (≤0.9) is low (15% to 20%) but the specificity near 100 percent. The positive and negative predictive values for ABI were adequate (i.e., >80%) (Table 15).88 Other diagnostic studies of ABI were mainly conducted in persons referred for vascular testing or with symptoms. The 2012 NICE guidelines on lower limb PAD explicitly do not address screening for asymptomatic PAD; however, they do recommend using ABI as part of the diagnostic evaluation in persons with suspected PAD (e.g., having intermittent claudication, leg ulcers, common foot problems, or cardiovascular risk factors).112 These guidelines included five studies of diagnostic accuracy in persons with suspected PAD, using an imaging reference standard. The guidelines found that sensitivity and specificity for an ABI of less than 0.9 ranged from 71 to 89 percent and 42 to 93 percent, respectively. The five studies used different diagnostic reference standards in different populations, with different ABI protocols (e.g., manual Doppler or oscillometric blood pressure). Another recent review of eight diagnostic accuracy studies also found that the sensitivity and specificity of ABI ranged from 61 to 95 percent and 56 to 90 percent, respectively.113 Both of these reviews focus on the test performance of ABI conducted in symptomatic patients or specialized populations (e.g., inpatients). As a result, the estimates of test performance may not apply to screening in primarily asymptomatic persons or unselected populations.

While we found no evidence that explicitly evaluates the harms of ABI testing, we do not hypothesize any major harms, given that the test itself and subsequent diagnostic testing in persons without symptoms are noninvasive. Draft NICE guidelines also found no specific evidence for harms and state that ABI is a noninvasive test with no recognized harms with correct equipment use.112 Lack of appropriate training in how to conduct ABI testing, however, may result in misdiagnosis.

### Treatment of Persons With Screen-Detected Low ABI or Asymptomatic PAD

There is very sparse evidence addressing asymptomatic or minimally symptomatic (e.g., with atypical symptoms or mild intermittent claudication) persons with low ABI or PAD. Based on one large, good-quality trial (n=3,350), low-dose aspirin does not prevent CVD events in adults ages 50 to 75 years without known CVD who have a low ABI (≤0.9). In fact, low-dose aspirin may increase major bleeding events. One smaller trial showed that an intensive telephone counseling intervention aimed at adults with primarily asymptomatic PAD can decrease LDL levels and achieve treatment goal levels (<100 mg/dL) compared with an attention control.

The vast majority of treatment research is conducted in symptomatic persons with PAD. Expert-based guidelines by the ACCF/AHA and the Trans-Atlantic Inter-Society Consensus (TASC) II are generally in agreement on their recommendations on the management of PAD, other than a few key differences in the grading of, and language used for, these recommendations.3,8 Both of these groups agree on aggressive medical management of PAD and aggressive management of the diseases (i.e., diabetes) or CVD risk factors (i.e., smoking, increased lipids, hypertension) contributing to PAD. These treatment guidelines, however, largely focus on treatment of symptomatic PAD, citing literature in persons with symptomatic disease. Therefore, we did not include this evidence in our review. In 2012, NICE issued evidence-based treatment guidance that focuses exclusively on exercise therapy, naftidrofuryl oxalate, and revascularization in persons with intermittent claudication or critical limb ischemia and pain management in critical limb ischemia.112 In October 2012, a draft report of a comprehensive review of “Treatment Strategies for Patients With PAD” was posted for public comment through AHRQ's Effective Health Care program.114 This report focused on treatment of persons with intermittent claudication or critical limb ischemia. This report also assessed the effectiveness of antiplatelet therapy for asymptomatic persons with PAD and found the same evidence and came to the same conclusion as our review.

### ABI in Clinical Practice

The ABI measurement followed rigorous protocols in the diagnostic and prognostic studies included in our review. As with any intervention or testing, the real-world performance of ABI may be less than ideal. The implementation of ABI as a screening practice in primary care represents challenges around opportunity costs of screening, as well as reproducibility. The ABI may take up to 15 minutes to measure and likely cannot be conducted as part of the primary care visit.3 In the diagnostic study, ABI testing required a minimum of 30 minutes of rest before the ABI was measured.88 In the prognostic population-based cohort studies, the resting time before ABI was measured varied. Although the ABI is considered to have good reproducibility,3 measuring it correctly requires training. Without proper training, results can vary substantially, which can impact its test performance. Ideally, ankle pressure is measured over two sites on each leg—one of which is the posterior tibial artery, the other being the dorsalis pedis artery or the anterior tibial artery. The value used for the ankle measurement could be the higher, the lower, or the mean of the two arterial pressures. Similarly, arm pressure is ideally measured over the right and left arms; the value used could be the mean or the higher of the right and left pressures.25,35, 36,115 While ABIs are calculated separately for each leg, a single ABI—usually, the lower of the two leg values—might be used to reflect a patient's general health.115,116 The technique chosen can affect the prevalence of a low ABI (≤0.9),25,35,36,115 as well as the association of a low ABI with CVD risk factors,25,35,115 prevalent CVD,36,115 and subclinical atherosclerosis.35

The handheld Doppler ultrasound should be used to measure systolic pressure. Other methods, such as an oscillometric (automated) device,34,117 a stethoscope,118 or palpation119 should not be substituted, as these methods have lower test performance when compared with the handheld Doppler ultrasound. Both the recent AHA scientific statement on the measurement of ABI and the NICE guidelines explicitly recommend that the ABI be conducted manually with a Doppler probe in preference to an automated system.112,116

Protocols for conducting ABI measurement vary across guidelines, research, and practice. Both the ACCF and AHA, for example, recommend using the higher of the systolic pressures from the ipsilateral dorsalis pedis and posterior tibial arteries, divided by the higher of the systolic pressures from the right and left brachial arteries.3,116 NHANES, on the other hand, used the mean of the systolic pressures from the ipsilateral dorsalis pedis and posterior tibial arteries, divided by the mean of the systolic pressures from the right and left brachial arteries.25 Most protocols for ABI measurement in our included studies used a manual device, an average of pressures, and measurement from the posterior tibial artery. There was variation, however, in the number of times the blood pressure was measured (e.g., PIVUS took the average of three brachial measurements, while EAS took a single posterior tibial measurement), the choice of measurement used (e.g., MESA used the higher of dorsalis pedis or posterior tibial pressures), the location of ankle measurement (e.g., MESA measured dorsalis pedis and posterior tibial pressures), and the choice of manual versus automated devices (e.g., ARIC used an oscillometric blood pressure device).

Currently in the United States, ABI alone does not have a billing code for reimbursement.120 As such, reimbursement requires additional testing (i.e., Doppler waveform recording and analysis, volume plethysmography, or transcutaneous oxygen tension measurements), so implementation of ABI in clinical practice would require specialized equipment.

### Targeted Screening

As mentioned earlier, certain subgroups may derive a higher benefit from screening than a general population, suggesting that targeted (as opposed to universal) screening may be appropriate. Taken together, the best available evidence on screening with ABI in primary care, the best prevalence estimates of abnormal ABI in general or primary care populations, and the known epidemiology of risk factors for PAD can inform which subgroups may benefit from ABI measurement, either to detect asymptomatic PAD or to predict risk for CAD or CVD events. We found that several key factors, including age, sex, smoking, and composite FRS, may inform targeted screening. Current guidelines by the ACCF/AHA recommend screening in persons age 50 years or older with a history of smoking or diabetes. The primary rationale for screening persons with diabetes has been the higher prevalence of PAD and more commonly asymptomatic disease in persons with diabetes. Our review purposely excluded the use of ABI in persons with known CVD and/or diabetes, however, as these persons should be receiving maximal CVD risk reduction interventions. Therefore, we do not address the value of ABI testing in these populations.

First, evidence for screening ABI in our review is more consistent and robust for older adults age 65 years and older. The sole diagnostic accuracy study was conducted in adults age 70 years and older.88 The results from the ARIC cohort study (ages 45 to 64 years) examining risk prediction (KQ 4) showed nonsignificant risk reclassification for future CVD events and no significant association with future cerebrovascular events.91,98 Prevalence data from population-based studies support this finding, as the prevalence of low ABI is low in adults younger than age 60 years, as is test positivity or yield.12

Second, sex and different underlying cardiovascular risks may influence the relative magnitude of benefit. Included evidence suggests that persons at the thresholds of FRS risk categories have greater potential of being reclassified based on ABI results. The ABI Collaboration meta-analysis, with the most robust sex-specific analyses, suggests that women at low or intermediate FRS risk with a low ABI (≤0.9) have the greatest change (increase) in risk.46 Because men have a higher FRS than women, the prevalence of low ABI is higher in low- to intermediate-risk women compared with men at low to intermediate risk (Table 6a), all other factors being equal. Targeting clinic populations with higher underlying prevalence of low ABI based on epidemiology may be reasonable. Based on multiple studies in general or primary care populations, current smoking is the strongest predictor for low ABI for both men and women, and across all ages.19,26-30

Finally, limited data from cohorts that include nonwhite populations suggest that this evidence should also apply to these populations. Available data, however, are most applicable to blacks and whites, as other races and ethnicities are grossly underrepresented. Contextual data show that while the FRS is well calibrated across a wide range of white and black populations, it may overestimate risk in other populations, such as patients of Asian, Native American, or Latino/Hispanic descent.45

## Limitations

Our review has several important limitations. First, our review focuses on the use of ABI as a screening tool, rather than a diagnostic tool. As a result, we included studies that focused primarily on unselected or asymptomatic persons. The overwhelming majority of screening and treatment studies focused on selected populations (e.g., referred to a vascular laboratory or clinic) or persons with PAD symptoms. Few studies made a distinction between atypical symptoms and intermittent claudication. Our review explicitly excluded studies in which a large proportion of subjects had intermittent claudication. While we did allow for studies that included subjects with atypical symptoms, few studies described symptoms with such detail. In addition, our review excluded studies of populations with known existing CVD, diabetes, or severe chronic kidney disease. The current literature on screening or treating generally asymptomatic patients is very limited. Only one diagnostic study with a suitable reference standard has been conducted in an unselected population, and this population was small, older, and ethnically homogenous (conducted in Sweden). Experts have argued that diagnostic studies in symptomatic persons should be applicable to asymptomatic persons because 1) the resting ABI is done while patients are asymptomatic (even if they experience intermittent claudication with activity), and 2) the reduced muscular metabolism (which causes symptoms) has no impact on arterial perfusion pressure. Empiric diagnostic accuracy studies have shown, however, that a distorted selection not also affects applicability but also the validity of these types of studies due to spectrum bias.69-73 Spectrum bias refers to the phenomenon that the diagnostic test performance may change between clinical settings due to changes in patient case-mix. Therefore, this review focused on studies less prone to spectrum bias. For context in our discussion, we acknowledge other systematic reviews that have been conducted on the diagnostic accuracy of ABI in selected populations, as the existing evidence in asymptomatic persons is very limited.

Only two treatment trials focused on generally asymptomatic persons, and these trials were quite different from one another (aspirin and telephone counseling). Additionally, there is no evidence on other interventions to reduce CVD risk or on interventions that might delay the onset of lower-extremity symptoms in asymptomatic persons. Again, experts have argued that treatment in symptomatic persons should be applicable to asymptomatic persons because the rates of CVD events and mortality are similar in symptomatic versus asymptomatic persons with low ABI, as demonstrated in the getABI cohort. We acknowledge that interventions (i.e., antiplatelet therapy, statins, angiotensin-converting enzyme inhibitors) that are effective in CVD risk reduction in symptomatic persons with PAD may be applicable to persons without symptoms. Based on direct evidence in asymptomatic persons with low ABI, however, it is unlikely that low-dose aspirin benefits screen-detected persons with low ABI and no known CVD or diabetes.100 Unfortunately, the effectiveness of treatments in persons with symptomatic PAD is not within the scope of this review. It is also important to acknowledge that many persons with symptomatic (or asymptomatic) PAD included in major CVD treatment trials (e.g., Heart Outcomes Prevention Evaluation trial, Heart Protection Study, Clopidogrel versus Aspirin in Patients at Risk of Ischaemic Events trial, Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management and Avoidance trial) had comorbid CAD and/or diabetes.121-126

Our review focuses on the additional risk discrimination ABI adds to the FRS (as defined by ATP III). While ABI is the most commonly used risk prediction tool in the United States, it is not the only tool, and the current version is set to be updated with the release of ATP IV in early 2013.^92^ It is likely that the new algorithm will focus on the risk for global CVD events, rather than CAD-specific risk. If the updated algorithm and recommendations change the definition of risk categories (e.g., intermediate risk) or shift the practice paradigm to lower thresholds of treatment (e.g., statins or lower LDL cholesterol goals for lower-risk individuals), however, the prognostic value of ABI will most certainly change and could possibly become less clinically important. There are also many other accepted risk tools, including the Framingham global CVD score,51 QRISK,52,53 and the Reynolds risk score,54,55 that may perform better than the FRS to predict CVD events. None of the excluded studies, however, evaluated the ability of ABI to improve upon the risk prediction of these other risk tools. One included study (MESA; n=1,330) found no substantial reclassification for ABI in intermediate-risk persons when added to the Reynolds risk score to predict CAD (NRI, 0.002) or CVD (NRI, 0.008).48 Another risk prediction study that was not included in our review evaluated reclassification of other risk markers in addition to the Coronary Risk in the Elderly (CORE) model.127 This study demonstrated small (or negligible) NRIs for ABI alone in addition to the CORE model in the CHS and Rotterdam cohorts (0.033 [CHS] and 0.003 [Rotterdam] in men; 0.001[CHS] and 0.036 [Rotterdam] in women).127 Although there are many population-based cohort studies examining the additional value of ABI in risk prediction, race/ethnic groups other than whites and blacks are not well represented.

It is also important to note that the NRI itself has important limitations. While the NRI's strength is the ability to interpret the “appropriateness” of risk reclassification, the measure itself is agnostic. In other words, movements across categories are weighed equally, so that persons move from low to high CAD or CVD risk in the same manner as persons move from high to intermediate risk. For clinical management, it is arguably more important if a person is reclassified from low to high risk, as this would change therapies and therapeutic goals, versus reclassification of someone from high to intermediate risk, as clinicians and patients may be less likely to change or withdraw therapies.75 Therefore, the NRI should not be interpreted in isolation. As with any body of evidence, the results from well-conducted studies (i.e., in which ABI was measured under protocols) may be overly optimistic compared with results when ABI is used in clinical practice. ABI measurement techniques vary across studies and in clinical practice. Differences in techniques may affect its reproducibility and performance in detecting PAD, as well as predicting CAD and/or CVD events.

## Emerging Issues and Future Research

The existing limitations in the current body of literature can help inform the areas of priority for future research.

First, researchers and clinicians in this field need clarity of language about describing PAD and should not automatically describe low ABI as equivalent to having PAD. It is clear from the risk prediction literature that having a low ABI is not equivalent to having a CAD risk equivalent or CVD.

Second, because risk prediction for CAD and CVD is an evolving science, with updates to ATP III expected in early 2013,^92^ ongoing studies or re-analyses of existing population-based cohorts will be crucial to our understanding of the value of screening ABI to reclassify CAD and CVD risk beyond FRS and other risk prediction models.

Third, additional analyses for risk prediction will help us understand the relative value of ABI in important subgroups (e.g., those with higher prevalence of low ABI, those in whom traditional risk prediction does not perform well, or those near thresholds of risk categories), where ABI may help in the discrimination and calibration of existing models. This information will inform the utility or need for targeted screening. The ABI Collaboration represents the largest and most clinically important source of data with enough power to conduct these subgroup analyses. NRI for important subgroups (e.g., by age, sex, race/ethnicity) from the ABI Collaboration data would better clarify the clinical value of ABI in CVD risk prediction.

Fourth, more information about the value of high ABI (>1.30 or 1.40) in CVD risk prediction is needed to help us understand whether high values should be interpreted as predicting a normal risk, lower risk, increased risk, or differential risk depending on the patient's sex.

Fifth, more studies using valid reference standards are needed to describe the test performance characteristics of ABI for detecting PAD in unselected or asymptomatic individuals.

Sixth, more trials evaluating CVD risk factor modification (i.e., antiplatelet therapy, pharmacologic or nonpharmacologic therapies for lipid reduction, blood pressure control, smoking cessation, and weight management) are needed to determine whether treating asymptomatic or minimally symptomatic persons with low ABI reduces cardiovascular outcomes, prevents lower-extremity symptoms, or improves quality of life compared with treating persons with symptomatic PAD. Likewise, more trials are needed evaluating whether aggressive CVD risk factor modification in persons with low ABI detected by screening, without known CVD or diabetes, is beneficial compared with treatment based on known risk factors alone.

In our communication with Dr. Gerald Fowkes of the ABI Collaboration (October/November 2010), we understand that a re-analysis of the ABI Collaboration data is underway, which will address many of the limitations of the current meta-analysis, as outlined in the results of our report, including the calculation of the NRI. We believe that this re-analysis will provide crucial information in the understanding of the additional value of ABI to FRS in CVD risk prediction.

Our search of Clinicaltrials.gov identified five additional studies in progress that may address some of these outstanding issues (Appendix C). The most promising is a large population-based screening trial in Viborg, Denmark with planned enrollment of 40,000.^128^ This study, the Viborg Vascular screening trial, is randomizing men (ages 65 to 74 years) to screening versus no screening for PAD and abdominal aortic aneurysm. Individuals with abnormal results will be treated for CVD risk factors. This study's outcomes will include CVD morbidity and mortality after 10 years. This trial started in September 2008 and is scheduled to have primary outcome data in late 2018.

## Response to Public Comments

A draft version of this evidence report was posted for public comment on the USPSTF Web site from March 19 to April 15, 2013. We received comments from six unique individuals or organizations. All comments were reviewed and considered. There were no new substantive issues brought up during the public comment period that were not previously raised and adjudicated during the expert review phase. The major concern raised was our review's exclusions of studies conducted primarily in symptomatic individuals (i.e., persons with intermittent claudication). These studies are considered outside the USPSTF's scope and therefore no changes were incorporated into the final report. Please refer to the Limitations section for details.

## Conclusions

One study showed that ABI in primary care has low sensitivity to detect PAD in older adults but adequate positive and negative predictive values. We found no evidence that suggested treatment of low ABI detected by screening or treatment of generally asymptomatic PAD leads to fewer CVD outcomes. One trial showed that low-dose aspirin for persons with low ABI detected by screening does not prevent CVD outcomes. The potential utility of screening ABI in primary care is not only its ability to detect underlying PAD but its ability to aid in CVD risk prediction. Based on a large body of evidence (14 primary studies and one meta-analysis reflecting a total of 18 cohorts), ABI likely improves risk reclassification beyond FRS, but the magnitude of improvement is unclear and likely to be small. The net reclassification may be greatest for persons age 65 years and older and persons at the thresholds of FRS risk categories. There is limited evidence on how ABI might add to risk prediction tools other than the FRS, and it is unclear how the current evidence will apply to evolving recommendations. While there are unlikely to be important harms from screening ABI in primary care, there are issues with implementing ABI for routine screening due to the time needed to conduct the test, variation in ABI protocols, and equipment needed for reimbursement of testing in the current environment.