# Results

Our review presents all new evidence that was generated since the 2005 systematic review to support the previous USPSTF recommendation (Table 2). The previous review included only three studies, none of which were included in our review; we excluded two studies because they focused primarily on persons with symptomatic PAD63,64 and one study because it was a cross-sectional study evaluating treatment.65 We excluded studies from the 1996 review due to general lack of relevance or study design considerations.

Table 2 Comparison of Studies Included in Previous and Present USPSTF Reviews

Key Question | Study | USPSTF Reviews
Key Question | Study | 1996^129^ | 2005^62^ | Current
KQ 1 Morbidity | Fowler 2002^63^ | | X
KQ 2 Test Performance | Wikstrom 2009^129^ | | | X
KQ 2 Test Performance | Wikstrom 2008^88^ | | | X
KQ 2 Test Performance | Vogt 1993^130^ | X
KQ 2 Test Performance | Moneta 1987^131^ | X
KQ 2 Test Performance | Strandness 1987^132^ | X
KQ 2 Test Performance | Criqui 1985^133^ | X
KQ 2 Test Performance | Barnes 1979^134^ | X
KQ 3 Harms | None
KQ 4 Prediction | Hoorn 2012 97 | | | X
KQ 4 Prediction | Kavousi 2012^49^ | | | X
KQ 4 Prediction | Murphy 2012^91^ | | | X
KQ 4 Prediction | Yeboah 2012^48^ | | | X
KQ 4 Prediction | Rodondi 2010^47^ | | | X
KQ 4 Prediction | Fowkes 2008^46^ | | | X
KQ 4 Prediction | Sutton-Tyrrell 2008^93^ | | | X
KQ 4 Prediction | Price 2007^96^ | | | X
KQ 4 Prediction | Weatherley 2007^94^ | | | X
KQ 4 Prediction | O'Hare 2006^38^ | | | X
KQ 4 Prediction | Lee 2004^50^ | | | X
KQ 4 Prediction | Van der Meer 2004^135^ | | | X
KQ 4 Prediction | Abbott 2001^99^ | | | X
KQ 4 Prediction | Abbott 2000^95^ | | | X
KQ 4 Prediction | Tsai 2001^98^ | | | X
KQ 4 Prediction | Vogt 1993^131^ | X
KQ 5 Treatment | McDermott 2011^101^ | | | X
KQ 5 Treatment | Fowkes 2010^100^ | | | X
KQ 5 Treatment | McDermott 2003^65^ | | X
KQ 5 Treatment | Tornwall 1997^64^ | | X
KQ 6 | Fowkes 2010^100^ | | | X

## KQ 1 Is Screening Generally Asymptomatic Adults for PAD Using ABI Effective in Reducing CVD Morbidity and Mortality?

We found no studies that directly assessed the impact of screening unselected adults (or generally asymptomatic adults) with ABI on CVD or PAD health outcomes.

## KQ 2 What Is the Diagnostic Accuracy of ABI as a Screening Test for PAD in Generally Asymptomatic Adults?

We found one fair-quality study (described in two articles) that estimated the test performance of ABI screening for PAD in a generally asymptomatic population that was representative of patients in primary care (Table 3).88 We excluded two poor-quality studies because they used a suboptimal reference standard (central augmentation index) or because this standard was not applied to a reasonable portion of the sample.89,90 We included one diagnostic accuracy study that involved 306 individuals randomly recruited from a larger population-based cohort study called the Prospective Investigation of the Vasculature in Uppsala Seniors (PIVUS) (n=1,016).88 Participants in this study were 70-year-old (at the time of study recruitment) men and women (equally distributed) without contraindications for an MRA (e.g., without a cardiac pacemaker, prosthetic valves, intracranial clips, or claustrophobia). Approximately 8 percent of participants were smokers, 7 percent had a history of MI, 4 percent had a history of CVA, 11 percent had diabetes, and 33 percent were on medications for hypertension.

Table 3 Study Characteristics and Results for KQ 2: In Generally Asymptomatic Adults, What Is the Diagnostic Accuracy of ABI as a Screening Test for PAD?

Cohort, Study, Year | Country, N Analyzed | ABI Cutoff | Mean Age | % Women | % White | % Risk Factor | % ABI <0.9 | % Stenosis | % Sensitivity/Specificity (95% CI) | % PPV/NPV (95% CI)
PIVUS Wikstrom, 2008^88^ Wikstrom, 2009^129^ | Sweden 306 | <0.9 | 70 years | 47.4 | 100^*^ | Current smoker: 7.8 Hx MI: 6.9 Hx CVA: 3.9 Hx DM: 10.6 HTN meds: 33 | Right leg 12/268=4.5% Left leg 11/265=4.2% | ≥50% stenosis Right leg 51/268=19.0% Left leg 61/265=23.0% 100% stenosis Right leg 34/268=12.7% Left leg 37/265=14.0% | Right leg Sensitivity: 20 (10 to 34) Specificity: 99 (96 to 100) Left leg Sensitivity: 15 (7 to 27) Specificity: 99 (96 to 100) Right leg Sensitivity: 24 (11 to 42) Specificity: 98 (95 to 99) Left leg Sensitivity: 16 (7 to 33) Specificity: 98 (95 to 99) | Right leg PPV: 83 (51 to 97) NPV: 84 (79 to 88) Left leg PPV: 82 (48 to 97) NPV: 80 (74 to 84) Right leg PPV: 67 (35 to 89) NPV: 90 (85 to 93) Left leg PPV: 55 (25 to 82) NPV: 88 (83 to 91)

* Assumed.

Abbreviations: ABI = ankle-brachial index; CI = confidence interval; CVA = cerebrovascular accident; DM = diabetes mellitus; HTN = antihypertension; Hx = history; MI = myocardial infarction; NPV = negative predictive value; PIVUS = Prospective Investigation of the Vasculature in Uppsala Seniors; PPV = positive predictive value.

This study used whole-body MRA to detect at least 50 percent stenosis or total occlusion (100% stenosis) in the pelvic or lower extremity arteries as its reference standard for diagnosing PAD. While this was a well-conducted study, the mean interval between ABI and MRA was 16 months (range, 3 to 24 months) and it is unclear whether the ABI and MRA (reference standard) were interpreted independently. While using at least 50 percent stenosis as a definition for PAD is reasonable, it is unclear whether this is the optimal or universally accepted threshold for the diagnosis. Furthermore, ABI testing in this study was conducted after subjects had rested supine for 30 minutes, which may not be applicable in primary care.

About 4 percent of persons in this trial had an ABI of less than 0.9 (used as the cutoff for low ABI). An ABI of less than 0.9 was 15 (95% CI, 7 to 27) to 20 percent (95% CI, 10 to 34) sensitive for at least 50 percent stenosis but 99 percent (95% CI, 96 to 100) specific. Although an ABI of less than 0.9 had very low sensitivity for detecting at least 50 percent stenosis by MRA, the positive and negative predictive values were reasonable: 82 (95% CI, 48 to 97) to 83 percent (95% CI, 51 to 97) and 80 (95% CI, 70 to 84) to 84 percent (95% CI, 79 to 88), respectively. Given the sample size of only 306 persons, only 4 percent of whom had a low ABI, the CIs around these estimates are quite wide.

We are unable to comment on whether and how the diagnostic accuracy of ABI varies by age, sex, race/ethnicity, or CVD risk factors based on this single study that was conducted in 70-year-old Swedish men and women.

## KQ 3 What Are the Harms of Screening With ABI?

We found no studies that directly addressed the harms of screening with ABI. In the only study that estimated the test performance of ABI in a population relevant to primary care screening, one person had a vasovagal episode before contrast for the reference MRA was administered; no other harms were reported.88

Since the ABI test is noninvasive, the harms associated with this test should be minimal. While there are potential harms from false-positive test results leading to unnecessary diagnostic testing or overdiagnosis, the diagnostic workup for an abnormal ABI in generally asymptomatic persons is also noninvasive and can be done without radiation (e.g., using duplex ultrasound or MRA). Therefore, the harms of false-positive test results and subsequent diagnostic testing should be low. Another potential harm is from false-negative testing leading to a missed diagnosis, as the sensitivity was quite low. The clinical importance of such missed diagnoses is unclear because these asymptomatic persons would not be detected without screening.

## KQ 4 Does ABI Accurately Predict CVD Morbidity and Mortality Independent of Traditional Risk Factors?

### Summary of Overall Findings

We included one fair-quality systematic review and 14 fair- to good-quality studies that addressed whether ABI could predict CAD or CVD morbidity and mortality independent of the FRS factors (Table 4). We included studies that demonstrated the additional prognostic value of ABI to age, sex, smoking status, systolic blood pressure, total cholesterol, and HDL cholesterol. Most evidence for this KQ comes from one large, individual patient-level meta-analysis from the ABI Collaboration.46 This meta-analysis (n=48,294) included 16 international population-based cohorts relevant to primary care: Atherosclerosis Risk in Communities (ARIC) Study, Belgian Physical Fitness Study, Cardiovascular Health Study (CHS), Edinburgh Artery Study (EAS), Framingham Offspring Study, Health in Men Study, Honolulu Heart Program, Hoorn Study, InCHIANTI Study, Limburg Peripheral Arterial Occlusive Disease (PAOD) Study, Men Born in 1914 Study, Rotterdam Study, San Diego Study, San Luis Valley Diabetes Study, Strong Heart Study, and the Women's Health and Aging Study. The other 14 studies included in our review represent eight unique cohorts (ARIC, CHS, EAS, Health ABC, Honolulu Heart Program, Hoorn study, Multi-Ethnic Study of Atherosclerosis [MESA], and Rotterdam Study), only two of which (Health ABC; n=2,191 and MESA; n=1,330) are not represented in the ABI Collaboration. We excluded many of the cohorts that were included in the ABI Collaboration meta-analysis because the individual articles did not include all the FRS factors in their multivariable models. Since the ABI Collaboration had access to patient-level data, however, they were able to include these cohorts in their analyses.

Table 4 Study Characteristics for KQ 4: Does ABI in Generally Asymptomatic Adults Accurately Predict CVD Morbidity and Mortality Independent of FRS?

Cohort Study, Year Quality | Country N Analyzed | Reference Group | Followup, year^*^ | Mean Age, year | % Women | % White | % Risk Factor | % ABI <0.9 | MI (# events) | CVA (# events) | Death (# events) | Other outcomes (# events)
ABI Collaboration Fowkes 2008^46^ Fair plus | Australia, Belgium, Italy, the Netherlands, Scotland, Sweden, US 48,294 | ABI = 1.11–1.40 | 10 | 61.7 | 48.3 | NR | HTN: NR Tobacco use: NR DM: NR | 7.7 | Composite (3884) | NR | CVD (CAD or CVA): alone (2718) and composite (3884) All-cause: alone (9924) | None
ARIC Tsai 2001^98^ Good | US 14,306 | ABI >1.20 | 7.2 (med) | NR range, 45–64 | 55.4 | 73.8 | HTN meds: 24.4 Tobacco use (current): 25.7 DM: 9.4 | 2.9 | NR | Composite (206) Hemorrhagic CVA not included | CVA: composite (206) | None
ARIC Weatherley 2007^94^ Good | US 13,588 | ABI ≥0.90 | 13.1 (med) | 54.0 | 56.8 | 73.8 | HTN: 33.2 Tobacco use (former): 31.5 (current): 25.8 DM: 8.7 | 2.8 | Composite (964) | NR | CAD: Composite (964) | None
ARIC Murphy 2012^91^ Good | US 11,594 | ABI = 1 SD | 14 (med) | 53.8 | 56.4 | 75.8 | HTN: 33.4 Tobacco use (current): 25.7 DM: excluded | 2.3 | Composite (659) | Composite (659) | CVD (CAD or CVA): composite (659) All-cause: alone (682) | None
CHS O'Hare 2006^38^ Fair plus | US 5,748 | ABI = 1.11–1.20 | 11.1 | 73 | 57 | 85 | HTN meds: 47.1 Tobacco use (current): 10.1 DM: 7.4 | 13.8 | Composite (1491) | Composite (1491) | CVD (CAD or CVA): composite (953) All-cause: alone (2311) | Angina, CABG, LE amputation or revascularization: composite (1491)
Edinburgh Lee 2004^50^ Fair plus | Scotland 1,507 | ABI >0.9 | 12 | 64.7 | 47.7 | NR | SBP (mean): 145 Tobacco use (current): 25.7 DM: 9.4 | 16.3 | Alone (fatal or nonfatal) (235) | Alone (fatal or nonfatal) (128) | CAD: alone (101) CVA: alone (49) CVD (CAD or CVA): composite (202) All-cause: alone (494) | None
Edinburgh Price 2007^96^ Fair plus | Scotland 1,007 | ABI >0.9 | 12 | 69.4 | 48.3 | NR | SBP (mean): 146 Tobacco use (pack-years): 2.48 DM: 3.9 | 18.7 | Composite (137) | Composite (137) | CVD (CAD or CVA): composite (137) | Angina or IC^*^ PPV/NPV only
Health ABC Rodondi 2010^47^ Good | US 2,191 | ABI = 1.01–1.30 | 8.2 (med) | 73.5 | 55.3 | 58.9 | HTN: 46.1 Tobacco use (former): 43.6 (current): 10.1 DM: 13.3 | NR | Composite (hard event= 197) Composite (total event= 351) | NR | CAD: composite (hard event=197) CAD: composite (total event=351) All-cause: NR | Angina hospitalization or revascularization: composite (total event=351)
Health ABC Sutton-Tyrrell 2008^93^ Good | US 2,886 | ABI = 0.91–1.30 | 6.7 | 73.6 | 51.7 | 59.4 | HTN: 49.9 Tobacco use (former): 45.3 (current): 10.1 DM: 14.6 | 13.3 | Composite (487) | Composite (174) | CAD: composite (487) CVA: composite (174) CVD (CAD or CVA): alone (219) All-cause: alone (616) | Angina hospitalization: composite (487) CHF hospitalization: alone (296)
Honolulu Abbott 2000^95^ Fair plus | US 2,863 | ABI ≥1.0 | NR range, 3–6 | NR range, 71–93 | 0 | 0 | HTN: NR Tobacco use: NR DM: NR | NR <0.8: 6.3 | Composite (186) | NR | CAD: composite (186) | None
Honolulu Abbott 2001^99^ Fair | US 2,767 | ABI ≥0.9 | NR range, 3–6 | NR range, 71–93 | 0 | 0 | HTN: 52.4 Tobacco use (former): 52.2 (current): 7.3 DM: 27.0 | 11.6 | NR | Composite (91) | CVA: composite (91) | None
Hoorn Hanssen2012^97^ Fair | The Netherlands 634 | ABI ≥0.9 | 17.2^†^ range, 0.5–19.2^†^ | 64.3^†^ range, 50–75^†^ | 51.9^†^ | NR | HTN: 39.1^†^ Tobacco use (ever): 62.5^†^ DM: 24.8^†^ | 10.4^†^ | NR | NR | CVD: alone (85) All-cause: alone (289) | None
MESA Yeboah 2012^48^ Fair | US 1,330 | ABI = 1 SD | 7.6 (med) | 63.8 | 33.3 | 35.7 | HTN meds: 38.2 Tobacco use (current): 16.5 (former): 37.1 (never): 46.3 DM: 0 | NR 1.14, med | Composite (94) | Composite (123) | CAD: composite (94) CVD: composite (123) | None
Rotterdam van der Meer 2004^135^ Fair plus | The Netherlands 6,389 | ABI ≥1.21 | 9 (est) | 69.3 | 61.9 | NR | HTN meds: 29.4 Tobacco use (current): 21.5 DM: 10.1 | NR <0.97: 25 | Composite (258) | NR | CAD: composite (258) | None
Rotterdam Kavousi 2012^49^ Good | The Netherlands 5,933 | ABI=0.91–1.40 | 6.8 (med) | 69.1 | 59.4 | NR | HTN meds: 23.5 Tobacco use (current): 17.5 DM: 12.9 | ≤0.9, 14 | Composite (347) | NR | CAD: composite (347) | None

* Mean (years).

† For cohort including patients with diabetes; values for patients without diabetes not reported separately.

Abbreviations: ABC = Aging and Body Composition; ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities; CABG = coronary artery bypass graph; CAD = coronary artery disease; CHF = congestive heart failure; CHS = Cardiovascular Health Study; CVA = cerebrovascular accident; CVD = cardiovascular disease; DM = diabetes mellitus; est = estimated; HTN = hypertension; IC = intermittent claudication; LE = lower extremity; med = median; meds =medications; MESA = Multi-Ethnic Study of Atherosclerosis; MI = myocardial infarction; NPV = negative predictive value; NR = not reported; PPV = positive predictive value; SBP = systolic blood pressure; SD = standard deviation.

Overall, low ABI (≤0.9) is generally associated with future CAD and CVD events, independent of FRS factors. This result is based on a large number of persons (n=52,510) across 18 different population-based cohorts, representative of a wide age range of adults of both sexes. The clinical relevance of this association (i.e., the degree to which it can reclassify CAD or CVD risk beyond FRS), however, is still uncertain. In general, the body of evidence can be divided into pragmatic studies (i.e., “Does ABI reclassify risk?”) and explanatory studies (i.e., “Can ABI reclassify risk?”). The ABI Collaboration meta-analysis provides by far the largest body of evidence. This pragmatic study demonstrates that ABI can reclassify both men and women based on their 10-year risk of total CAD events (CAD death, MI, and angina). This reclassification analysis included 13 population-based cohort studies reporting adequate information.46 While this analysis showed that 19 percent of men and 36 percent of women could be reclassified based on their ABI, several issues limit the interpretation of their findings. First, the study does not report the NRI, which limits our understanding of what proportion of persons have been appropriately reclassified and limiting the comparison of their findings to other studies included in this review (Table 1). Second, the ABI Collaboration reclassification table is based on risk of total CAD events (CAD death, MI, or angina), as opposed to hard CAD events (CAD death or MI only), which was the outcome used in the ATP III FRS algorithm (Table 5). Third, the reclassification of most men is based on relatively small absolute changes in risk (e.g., the change in 10-year risk for high-risk men with normal ABI changed from 23% to 18%) (Table 6a). Such absolute changes in risk, which currently result in risk reclassification, may not be clinically important if imprecision around these measurement of risk exists or if different definitions of risk categories (e.g., total vs. hard CAD events, CAD vs. CVD events, different treatment thresholds) are applied.

Table 5 Comparison of 10-Year Risks for Hard CAD Events Versus Total CAD Events by FRS Category42

Risk category | Hard CAD events (CAD death or MI) | Total CAD events (CAD death, MI, or angina)
Low | <10% | <15%
Intermediate | 10%–20% | 15%–25%
High | >20% | >25%

Abbreviations: CAD = coronary artery disease; MI = myocardial infarction.

Table 6a Risk Reclassification (by Sex) of ABI in Addition to FRS in the ABI Collaboration Cohorts46

Table 6a is a reclassification table using data reported in the ABI Collaboration study. It shows that when using an ABI of 1.11 to 1.40 as normal, 19 percent of men and 36 percent of women were reclassified when ABI was added to the FRS. For men, the greatest percent of reclassification was among those who were initially classified as high risk (23% over 10 years) with a normal ABI (1.11 to 1.40) and were subsequently reclassified as being at intermediate risk (18% over 10 years). Women who were initially at low or intermediate risk (11% or 13% over 10 years, respectively) who had a low ABI (0.9 or less) were subsequently reclassified as being at high risk (21% and 25% over 10 years, respectively). If the normal range of ABI was defined as 0.91 to 1.40 (the more traditional definition), the proportion reclassified would appear larger for men (35%) and smaller for women (7.3%). In this scenario, the greatest percent of reclassification remains the same; that is, among men at high risk with normal ABI and among women at low to intermediate risk with low ABI.

Group | FRS Category | Total | | ABI ≤ 0.90 | | ABI 0.91 to 1.10 | | ABI 1.11 to 1.40 | | ABI > 1.40
Group | FRS Category | N (%) | Total CAD risk (%) | N (%) | Total CAD risk (%) | N (%) | Total CAD risk (%) | N (%) | Total CAD risk (%) | N (%) | Total CAD risk (%)
Men | Low (<10%) | 5643 (26.3) | 5 | 76 (0.4) | 8 | 1076 (5.0) | 5 | 4255 (19.9) | 4 | 236 (1.1) | 5
Men | Intermediate (10%-19%) | 7392 (34.5) | 13 | 245 (1.1) | 16 | 2069 (9.7) | 12 | 4815 (22.5) | 12 | 263 (1.2) | 8^*^
Men | High (≥ 20%) | 8398 (39.2) | 23 | 1149 (5.4) | 40 | 3406 (15.9) | 21 | 3668 (17.1) | 18^*^ | 175 (0.8) | 14^*^
Women | Low (<10%) | 15505 (69.0) | 11 | 1083 (4.8) | 21^*^ | 6192 (27.5) | 10^*^ | 7909 (35.2) | 9 | 321 (1.4) | 11^*^
Women | Intermediate (10%-19%) | 5563 (24.7) | 13 | 558 (2.5) | 25^*^ | 2429 (10.8) | 12 | 2433 (10.8) | 11 | 143 (0.6) | 13
Women | High (≥ 20%) | 1418 (6.3) | 27 | 200 (0.9) | 44 | 598 (2.7) | 21 | 577 (2.6) | 22 | 43 (0.2) | 34

* Risk category changed from that predicted by the FRS when ABI included

Table 6b Risk reclassification (by sex) of ABI in addition to Framingham Risk Score (FRS) when collapsing ABI scores 0.91 to 1.40

Table 6b is a reclassification table using data reported in the ABI Collaboration study. It shows that when using an ABI of 1.11 to 1.40 as normal, 19 percent of men and 36 percent of women were reclassified when ABI was added to the FRS. For men, the greatest percent of reclassification was among those who were initially classified as high risk (23% over 10 years) with a normal ABI (1.11 to 1.40) and were subsequently reclassified as being at intermediate risk (18% over 10 years). Women who were initially at low or intermediate risk (11% or 13% over 10 years, respectively) who had a low ABI (0.9 or less) were subsequently reclassified as being at high risk (21% and 25% over 10 years, respectively). If the normal range of ABI was defined as 0.91 to 1.40 (the more traditional definition), the proportion reclassified would appear larger for men (35%) and smaller for women (7.3%). In this scenario, the greatest percent of reclassification remains the same; that is, among men at high risk with normal ABI and among women at low to intermediate risk with low ABI.

Group | FRS Category | Collapsing ABI scores: 0.91 to 1.40
Group | FRS Category | N (%) | Total CAD risk (%)
Men | Low (<10%) | 5331 (24.9) | 4
Men | Intermediate (10%-19%) | 6884 (32.1) | 12
Men | High (≥ 20%) | 7074 (33.0)^*^ | 19^*^
Women | Low (<10%) | 14101 (62.7) | 9
Women | Intermediate (10%-19%) | 4862 (21.6) | 11
Women | High (≥ 20%) | 1175 (5.2) | 21

* Risk category changed from that predicted by the FRS when ABI included

Four other selected cohorts were used in studies creating explanatory models designed to determine whether ABI can accurately reclassify CAD or CVD risk (using the NRI) when added to the FRS model (Table 7).47-49,91 Two of these studies are represented in the ABI Collaboration.49,91 NRIs ranged from 0.006 (for hard CAD)49 to 0.079 (for hard CAD).47 The Health ABC and the Rotterdam cohorts reported NRIs for all persons and those at intermediate FRS risk and demonstrated that the NRI was higher in the intermediate-risk group. In another fair-quality cohort study, the NRI for intermediate-risk persons (MESA; n=1,330) was smaller (0.036 for CAD outcomes and 0.068 for CVD outcomes). This cohort, however, was younger than the Health ABC and Rotterdam cohorts and used a different threshold for defining intermediate risk (>5% to <20%, rather than 10% to <20%).48 In all of these studies, however, the calculation of the NRI for the intermediate-risk group is inflated. Given limitations in reported data, we could only calculate a corrected NRI for the Health ABC and ARIC cohorts. The corrected NRI for the Health ABC cohort was similar to the overall NRI (0.038 [95% CI, -0.029 to 0.105] vs. 0.033 [95% CI, 0.0004 to 0.065], respectively). There was no statistically significant net reclassification of risk for future CVD events in a large cohort of persons younger than age 65 years (ARIC; n=11,594).91 Direct comparisons across studies' findings are difficult due to differences in their methods, definitions of composite CAD and CVD outcomes, and definitions of risk categories. While differences prevent us from determining the consistency of findings across different studies, results suggest that the overall NRI is relatively small, although it may be higher among older persons (Health ABC; n=2,191).47

Table 7 Summary of NRI Results for KQ 4: Does ABI in Generally Asymptomatic Adults Accurately Predict CAD Morbidity and Mortality Independent of FRS?

Cohort Study, Year | N Followup (years) | Mean age, years % Women | % Risk factor | Intermediate risk definition | NRI (95% CI) or CAD outcomes | NRI (95% CI) for CVD outcomes
ARIC Murphy, 2012^91,136^ | 11,594 14.0 | 53.8 56.4 | HTN: 33.4 DM: 0 Tobacco use: 25.7 | 10-y risk for CVD: 6%–19% | NR | [underlined: Total events]: NR [underlined: Hard events] All: 0.008 (p=0.50) Int: NR NRI-c^‡^ for hard CVD events, intermediate-risk subjects: -0.011
Health ABC^*^ Rodondi, 2010^47^ | 2,191 8.2 | 73.5 55.3 | HTN: 46.1 DM: 13.3 Tobacco use: 10.1 | 7.5-y risk for CAD: 7.5%–15% | [underlined: Total events] All: 0.033 (0.0004 to 0.065) Int: 0.07 (0.029 to 0.112) NRI-c^‡^ (95% CI) for total CAD events, intermediate-risk subjects: 0.038 (-0.029 to 0.105) [underlined: Hard events] All: 0.079 (NR) Int: 0.193 (NR) | NR
MESA^*,†^ Yeboah, 2012^48^ | 1,330 7.6 | 63.8 33.3 | HTN meds: 38.2 DM: 0 Tobacco use: 16.5 | 7.5-y risk for CAD: 2.0%–15.4% 7.5-y risk for CVD: 3.4%–21.1% | [underlined: Total events] All: NR Int: 0.036 (NR) [underlined: Hard events]: NR | [underlined: Total events] All: NR Int: 0.068 (NR) [underlined: Hard events]: NR
Rotterdam Kavousi, 2012^49^ | 5,933 6.8 | 69.1 59.4 | HTN meds: 23.5 DM: 12.9 Tobacco use: 17.5 | 10-y risk for CAD: 10%–20% | [underlined: Total events]: NR [underlined: Hard events] All: 0.006 (-0.018 to 0.029) Int: 0.073 (0.029 to 0.117) | NR

* Not included in the ABI Collaboration.

† MESA included only intermediate-risk individuals.

‡ NRI-c was calculated.

Abbreviations: ABC = Aging and Body Composition; ARIC = Atherosclerosis Risk in Communities; CAD = coronary artery disease; CVD = cardiovascular disease; DM = diabetes mellitus; HTN = hypertension; Int = intermediate; meds = medications; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; NRI = net reclassification improvement; NRI-c = corrected NRI.

### Detailed Findings for Risk Prediction of CAD

#### CAD Risk Reclassification of ABI, in Addition to FRS

The current ATP III algorithm focuses on 10-year hard CAD risk (as defined by CAD death or MI). Risk categories for hard CAD events (CAD death or MI) are defined as: low, which represents less than 10 percent 10-year CAD risk; intermediate, representing 10 to 20 percent risk; and high, representing greater than 20 percent risk. Previous FRS, however, used total CAD events (CAD death, MI, or angina). Generally the estimates for hard CAD are about two thirds to three fourths of those for total CAD. Therefore, the risk categories for total CAD events are defined as: low, representing less than 15 percent 10-year CAD risk; intermediate, representing 15 to 25 percent risk; and high, which represents greater than 25 percent risk (Table 5).42

The vast majority of evidence comes from the ABI Collaboration review, an individual patient-level meta-analysis of population-based cohorts in which participants had no history of CAD and baseline ABI and followup data on CAD outcomes (including MI, CAD, and overall death) were available. This meta-analysis included 16 population-based cohorts (n=48,294) from the United States, Western Europe, and Australia (Table 8). Most cohorts included 1,000 to 5,000 persons, although the largest study (ARIC) included over 14,000 persons. The mean age within the cohorts ranged from 47 to 78 years. Eleven cohorts included both men and women, four included only men (Belgian Physical Fitness Study, Health in Men Study, Honolulu Heart Program, and Men Born in 1914 Study), and one included only women (Women's Health and Aging Study). Most cohorts were predominantly white, with the exception of ARIC (about 25% black), the Honolulu Heart Study (100% Japanese American), San Luis Valley Diabetes Study (about 40% Latino), and the Strong Heart Study (100% Native American). The median duration of followup ranged from 3.0 to 16.7 years, with nine of the 16 studies having more than 10 years of followup data.

Table 8 Baseline Characteristics of ABI Collaboration Cohorts46

Cohort Study | Country | N | % Women | Mean Age, year | Group | FRS, % mean | ABI, mean
ARIC98 | US | 14,014 | 56.7 | 54 | Men | 12.8 | 1.17
ARIC98 | US | 14,014 | 56.7 | 54 | Women | 7.3 | 1.12
Belgian Physical Fitness103 | Belgium | 2,068 | 0 | 47 | Men | 11.0 | 1.21
Belgian Physical Fitness103 | Belgium | 2,068 | 0 | 47 | Women | NA | NA
Cardiovascular Health Study38 | US | 4,625 | 60.1 | 73 | Men | 25.4 | 1.10
Cardiovascular Health Study38 | US | 4,625 | 60.1 | 73 | Women | 8.0 | 1.06
Edinburgh Artery Study50 | Scotland | 1,392 | 50.4 | 64 | Men | 26.2 | 1.07
Edinburgh Artery Study50 | Scotland | 1,392 | 50.4 | 64 | Women | 11.5 | 1.01
Framingham Offspring137 | US | 3,126 | 54.5 | 58 | Men | 15.3 | 1.16
Framingham Offspring137 | US | 3,126 | 54.5 | 58 | Women | 7.5 | 1.10
Health in Men138 | Australia | 2,771 | 0 | 72 | Men | 29.4 | 1.07
Health in Men138 | Australia | 2,771 | 0 | 72 | Women | NA | NA
Honolulu Heart Program95 | US | 2,863 | 0 | 78 | Men | 31.6 | 1.05
Honolulu Heart Program95 | US | 2,863 | 0 | 78 | Women | NA | NA
Hoorn139 | The Netherlands | 554 | 51.3 | 63 | Men | 26.8 | 1.03
Hoorn139 | The Netherlands | 554 | 51.3 | 63 | Women | 14.5 | 1.02
InCHIANTI140 | Italy | 1,050 | 54.2 | 67 | Men | 24.8 | 1.04
InCHIANTI140 | Italy | 1,050 | 54.2 | 67 | Women | 8.0 | 1.05
Limburg PAOD107 | The Netherlands | 2,351 | 56.1 | 57 | Men | 20.2 | 1.08
Limburg PAOD107 | The Netherlands | 2,351 | 56.1 | 57 | Women | 11.7 | 1.07
Men Born in 1914 Study141 | Sweden | 391 | 0 | 69 | Men | 31.5 | 1.02
Men Born in 1914 Study141 | Sweden | 391 | 0 | 69 | Women | NA | NA
Rotterdam135 | The Netherlands | 5,649 | 62.2 | 69 | Men | 29.6 | 1.10
Rotterdam135 | The Netherlands | 5,649 | 62.2 | 69 | Women | 10.2 | 1.05
San Diego Study142 | US | 558 | 56.3 | 66 | Men | 21.6 | 1.08
San Diego Study142 | US | 558 | 56.3 | 66 | Women | 7.8 | 1.02
San Luis Valley Diabetes143 | US | 1,512 | 55.4 | 53 | Men | 15.6 | 1.16
San Luis Valley Diabetes143 | US | 1,512 | 55.4 | 53 | Women | 9.1 | 1.10
Strong Heart Study144 | US | 4,326 | 60.6 | 56 | Men | 15.5 | 1.15
Strong Heart Study144 | US | 4,326 | 60.6 | 56 | Women | 10.8 | 1.15
Women's Health and Aging145 | US | 689 | 100 | 78 | Men | NA | NA
Women's Health and Aging145 | US | 689 | 100 | 78 | Women | 7.1 | 1.05

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities; FRS = Framingham risk score; InCHIANTI = Invecchiare in Chianti (Aging in the Chianti Area); NA = not applicable; PAOD = Peripheral Arterial Occlusive Disease.

This study reports the reclassification from FRS categories when ABI was added for both men and women from the 13 (of the 16) cohorts that had relevant outcomes available. In these cohorts, 5.5 percent in the low-risk category, 6.2 percent in the intermediate-risk category, and 13.7 percent in the high-risk category had a low ABI (≤0.9) (Table 9). High ABI (>1.40) was much less common, with an overall rate of 2.7 percent (1,181/43,919). In most cohorts, women had a lower average ABI and a higher percent of low ABI in each FRS category.

Table 9 Prevalence of Low ABI (≤0.9) by FRS Categories in the ABI Collaboration Cohorts46

FRS Category | Men | Women | Both Sexes
Low (<10%) | 1.3% | 7.0% | 5.5%
Intermediate (10%–19%) | 3.3% | 10.0% | 6.2%
High (≥20%) | 13.7% | 14.1% | 13.7%

Abbreviation: FRS = Framingham risk score.

Using an ABI of 1.11 to 1.40 as normal (as opposed to the traditional 0.91 to 1.40), 19 percent of men and 36 percent of women were reclassified when ABI was added to the FRS (Table 6a). The ABI Collaboration investigators used this referent group (ABI of 1.11 to 1.40) because they found an inverse J-shaped relationship between ABI and mortality and CVD mortality, in which all ABI groups (<0.90, 0.91 to 1.10, and >1.40) had an elevated mortality risk compared with the lowest-risk group (1.11 to 1.40). For men, the greatest percent of reclassification was among those who were initially classified as high risk (23% over 10 years) with a normal ABI (1.11 to 1.40) and were subsequently reclassified as being at intermediate risk (18% over 10 years) (Table 6a). Women who were initially at low or intermediate risk (11% or 13% over 10 years, respectively) who had a low ABI (≤0.9) were subsequently reclassified as being at high risk (21% and 25% over 10 years, respectively) (Table 6a). If the normal range of ABI was defined as 0.91 to 1.40 (the more traditional definition), the proportion reclassified would appear larger for men (35%) and smaller for women (7.3%) (Table 6b). In this scenario, the greatest percent of reclassification remains the same; that is, among men at high risk with normal ABI and among women at low to intermediate risk with low ABI.

These results should be interpreted with caution, however, regardless of the range of ABI used as the referent category. First, the reclassification table only illustrates the movement of individuals across categories of risk, but does not comment on the appropriateness of the reclassification. This analysis was conducted before 2008 and, therefore, did not use more recent measures of risk reclassification, such as the NRI. Without the NRI or the ability to calculate the NRI based on the data presented, the true clinical meaning of this movement is not clear and it is difficult to compare the results with the other studies we included. Second, the ABI Collaboration reclassification table examines the risk of total CAD events (CAD death, MI, and angina); however, the risk categories they use are based on hard CAD events (CAD death and MI only). If the investigators applied a modified categorization of risk (Table 5), most change in risk would not result in actual risk reclassification. Third, changes in risk that do result in risk reclassification may represent small absolute changes of risk (for example, a change from 23% 10-year risk using FRS alone to 18% 10-year risk among men with a normal ABI). Therefore, the clinical significance (risk reclassification) is highly dependent on accepted definitions of risk strata as well as the precision around these estimates of 10-year risk. The true clinical impact of these changes is unclear without CIs around these changes in percentages of risk. The precision around these risk estimates depends on how many individuals contributed to the 10-year followup, the number of individuals in each risk category (for example, there were only 175 men at high risk by FRS with an ABI of >1.40), and the variability in event rates. While most cohorts had at least 10 years of followup data, authors presented no sensitivity analysis comparing cohorts with at least 10 years of followup data with cohorts with shorter followup data. Length of study followup (i.e., if <10 years) may be important if the risk for CAD events over the 10 years were not constant. From the results of the ABI Collaboration, we know that a normal or abnormal ABI can reclassify risk, but the clinical impact is still uncertain given these limitations. Finally, the risk reclassification is based on ATP III, which will be updated in early 2013.^92^ If the practice paradigm should shift to treatment at lower risk, the ABI may not add any value to FRS. Nonetheless, the data from the ABI Collaboration remain the largest body of evidence to date on the added value of ABI to the current approach for CAD risk prediction.

Three explanatory studies suggest that ABI can help reclassify individuals' 10-year CAD risk when added to the FRS (Table 10).47-49 One additional study, an analysis of EAS, reports the difference in AUC for fatal MI only (Table 10).50 Given this noncomparable outcome and that EAS is included in the ABI Collaboration, this study is not discussed in any detail. The first U.S.-based cohort, Health ABC, was one of two cohorts not included in the ABI Collaboration.47 In this good-quality study (n=2,191), participants were older (mean age, 73.5 years [range, 70 to 79 years]) and likely sicker, as evidenced by the fact that a high proportion of individuals had outcomes (Table 4 and Table 10). Participants were followed for a median of 8.2 years. In this cohort, CAD risk was based on either hard CAD events (MI or death from MI) or total CAD events (hard events plus hospitalization due to angina or coronary revascularization). For total CAD events, the NRI of adding ABI to FRS and diabetes was 0.033 (95% CI, 0.0004 to 0.065); among the intermediate-risk group, the NRI was 0.07 (95% CI, 0.029 to 0.112) (Table 10). Our calculated corrected NRI for the intermediate-risk group was 0.038 (95% CI, -0.029 to 0.105), however, which is similar to the overall NRI. For hard CAD events, the NRI was higher than for total events (Table 10). In the Health ABC cohort, 8.8 percent of participants were reclassified when the ABI was added to the FRS. This study appears to have used the same risk categories for both the total and hard CAD analyses.

Table 10 CAD Outcomes for KQ 4: Does ABI in Generally Asymptomatic Adults Accurately Predict CAD Morbidity and Mortality Independent of FRS?

Cohort Study, Year | N | Years Followup | % ABI <0.9 | Risk association HR or RR (95% CI) adjusted for FRS factors and other predictors^*^ | Risk reclassification in addition to FRS factors
ABI Collaboration Fowkes 2008^46^ | 48,294 | 10 | 7.7 Men: 7.4 Women: 8.1 | [underlined: HR^†^ (of major coronary events) for ABI 1.11–1.40]: Men: 2.16 (1.76 to 2.66) Women: 2.49 (1.84 to 3.36) ABI ≤0.90: reference | [underlined: Risk reclassification]: For men: 19% would change risk category; greatest effect of ABI is among those at high risk by FRS; a normal ABI would reclassify them to intermediate risk. For women: 36% would change risk category; greatest effect of ABI is among those at low or intermediate risk by FRS; an abnormal ABI would reclassify them to high risk. [underlined: AUC for major coronary events by predictors, among men]: FRS+DM: 0.646 FRS+DM+ABI: 0.655 [underlined: AUC for major coronary events by predictors, among women]: FRS+DM: 0.605 FRS+DM+ABI: 0.658
ARIC Weatherley 2007^94^ | 13,588 | 13.1 (median) | 2.8 | [underlined: HR^‡^ of CAD event (definite CAD death, definite or probable hospitalized MI, or unrecognized MI) per 0.10 decrease in ABI]: White men: 1.15 (1.08 to 1.24) White women: 1.11 (1.01 to 1.23) Black men: 1.25 (1.11 to 1.41) Black women: 1.20 (1.07 to 1.34) | NR
Edinburgh Artery Study Lee 2004^50^ | 1,507 | 12 | 16.3 | [underlined: RR^§^ of fatal and nonfatal MI for ABI ≤0.90:] 1.10 (0.78 to 1.54) ABI >0.90: reference | [underlined: AUC for fatal MI by predictors (p for significance of increase in predictive value)]: age + sex: 0.66 (p≤0.001) age + sex + DM + prevalent CVD: 0.74 (p≤0.001) age + sex + DM + prevalent CVD + FRS predictors: 0.77 (p≤0.001) age + sex + DM + prevalent CVD + FRS predictors + ABI: 0.78 (p≤0.01)
Health ABC Rodondi 2010^47^ | 2,191 | 8.2 (median) | NR | [underlined: HR^†^ (of total CAD events: nonfatal MI, coronary death, angina or revascularization)]: ABI ≤0.9: 1.57 (1.14 to 2.18) ABI 0.91–1.00: 1.05 (0.73 to 1.49) ABI 1.01–1.30: reference ABI 1.31–1.40: 1.29 (0.75 to 2.23) ABI >1.4: 2.89 (1.47 to 5.68) | [underlined: NRI (95% CI) for total CAD events]: all subjects: 0.033 (0.0004 to 0.065) intermediate-risk subjects: 0.07 (0.029 to 0.112) NRI-c^‡‡^ (95% CI) for total CAD events, intermediate-risk subjects: 0.038 (-0.029 to 0.105) [underlined: NRI (95% CI) for hard CAD events]: all subjects: 0.079 (NR) intermediate-risk subjects: 0.193 (NR) [underlined: AUC for total CAD events by predictors]: FRS+DM: 0.631 FRS+DM+ABI: 0.650
Health ABC Sutton-Tyrrell 2008^93^ | 2,886 | 6.7 (mean) | 13.3 | [underlined: RR║ (of total CAD events: coronary death, hospitalization for acute MI or angina)]: ABI ≤0.9: 1.41 (1.11 to 1.81) ABI 0.91–1.3: reference ABI ≥1.3: 1.50 (1.01 to 2.23) NC: 1.65 (1.02 to 2.68) [underlined: RR║ (CHF events)]: ABI ≤0.9: 1.51 (1.12 to 2.02) ABI 0.91–1.3: reference ABI ≥1.3: 1.03 (0.54 to 1.97) NC: 2.40 (1.40 to 4.10) | NR
Honolulu Heart Program Abbott 2000^95^ | 2,863 | 3–6 | NR <0.8: 6.3 | [underlined: RR^¶^ (of nonfatal MI, death from CAD, or sudden death)]: ABI <0.8: 2.7 (1.6 to 4.5) ABI 0.8 to <1.0: 1.3 (0.9 to 1.9) ABI ≥1.0: reference | NA
MESA Yeboah 2012^48^ | 1,330 | 7.6 (median) | NR 1.14, median | [underlined: HR^#^ (95% CI) for CAD events (MI, CAD death, resuscitated cardiac arrest, angina with revascularization) with 1 SD change in ABI]: ABI and other predictors: 0.79 (0.66 to 0.95); p=0.01 | [underlined: For incident CAD]: NRI for FRS+ABI, intermediate-risk subjects: 0.036 AUC for FRS alone: 0.623 AUC for FRS+ABI: 0.650
Rotterdam Kavousi 2012^49^ | 5,933 | 6.8 (median) | NR | [underlined: HR^**^ (of nonfatal MI, fatal MI, or fatal CAD)]: ABI ≤0.9, overall: 1.3 (1.0 to 1.7) Men: 1.6 (1.1 to 2.2) Women: 1.1 (0.7 to 1.6) ABI 0.91–1.4: reference | [underlined: NRI (95% CI) for all subjects]: Overall: 0.006 (-0.018 to 0.029) Men: -0.016 (-0.065 to 0.033) Women: -0.009 ( -0.027 to 0.010) [underlined: NRI (95% CI) for intermediate-risk subjects]: Overall: 0.073 (0.029 to 0.117) Men: 0.065 (-0.011 to 0.141) Women: -0.012 ( -0.042 to 0.017) [underlined: AUC (95% CI) for nonfatal MI, fatal MI, or fatal CAD with FRS predictors]: 0.73 (0.71 to 0.75) [underlined: Change in AUC (95% CI) adding PAD as a predictor]: Overall: 0.00 (0.00 to 0.00) Men: 0.01 (0.00 to 0.01) Women: 0.00 (0.00 to 0.00)
Rotterdam van der Meer 2004^135^ | 6,389 | 9 (estimated) | NR | [underlined: HR^††^ (of fatal or nonfatal incident MI)]: ABI <0.97: 1.59 (1.05 to 2.39) ABI 0.97–1.10: 1.55 (1.04 to 2.31) ABI 1.10–1.21: 1.12 (0.74 to 1.70) ABI >1.21: reference | NA

* HR or RR adjusted for age, sex, systolic blood pressure, total cholesterol level, high-density lipoprotein cholesterol level, and current smoking, at minimum.

† Also adjusted for diabetes.

‡ Also adjusted for center, low-density lipoprotein cholesterol, and diabetes.

§ Also adjusted for diabetes and prevalent CAD.

║ Also adjusted for race, site, prevalent CVD, diabetes, body mass index, physical activity, and triglycerides.

¶ Also adjusted for diabetes, alcohol intake, fibrinogen, body mass index, distance walked per day, and past smoking.

# Also adjusted for race/ethnicity, body mass index, blood pressure medication use, and statin use.

** Also adjusted for treatment of hypertension and diabetes.

†† Also adjusted for diabetes, diastolic blood pressure, body mass index, use of aspirin, and antihypertension and cholesterol-lowering medications.

‡‡ NRI-c was calculated.

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities; AUC = area under the curve; CAD = coronary artery disease; CHF = congestive heart failure; CI = confidence interval; CVD = cardiovascular disease; DM = diabetes mellitus; FRS = Framingham risk score; HR = hazard ratio; MESA = Multi-Ethnic Study of Atherosclerosis; MI = myocardial infarction; NA = not applicable; NC = noncompressible arteries; NR = not reported; NRI = net reclassification improvement; NRI-c = corrected NRI; PAD = peripheral artery disease; RR = relative risk; SD = standard deviation.

The second U.S.-based cohort, MESA, was the other cohort not included in the ABI Collaboration.48 This fair-quality analysis focused on a subsample (n=1,330 of 6,814) of MESA participants who were at intermediate risk for incident CAD based on the FRS. The authors defined incident CAD as MI, death from CAD, resuscitated cardiac arrest, or angina (definite or probable followed by revascularization). The authors defined intermediate risk as estimated 10-year CAD risk of greater than 5 to less than 20 percent, as opposed to the traditional 10 to 19 percent risk for hard CAD or 15 to 25 percent risk for total CAD. Participants were younger (mean age, 63.8 years) than those in Health ABC (mean age, 73.5 years) (Table 4). Only 33 percent of participants were women and 36 percent were white. Participants were followed for a median of 7.6 years. As a result, CAD risk was redefined based on 7.5-year risk (e.g., intermediate risk of 2.0% to 15.4%). For incident CAD, the NRI was 0.036 among intermediate-risk participants. This is slightly lower than the NRI seen in Health ABC, although within its 95 percent CI. We were unable to calculate a corrected NRI for the MESA cohort, since the full reclassification table was not presented.

The third cohort, the Rotterdam study from the Netherlands, was included in the ABI Collaboration.49 This good-quality study (n=5,933) included slightly younger (mean age, 69 years) and apparently healthier participants, with a lower rate of CAD events than the Health ABC cohort (Table 4 and Table 10). Approximately 60 percent of participants were women, and presumably most were white Dutch. Participants had a median of 6.8 years followup. CAD risk was based on hard CAD events (CAD death or MI). This study used an ABI of 0.91 to 1.40 as the referent group. The NRI for all participants was not statistically significant (0.006 [95% CI, -0.018 to 0.029]) when ABI was added to the FRS. The NRI was higher for participants at intermediate risk (0.073 [95% CI, 0.029 to 0.117]) (Table 10). Again, we were unable to calculate a corrected NRI for the intermediate-risk group due to limited data published. While men had greater changes than women, neither sex had statistically significant changes.

In general, these three cohorts showed a small or nonsignificant NRI for the ABI in addition to the FRS alone. One of these cohorts was included in the ABI Collaboration. These explanatory models refit a regression model with all of the FRS factors (and other risk factors) to determine whether ABI can improve upon the existing prognostic model. In the case of oversimplified regressions (which assume that factors have simple linear relations and no interactions), the incremental prognostic value estimated may be higher than in actual practice. We had difficulty making comparisons between studies because of differences in populations (e.g., age, sex, race/ethnicity), choice of referent group (i.e., definition of normal ABI), definitions of composite CAD outcomes (i.e., hard vs. incident vs. total CAD) and risk categories (e.g., intermediate risk of 10% to 19%, 15% to 25%, or 5% to 20%), and measures of reclassification (i.e., number reclassified vs. NRI).

#### Risk Association of CAD and ABI, Independent of FRS

In addition to, and sometimes as a precursor to, demonstrating risk reclassification, the included studies also report the association of ABI and future CAD events after adjusting for (at least) the FRS factors (Table 10). The ABI Collaboration showed a significant increase for major CAD events for an ABI of 0.90 or less (compared with an ABI of 1.11 to 1.40) after adjusting for FRS factors (HR, 2.16 [95% CI, 1.76 to 2.66] for men and HR, 2.49 [95% CI, 1.84 to 3.36] for women). Adjusted results were not given for an ABI of >1.40. Unadjusted HRs for a high ABI, however, were not statistically significant for major CAD events. After adjusting for FRS factors, the Health ABC, MESA, and Rotterdam cohorts all suggest an independent association of low ABI with CAD events. These results are not consistently reported for high ABI values. Among the Health ABC cohort, the adjusted HR was 1.57 (95% CI, 1.14 to 2.18) for an ABI of 0.9 or less and 2.89 (95% CI, 1.47 to 5.58) for an ABI greater than 1.40 (compared with an ABI of 1.01 to 1.30).47 In another report from the Health ABC cohort, the adjusted RR was 1.41 (95% CI, 1.11 to 1.81) for an ABI of 0.9 or less and 1.50 (95% CI, 1.01 to 2.23) for an ABI greater than 1.40 (compared with an ABI of 0.91 to 1.30).93 In the MESA cohort, the adjusted HR for ABI was 0.79 (95% CI, 0.66 to 0.95) per one standard deviation change in ABI.48 While there was a trend of an association of ABI with CAD events in the Rotterdam cohort, the adjusted HR was not statistically significant (1.3 [95% CI, 1.0 to 1.7]) for an ABI of 0.9 or less (compared with an ABI of 0.91 to 1.40).49 While the Rotterdam cohort included subjects with history of CVA, the MESA and Health ABC cohorts did not. Neither of these reports from the MESA or Rotterdam cohorts report HR for an ABI of greater than 1.30 or 1.40.

Three other included studies reported the independent HR or RR for CAD outcomes by ABI, after adjusting for FRS factors. These studies, however, did not present risk reclassification data.50,94,95 The largest cohort study, ARIC (n=13,588), was conducted in the United States.94 This good-quality study included participants ages 45 to 64 years (mean age, 54 years), about half of whom were women and a quarter of whom were black (Table 4). This study showed that ABI was consistently associated with future CAD events, after adjusting for FRS factors. HRs ranged from 1.11 to 1.25 for each 0.10 decrease in ABI measurement (Table 10). One cohort, EAS (n=1,507), included patients in Scotland ages 55 to 74 years (mean age, 65 years). Approximately half of participants were women, and presumably most patients were white British. This fair-quality study showed no statistically significant difference in relative risk at 12-years followup for fatal or nonfatal MI among participants with an ABI of 0.9 or less versus participants with an ABI of greater than 0.9 (RR, 1.10 [95% CI, 0.78 to 1.54]).50 Unlike other analyses, this analysis used RR at 12 years, rather than HR over time. The RR does not account for differences in earlier events, so there may be no significant differences in event rates by year 12 even, though HRs might be statistically significantly different. Finally, the Honolulu Heart Study (n=2,863) was conducted among older men (ages 71 to 93 years) of Japanese descent.95 This study had much shorter followup (3 to 6 years) than other cohorts and found that an ABI of less than 0.8 was independently associated with CAD compared with an ABI of 1.0 or more, after adjusting for FRS factors (RR, 2.7 [95% CI, 1.6 to 4.5]).

While these studies included differences in populations and choice of ABI categories and referent groups, they collectively show that a low ABI (≤0.9) is generally independently associated with future CAD risk after adjusting for FRS factors across large age groups, among men and women, and in blacks, whites, and Asians.

### Detailed Findings for Risk Prediction of Overall CVD Risk

#### CVD Risk Reclassification of ABI, in Addition to FRS

While the current ATP III algorithm focuses on 10-year CAD risk, the field is moving toward global CVD risk prediction. This risk prediction generally includes morbidity and mortality from cerebrovascular disease and PAD (in some cases). Three of our included studies reported CVD risk reclassification (NRI) or discrimination (AUC) with ABI using an explanatory model.48,91,96 The largest single cohort, ARIC (n=11,594), included participants ages 45 to 64 years (mean age, 54 years), nearly half of whom were men and about a quarter were black (Table 4). This good-quality study, conducted in the United States, showed no statistically significant reclassification based on NRI and AUC for hard CVD events (CVD death, MI, or CVA) (Table 11).91 The EAS (n=1,507), conducted in Scotland, included patients ages 55 to 74 years (mean age, 65 years) (Table 4).96 In this cohort, the AUC for MI or CVA was statistically significantly higher (p=0.02) for FRS plus ABI (AUC, 0.64 [95% CI, 0.59 to 0.69]) compared with FRS alone (AUC, 0.61 [95% CI, 0.56 to 0.67]) (Table 11). The third study, conducted in the United States, presented risk reclassification among a subsample of intermediate-risk participants from the MESA cohort (n=1,330).48 This subsample included participants with a mean age of 63.8 years, about one third of whom were women and one third were white (Table 4). Incident CVD in this study included incident CAD (see description in above section) and CVA or CVD death. This fair-quality study showed an NRI of 0.068 for incident CVD with ABI in addition to FRS among intermediate-risk participants, and a higher AUC (0.650 [95% CI not reported]) versus the FRS alone (0.623 [95% CI not reported]) (Table 11). We were unable to calculate a bias-corrected NRI for these intermediate-risk persons due to limitations in the reported data.

Table 11 CVD Outcomes for KQ 4: Does ABI in Generally Asymptomatic Adults Accurately Predict CVD Morbidity and Mortality Independent of FRS?

Cohort Study, Year | N | Years Followup | % ABI <0.9 | Risk association HR, RR, or OR (95% CI) adjusted for FRS factors and other predictors^*^ | Risk Reclassification in addition to Framingham risk factors
ABI Collaboration Fowkes 2008^46^ | 48,294 | 10 | 7.7 Men: 7.4 Women: 8.1 | [underlined: HR^†^ (of death due to CAD or CVA) for ABI 1.11–1.40]: Among men: 2.92 (2.31 to 3.70) Among women: 2.97 (2.02 to 4.35) ABI ≤0.90: reference
ARIC Murphy 2012^91^ | 11,594 | 14 (med) 16 (max) 10 (for analysis) | 2.3 | [underlined: HR^‡^ (of hard CVD events: MI, cardiovascular death, or CVA) per standard deviation in ABI]: 0.849 (0.79 to 0.91) ABI, 1 SD: reference | [underlined: NRI for hard CVD events]: All subjects: 0.008; p=0.50 Intermediate-risk subjects: 0.06; p=NR NRI-c^††^ for hard CVD events, intermediate-risk subjects: -0.011 [underlined: AUC for hard CVD events]: Model FRS: 0.756 (0.739 to 0.773) Model FRS + ABI: 0.758 (0.741 to 0.775) p=0.23
Cardiovascular Health Study O'Hare 2006^38^ | 5,748 | 9.6 (for CV events) 11.1 (for CVD mortality) | 13.8 | [underlined: HR^§^ (of CV events: MI, CVA, angina, angioplasty, CABG, or lower-extremity amputation/revascularization)]: ABI ≤0.60: 1.60 (1.09 to 2.34) ABI 0.61–0.70: 1.57 (1.07 to 2.20) ABI 0.71–0.8: 1.63 (1.16 to 2.28) ABI 0.81–0.9: 1.72 (1.35 to 2.20) ABI 0.91–1.0: 1.37 (1.13 to 1.64) ABI 1.01–1.10: 1.08 (0.93 to 1.25) ABI 1.11–1.20: reference ABI 1.21–1.30: 0.90 (0.74 to 1.10) ABI 1.31–1.40: 0.97 (0.68 to 1.40) ABI >1.40: 1.00 (0.57 to 1.74) [underlined: HR (of CVD mortality)]: ABI ≤0.60: 2.13 (1.49 to 3.05) ABI 0.61–0.70: 2.31 (1.56 to 3.42) ABI 0.71–0.8: 2.01 (1.43 to 2.81) ABI 0.81–0.9: 2.37 (1.77 to 3.16) ABI 0.91–1.0: 1.60 (1.25 to 2.05) ABI 1.01–1.10: 1.05 (0.85 to 1.30) ABI 1.11–1.20: reference ABI 1.21–1.30: 0.95 (0.71 to 1.26) ABI 1.31–1.40: 1.33 (0.83 to 2.13) ABI >1.40: 1.76 (0.97 to 3.18) | NR
Edinburgh Artery Study Lee 2004^50^ | 1,507 | 12 | 16.3 | [underlined: RR║ (of nonfatal MI or CVA and CVD mortality)]: ABI ≤0.90: 1.06 (0.81 to 1.39) ABI >0.90: reference
Edinburgh Artery Study Price 2007^96^ | 1,007 | 12 | 18.7 | [underlined: OR^†^ (of MI or CVA)]: ABI ≤0.9: 1.70 (1.07 to 2.70) ABI >0.9: reference | [underlined: AUC (95% CI) for MI or CVA by predictors]: FRS + DM: 0.61 (0.56 to 0.67) FRS + DM + ABI: 0.64 (0.59 to 0.69) (p for difference= 0.02)
Health ABC Sutton-Tyrrell 2008^93^ | 2,886 | 6.7 (mean) | 13.3 | [underlined: RR^¶^ (of cardiovascular mortality: death due to atherosclerotic CVD or CVA)]: ABI ≤0.9: 2.18 (1.57 to 3.02) ABI 0.91–1.3: reference ABI ≥1.3: 1.32 (0.66 to 2.63) NC: 2.62 (1.39 to 0.92)
Hoorn Hanssen 2012^97^ | 624 (469 without DM) | 17.2 | 10.4 | [underlined: RR^#^ (95% CI) of CVD mortality (in persons without DM)]: ABI <0.9: 1.95 (0.88 to 4.33)
MESA Yeboah 2012^48^ | 1,330 | 7.6 (med) | NR 1.14 (med) | [underlined: HR^**^ (95% CI) of CVD events (CAD death, MI resuscitated cardiac arrest, angina with revascularization, CVA, or CVD death) with 1 SD change in ABI]: ABI and other predictors: 0.81 (0.68 to 0.95) p=0.012 | [underlined: For incident CVD]: NRI for FRS + ABI: 0.068 AUC for FRS alone: 0.623 (95% CI, NR) AUC for FRS + ABI: 0.650 (95% CI, NR)

* HR, RR, or OR adjusted for age, sex, systolic blood pressure, total cholesterol level, high-density lipoprotein cholesterol level, and current smoking, at minimum.

† Also adjusted for diabetes.

‡ Also adjusted for race and low-density lipoprotein cholesterol.

§ Also adjusted for race, diabetes, prevalent CVD (CAD, CVA, CHF), low-density lipoprotein, triglycerides, diastolic blood pressure, antihypertension medications, creatinine, body mass index, and C-reactive protein.

║ Also adjusted for diabetes and prevalent CAD.

¶ Also adjusted for race, site, prevalent CVD, diabetes, body mass index, physical activity, and triglycerides.

# Also adjusted for triglycerides, albuminuria, estimated glomerular filtration rate, waist circumference, history of CVD, and impaired glucose metabolism.

** Also adjusted for race/ethnicity, body mass index, blood pressure medication use, and statin use.

†† NRI and corrected NRI for intermediate-risk group were calculated.

Abbreviations: ABC = Aging and Body Composition; ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities; AUC = area under the curve; CABG = coronary artery bypass graft; CAD = coronary heart disease; CHF = congestive heart failure; CI = confidence interval; CV = cardiovascular; CVA = cerebrovascular accident; CVD = cardiovascular disease; DM = diabetes mellitus; FRS = Framingham risk score; HR = hazard ratio; max = maximum; med = median; MESA = Multi-Ethnic Study of Atherosclerosis; MI = myocardial infarction; NC = noncompressible arteries; NR = not reported; NRI = net reclassification improvement; NRI-c = corrected NRI; OR = odds ratio; PAD = peripheral artery disease; RR = relative risk; SD = standard deviation.

Generally, there are fewer data available about whether ABI can reclassify CVD than CAD risk. This result is not surprising, however, as the FRS was developed to predict CAD risk. Limited data suggest that ABI can reclassify CVD risk in addition to FRS, but not necessarily in adults younger than age 65 years. Comparisons across studies, however, are complicated by differences in populations, definitions of CVD composite outcomes, and definitions of risk categories.

#### Risk Association of CVD and ABI, Independent of FRS

The majority of studies do not address risk reclassification of CVD events. Instead, these studies focus on the independent risk association of ABI and future CVD events adjusting for (at least) the FRS factors (Table 11).46 The ABI Collaboration showed a significant increase between total CVD mortality (from CAD or CVA) and an ABI of 0.90 or less relative to an ABI of 1.11 to 1.40 after adjusting for FRS factors (HR, 2.92 [95% CI, 2.31 to 3.70] for men and HR, 2.97 [95% CI, 2.02 to 4.35] for women) (Table 11).46 While adjusted HRs are not given for an ABI of greater than 1.40, unadjusted HRs for a high ABI are not statistically significant for CVD mortality. Seven other included studies from six cohorts report the independent association of ABI and total CVD outcomes after accounting for FRS factors.38,48,50,91,93,96,97 Only two of these studies represent cohorts not included in the ABI Collaboration meta-analysis.48,93 The largest single cohort, ARIC (n=11,594), included participants ages 45 to 64 years (mean age, 54 years), nearly half of whom were men and about a quarter were black (Table 4). This good-quality study, conducted in the United States, showed a significant association per standard deviation in ABI, after adjustment for FRS (HR, 0.849 [95% CI, 0.79 to 0.91]) for hard CVD events (CVD death, MI, or CVA) (Table 11).91 The CHS cohort (n=5,748) is an older population (age 65 years or older [mean age, 73 years]) from the United States (Table 4).38 In this cohort, with about 10 years followup, HRs for a low ABI (≤0.9) were consistently and statistically significantly greater than those of the referent group (1.11 to 1.20) for combined CVD events (MI, CVA, angina, coronary or lower-extremity revascularization, or amputation) and CVD mortality, after adjusting for FRS factors (Table 11). HRs were not statistically significant for a high ABI (>1.30 or 1.40) for combined CVD events or CVD mortality. The EAS (n=1,507), conducted in Scotland, included patients ages 55 to 74 years (mean age, 65 years) (Table 4). With 12 years followup, this fair-quality study showed no statistically significant difference in relative risk for an ABI of 0.9 or less (vs. >0.9) and any CVD event (CVD death, MI, CVA) or CVD mortality (Table 11).50 In another report from EAS, the OR for an ABI of 0.9 or less (compared with an ABI of >0.9) for MI or CVA was 1.70 (95% CI, 1.07 to2.70) at 12 years followup, after adjusting for FRS factors.96 The Health ABC cohort (n=2,886), not represented in the ABI Collaboration meta-analysis, was a cohort of older adults in the United States (mean age, 74 years) (Table 4).93 Over a mean followup of 6.7 years, low ABI (≤0.9) was associated with CVD death (RR, 2.18 [95% CI, 1.57 to 3.02]) compared with an ABI of 0.91 to 1.31, after adjusting for FRS factors (Table 11). The Hoorn study (n=624) was a fair-quality cohort study conducted in the Netherlands in adults ages 50 to 75 years that had similar findings. Over a median of 17.2 years of followup, this study found that a low ABI (<0.9) was associated with a nonsignificant trend for future CVD death in those without diabetes mellitus (n=469; RR, 1.95 [95% CI, 0.88 to4.33]).97 The final study, also not included in the ABI Collaboration meta-analysis, used a subsample from the MESA cohort (n=1,330), representing a diverse group of participants at intermediate risk of CAD events.48 This study also demonstrated a statistically significant association for ABI with incident CVD (HR per standard deviation change in ABI, 0.81 [95% CI, 0.68 to 0.95]).

These explanatory studies examining the risk association of ABI and future CVD events vary widely in the populations studied, length of followup, definition of CVD composite outcomes, and choice of ABI referent groups. Collectively, however, these studies show that a low ABI is generally independently associated with future CVD events and/or CVD mortality across large range of participants, after adjusting for numerous predictors, including the FRS factors.

### Detailed Findings for Risk Prediction of CVA Alone

#### Risk Association of CVA and ABI, Independent of FRS

Four studies report on cerebrovascular outcomes separately from composite CVD outcomes (Table 12).50,93,98,99 The largest cohort, ARIC (n=14,306), included participants ages 45 to 64 years, nearly half of whom were men and about a quarter were black (Table 4). This good-quality study, conducted in the United States, found no statistically significant association between ischemic CVA and low ABI after adjusting for FRS factors (Table 12).98 Overall, however, the proportion of patients who had a CVA was low (1.4% [206/14,306]). One cohort from Scotland, EAS (n=1,507), included slightly older patients (ages 55 to 74 years) (Table 4). This study also found a statistically nonsignificant association of low ABI and CVA after adjusting for FRS factors, even though the proportion having a CVA was much higher (8.5% [128/1,507]).50 Two smaller U.S.-based cohorts (Health ABC93 [n=2,886] and the Honolulu Heart Study99 [n=2,767]) were conducted in older adults (age 70 years or older) who had higher prevalence of hypertension (about 50%) and diabetes (14.6% and 27%). These two studies found statistically significant associations between low ABI and CVA after adjusting for FRS factors (Table 4 and Table 12), but not high ABI (>1.30).93,99

Table 12 CVA (Alone) Outcomes for KQ 4: Does ABI in Generally Asymptomatic Adults Accurately Predict CVA Independent of FRS?

Cohort Study, Year | N | Years Followup | % ABI <0.9 | Risk association HR or RR (95% CI) adjusted for FRS factors and other predictors^*^ | Risk reclassification in addition to FRS factors
ARIC Tsai 2001^98^ | 14,306 | 7.2 (median) | 2.9 | [underlined: HR^†^ (of nonhemorrhagic CVA)]: ABI ≤0.80: 1.93 (0.78 to 4.78) ABI 0.81–0.90: 1.45 (0.56 to 3.76) ABI 0.91–1.00: 1.23 (0.67 to 2.26) ABI 1.01–1.10: 1.46 (0.94 to 2.25) ABI 1.11–1.20: 1.18 (0.77 to 1.79) ABI ≥1.20: reference | NR
Edinburgh Artery Study Lee 2004^50^ | 1,507 | 12 | 16.3 | [underlined: RR^‡^ (of nonfatal CVA)]: ABI ≤0.90: 1.29 (0.77 to 2.19) ABI >0.90: reference [underlined: RR^‡^ (of fatal and nonfatal CVA)]: ABI ≤0.90: 1.05 (0.67 to 1.65) ABI >0.90: reference | NR
Health ABC Sutton-Tyrrell 2008^93^ | 2,886 | 6.7 | 13.3 | [underlined: RR^§^ (of all CVA)]: ABI ≤0.9: 1.67 (1.13 to 2.45) ABI 0.91–1.3: reference ABI ≥1.3: 0.78 (0.31 to 1.93) NC: 2.09 (1.00 to 4.37) | NR
Honolulu Heart Program Abbott 2001^99^ | 2,767 | 3 to 6 | 11.6 | [underlined: HR║ (of all CVA)]: ABI <0.9: 2.0 (1.1 to 3.5) ABI ≥0.9: reference [underlined: HR║ (of thromboembolic CVA)]: ABI <0.9: 1.9 (1.0 to 3.7) ABI ≥0.9: reference [underlined: HR║ (hemorrhagic CVA)]: ABI <0.9: 3.3 (1.2 to 9.4) ABI ≥0.9: reference | NR

* HR or RR adjusted for age, sex, systolic blood pressure, total cholesterol level, high-density lipoprotein cholesterol level, and current smoking, at minimum.

† Also adjusted for diabetes, prevalent CAD, low-density lipoprotein cholesterol, antihypertension medication, and pack-years smoking.

‡ Also adjusted for diabetes and prevalent CAD.

§ Also adjusted for race, site, diabetes, prevalent CVD, body mass index, physical activity, and triglycerides.

║ Also adjusted for diabetes, fibrinogen, distance walked per day, and atrial fibrillation.

Abbreviations: ABC = Aging and Body Composition; ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities Study; CAD = coronary artery disease; CI = confidence interval; CVA = cerebrovascular accident; FRS = Framingham risk score; HR = hazard ratio; NC = noncompressible arteries; NR = not reported; RR = relative risk.

While there are some differences between how studies were conducted (e.g., length of followup), the ABI category used as the referent group, and the definition of CVA (hemorrhagic vs. ischemic), the differences in population characteristics likely explain differences in findings.

### Differences in Risk Prediction by Age, Sex, and Race/Ethnicity

The prevalence of low ABI increases with age.12 While differences in how studies were conducted and other population characteristics prevent us from arriving at definitive conclusions, the independent value of ABI (after adjusting for FRS) appears to be less robust for predicting future CAD, CVA, and total CVD outcome events among persons ages 45 to 64 years than among older persons, based on a single large cohort (ARIC).91,94,98

The distribution and prevalence of low ABI also appears to differ between men and women. Although this relationship is not consistent across cohorts, it appears that women have a lower mean ABI than men (Table 8). Few included studies provide direct comparison of risk reclassification or risks of ABI for CAD events between men and women. In the ABI Collaboration, women with low or intermediate risk of CAD events based on FRS factors had higher prevalence of low ABI than men with low or intermediate risk (Table 9), with greater risk reclassification for women than men.46 In the Rotterdam cohort (n=5,933), however, reclassification was higher for men than women, although the sex-specific NRIs were not statistically significant.49 In both the ARIC and Rotterdam cohorts, men had slightly higher adjusted HRs for low ABI and future CAD events than women.49,94

There is little direct evidence addressing these differences by race/ethnicity. The largest cohort, ARIC, was conducted in the United States and included about 25 percent blacks. This cohort had slightly higher adjusted HRs for low ABI and future CAD events than whites.94 The MESA cohort included a diverse sample of participants, but did not report ethnic-specific results for reclassification.48 The Honolulu Heart Study was conducted entirely in older (older than age 70 years) men of Japanese ancestry.95,99 In this cohort, low ABI was consistently associated with future CAD and CVA events after adjusting for traditional FRS factors. The Strong Heart Study (included in the ABI Collaboration analyses) was a cohort of Native American men and women, with a mean age of 56 years. The unadjusted HR for total mortality with ABI (compared with an ABI of 1.11 to 1.40) was not statistically significant for men or women.

## KQ 5 Does the Treatment of Generally Asymptomatic Persons With PAD Lead to Improved Patient Outcomes Beyond the Benefit of Treatment in Symptomatic Adults or Adults With Known CVD Risk Factors?

We found only two trials that examined the benefit of treatment in asymptomatic persons with low ABI or PAD (Table 13). We included trials in which the majority of patients either had no symptoms or no typical symptoms (i.e., no intermittent claudication). We excluded seven trials for quality and 77 studies because the majority of patients had intermittent claudication. No trials examined the benefit of earlier (asymptomatic) versus later (symptomatic) treatment of PAD. Included trials examined very different interventions and, as such, we discuss these trials separately.

Table 13 Study Characteristics for KQs 5 and 6: What Are the Benefits and Harms of Treatment of Generally Asymptomatic Adults With PAD?

Study, Year | USPSTF Quality | N | Mean Age, years | % Female | Mean ABI | Mean SBP, mm Hg | Mean total cholesterol, mg/dL | % Current smokers | Description of Intervention
Fowkes 2010^100^ | Good | 3,350 | 62.0 | 71.5 | 0.86 | 147.5 | 238.5 | 32.5 | IG: Enteric-coated aspirin 100 mg daily CG: Placebo daily
McDermott 2011^101^ | Fair | 335 | 70.5 | 40.6 | 0.68 | NR | 183.5 | 25.4 | IG1: 8 phone calls (25 minutes each) for 6 weeks focused on behavioral counseling to improve lipid control CG1: Attention control (education only) CG2: Usual care (no phone calls)

Abbreviations: ABI = ankle-brachial index; CG = control group; IG = intervention group; SBP = systolic blood pressure; USPSTF = U.S. Preventive Services Task Force.

The Aspirin for Asymptomatic Atherosclerosis (AAA) trial was a large, good-quality RCT (n=3,350) designed to determine whether persons in the general population with low ABI detected by screening would benefit from aspirin therapy (100 mg/day) (Table 13).100 This trial was conducted in Scotland and included adults ages 50 to 75 years without known CVD who had a screening ABI of 0.95 or less. Of 28,980 persons screened, only 1.7 percent (4,914) had an ABI of 0.95 or less. This population's mean ABI was 0.86. Among these patients, the mean age was 62 years, 71.5 percent of participants were women, mean systolic blood pressure was about 148 mm Hg, mean total cholesterol was about 239 mg/dL, and about a third were current smokers. After a mean followup of 8.2 years, there was no significant difference in CVD events (MI, CVA, or revascularization) between those who received aspirin versus placebo (HR, 1.03 [95% CI, 0.84 to 1.27]) (Table 14) and no difference in CVD events for the subgroup with an ABI of 0.9 or less (HR, 1.02 [95% CI, 0.80 to 1.29]). There were no significant differences in secondary outcomes (CVD events plus angina, intermittent claudication, or transient ischemic attack) or all-cause mortality. At 5 years, there was only about 15 percent crossover (e.g., persons taking aspirin outside of the trial by prescription or self-prescription). Authors also reported results per protocol, which showed no differences in outcomes between those actually taking aspirin versus those not taking aspirin. Although this was a well-conducted trial, it was powered to identify a 25 percent reduction in the primary outcome. As such, they might not have been able to identify smaller benefits. Additionally, the population was a relatively well community-derived sample that may not be fully representative of a clinic-based population.

Table 14 Study Outcomes for KQs 5 and 6: What Are the Benefits and Harms of Treatment of Generally Asymptomatic Adults With PAD?

Study, Year | Primary outcome | IG | CG | IG vs. CG | Secondary outcome | IG | CG | IG vs. CG | Harms | IG | CG | IG vs. CG
Fowkes 2010^100^ | Initial MI, CVA or revascularization | Events/1000 py (95% CI): 13.7 (11.8 to 15.9) | Events/1000 py (95% CI): 13.3 (11.4 to 15.4) | HR (95% CI): 1.03 (0.84 to 1.27) | All initial vascular events | Events/1000 py (95% CI): 22.8 (20.2 to 25.6) | Events/1000 py (95% CI): 22.9 (20.3 to 25.7) | HR (95% CI): 1.00 (0.85 to 1.17) | Major bleeding requiring hospital admission | Events/1000 py (95% CI): 2.5 (1.7 to 3.5) | Events/1000 py (95% CI): 1.5 (0.9 to 2.3) | HR (95% CI): 1.71 (0.99 to 2.97)
McDermott 2011^101^ | 12-month change in LDL, adjusted for baseline LDL | mg/dL (95% CI): -18.4 (-24.8 to -12.1) | mg/dL (95% CI): CG1: -6.8 (-13.0 to -0.5) CG2: -11.1 (-17.0 to -5.1) | 3-way ANOVA: p=0.035 IG vs. CG1: p=0.010 IG vs. CG2: p=0.208 | 12 month proportion of participants with LDL <100 mg/dL | % (95% CI): 21.6 (11.5 to 31.8) | % (95% CI): CG1: 9.0 (-3.2 to 21.2) CG2: 9.1 (-2.7 to 20.2) | 3-way ANOVA: p=0.009 IG vs. CG1: p=0.003 IG vs. CG2: p=0.018 | NR | N/A | N/A | N/A

Abbreviations: ANOVA = analysis of variance; CG = control group; CI = confidence interval; CVA = cerebrovascular accident; HR = hazard ratio; IG = intervention group; LDL = low-density lipoprotein; MI = myocardial infarction; N/A = not applicable; NR, not reported.

The second trial is a small, fair-quality RCT (n=355) designed to determine whether an intensive telephone counseling intervention could improve lipid control in patients with PAD and high LDL cholesterol levels (Table 13).101 This trial was conducted at two academic centers in the United States and used mixed recruitment methods to identify adult participants with known PAD and an LDL level of greater than 70 mg/dL. The majority of patients had no or atypical symptoms (20.3% and 54.5%, respectively), and the minority of patients had intermittent claudication (15.2%).102 The mean ABI in this sample of patients was only 0.68 and the mean LDL level was 103 mg/dL. The mean age was 70.5 years, 40.6 percent were women, the mean total cholesterol level was 183 mg/dL, about two thirds were taking cholesterol-lowering drugs, and about one fourth were current smokers. In this trial, persons in the intervention group received eight telephone calls every 6 weeks (total of 200 minutes) focusing on the importance of lowering LDL cholesterol, adherence to medication, communicating with their treating physician about needing more intensive therapy, and increasing walking activity; in addition, study staff sent a letter to the treating physician after each call. This trial compared the intervention group with two different control groups—an attention control with telephone calls on general PAD information and a usual care control (no calls). At 12 months, persons in the intervention group had a greater change in LDL cholesterol (-18.4 mg/dL) compared with the attention control (-6.8 mg/dL; p=0.010), but not with the usual care group (-11.1 mg/dL; p=0.208) (Table 14). A greater proportion of persons in the intervention group achieved LDL levels of less than 100 mg/dL (21.6%) compared with the attention control (9.0%; p=0.003) and the usual care group (9.1%; p=0.018).

## KQ 6 What Are the Harms of Treatment in Generally Asymptomatic Persons With PAD?

We found only one trial that directly examined the harms of treatment in asymptomatic persons with PAD. This trial was the good-quality AAA (n=3,350), which examined the effectiveness of low-dose aspirin in screen-detected persons with low ABI.100 In this trial (described in KQ 5), persons randomized to aspirin had a nonsignificant trend for increased major bleeding (requiring hospital admission) over a mean of 8.2 years followup compared with persons randomized to placebo (HR, 1.71 [95% CI, 0.99 to 2.97]) (Table 14).