# Methods

This review is not simply an update of the previous review because it includes broader CVD outcomes than the previous review in support of the 2005 USPSTF recommendation statement. Our current review specifically focuses on: 1) resting ABI test as the only screening modality; 2) the diagnostic performance of ABI testing in primary care populations, unselected populations, and/or asymptomatic populations; 3) the predictive value of ABI testing in primary care or unselected populations for major CVD outcomes; and 4) the treatment of patients with asymptomatic or minimally symptomatic PAD impacting both general CVD morbidity and PAD-specific (lower extremity) morbidity.

## Development of Work Plan

We prepared a draft work plan (from August to October 2011) that three external expert reviewers subsequently reviewed in October and November 2011. We presented the revised draft plan to the three USPSTF leads in December 2011. We presented this revised plan to stakeholders in Webinar format and portions of the plan (analytic framework, key questions [KQs], and inclusion criteria) were posted for public comment for 4 weeks in December 2011 and January 2012. We made minor revisions based on feedback garnered during this process and submitted a final version of our work plan in February 2012.

## Analytic Framework and KQs

Using the USPSTF's methods,68 we developed an analytic framework (Figure 1) and six KQs to guide our literature search. These KQs include:

KQ 1. Is screening generally asymptomatic adults for PAD using ABI effective in reducing CVD morbidity (e.g., MI, CVA), morbidity from PAD (e.g., amputation, impaired ambulation, impaired function), or mortality (e.g., CVD specific, overall)?

a. Does the effectiveness of screening for PAD vary by subgroup (i.e., age [especially for age 65 years and older], sex, race, risk factors)?

KQ 2. In generally asymptomatic adults, what is the diagnostic accuracy (e.g., sensitivity, specificity, positive and negative predictive value) of ABI as a screening test for PAD?

a. Does the diagnostic accuracy of ABI screening vary by subgroup (i.e., age [especially for age 65 years and older], sex, race, risk factors)?

KQ 3. What are the harms of screening (e.g., diagnostic inaccuracy [overdiagnosis], harms of additional testing)?

a. Do the harms of screening vary by subgroup (i.e., age [especially for age 65 years and older], sex, race, risk factors)?

KQ 4. Does ABI in generally asymptomatic adults accurately predict CVD morbidity (e.g., MI, CVA) and mortality independent of traditional risk factors?

a. What is the prevalence of a normal and abnormal ABI among low-, intermediate-, and high-risk adults?
b. At what frequency does the use of ABI significantly change the risk of CVD morbidity or mortality based on traditional risk factors alone (e.g., from intermediate risk to low or high risk)?
c. What is the accuracy of risk reclassification of CVD morbidity or mortality (in addition to traditional risk factors)?

KQ 5. Does treatment of asymptomatic or minimally symptomatic adults with PAD lead to improvement in patient outcomes beyond the benefits of treatment in symptomatic adults, or beyond the benefits of treatment of adults with known CVD risk factors (i.e., smoking, hypertension, hyperlipidemia)?

a. Does the effectiveness of treatment vary by subgroup (i.e., age [especially for age 65 years and older], sex, race, risk factors)?

KQ 6. What are the harms of treatment of screen-detected PAD?

a. Do the harms of treatment vary by subgroup (i.e., age [especially for age 65 years and older], sex, race, risk factors)?

Figure 1 Analytic Framework

Figure 1 is an analytic framework for the key questions of this report that depicts the events that unselected or asymptomatic adults could experience while undergoing screening for PAD using ABI. In general, the figure illustrates how using ABI to screen for PAD may result in reducing CVD morbidity, morbidity from PAD, or mortality. In addition, the figure looks at the diagnostic accuracy of ABI as a screening test for PAD and its use as a risk prediction tool. The figure also looks at whether treating asymptomatic adults with PAD improves patient outcomes beyond the benefits of treatment in symptomatic patients or patients with known CVD risk factors (for example, smoking). In addition, the figure depicts the possibility of harms or adverse events occurring as a result of treating PAD or using ABI to screen for PAD.

## Data Sources and Searches

We searched MEDLINE and the Cochrane Central Registry of Controlled Trials from 1996 through September 2012 to locate relevant English-language studies for all KQs (Appendix A). We supplemented our searches with suggestions from experts and reference lists from 62 recent relevant existing systematic reviews (Appendix B). We also searched ClinicalTrials.gov on September 12, 2012 for relevant ongoing trials (Appendix C).

## Study Selection

Two investigators independently reviewed 4,434 abstracts and 418 full-text articles (Appendix D) against the specified inclusion criteria (Appendix E). We resolved discrepancies by consultation with a third investigator. We list the studies we excluded at the full-text phase (i.e., based on exclusion criteria or for poor quality) in Appendix F.

Our review focuses on the clinical utility of resting ABI as the primary screening modality because it is the most commonly used and is able to detect asymptomatic persons. Therefore, our review excluded other methods of screening (e.g., questionnaires, exercise ABI, toe pressure measurement, pulse oximetry, duplex ultrasound, MRA). Our review also focuses on generally asymptomatic adults, which may include populations with atypical symptoms or minor symptoms not recognized as PAD. We excluded studies whose subjects primarily had known intermittent claudication. We also excluded studies conducted exclusively in persons with known CVD, diabetes, or severe chronic kidney disease (stage 4 and 5). We excluded studies conducted in hospital or specialty settings (i.e., vascular clinics or laboratories), as these settings typically represented populations selected for known or highly suspected PAD. Because we focus on largely asymptomatic persons, our primary outcomes of interest are CVD events and risk factor reduction, rather than lower-extremity symptoms. If studies that met our inclusion criteria also reported PAD-specific outcomes (e.g., limb function, ambulation, amputation), however, we considered these outcomes. Likewise, our included treatments focused on pharmacologic or lifestyle interventions primarily aimed at CVD risk reduction (e.g., smoking cessation, cholesterol lowering, blood pressure control, and antiplatelet therapy). Therefore, we excluded interventions aimed primarily at management of lower-extremity symptoms or functioning (e.g., cilostazol, supervised exercise training or physical therapy, revascularization).

For KQ 1, we considered any trial (randomized, controlled trial [RCT] or controlled clinical trial [CCT]) or systematic review that compared ABI screening to no screening reporting any outcome of interest (i.e., CVD or PAD-specific morbidity or mortality). For KQ 2, we considered prospectively conducted diagnostic accuracy studies or well-conducted systematic reviews of diagnostic accuracy. We excluded case-control studies in which cases were selected based on having known PAD. Distorted selection of subjects in recruitment or case-control designs has repeatedly been shown to overestimate sensitivity.69-73 A distorted selection of subjects directly affects the applicability of the study findings and threatens its validity (i.e., spectrum bias). Spectrum bias refers to the phenomenon that the diagnostic test performance may change between clinical settings due to changes in patient case-mix. For KQ 2, diagnostic accuracy studies had to compare ABI with a reference standard. Because the gold standard, DSA, is an invasive test that presents known risks, it is not ethical to administer this test in asymptomatic persons. Therefore, we considered any diagnostic test that could image the degree of atherosclerosis (e.g., MRA, CTA) or degree of impaired blood flow (e.g., duplex ultrasound) to be a reasonable diagnostic reference standard. We accepted all measures of diagnostic accuracy (e.g., sensitivity, specificity, positive or negative predictive values, positive or negative likelihood ratios). For KQ 4, we considered prospective longitudinal cohort studies or systematic reviews of risk prediction. Included risk prediction studies had to assess ABI in addition to existing FRS factors, as defined in ATP III (i.e., age, sex, smoking status, systolic blood pressure, total cholesterol, and HDL cholesterol).43 While studies could adjust for additional known risk factors, we excluded studies that did not consider all existing FRS factors as a minimum. For KQ 5, we included any trial (RCT or CCT) or systematic review with at least 12 weeks of followup that compared treatment of PAD with no treatment, with placebo treatment, or with delayed treatment. Again, we considered any outcome of interest (i.e., CVD or PAD-specific morbidity or mortality). While we included reviews, trials, cohort studies, and case-control studies for KQs 3 and 6, we excluded case series or case reports.

## Data Extraction and Quality Assessment

For screening studies, we extracted details about each study's location, recruitment, inclusion/exclusion criteria, participant characteristics, reference standard, test performance characteristics, and adverse events. For risk prediction studies, we extracted details about each study's location, recruitment, inclusion/exclusion criteria, participant characteristics, technique for measuring ABI, adequacy and length of followup, method for ascertaining outcomes, inclusion of prognostic factors other than ABI, analytic approach, and outcomes. Outcomes included relative event outcomes (e.g., hazard ratio [HR], relative risk [RR], or OR) or measures of risk reclassification. Measures of discrimination or risk reclassification included differences in the area under the curve (AUC) or c-statistic, percent reclassified (i.e., from a reclassification table), and net reclassification improvement (NRI) (Table 1).

Table 1 Types of Outcome Measures for Comparing Prediction Models in This Report74,75,78

Purpose | Measures | Description
Risk association | Hazard ratio (HR) Risk ratio (RR) Odds ratio (OR) | Independent association of ABI and outcome of interest (CAD or CVD events), after adjusting for FRS
Discrimination | Change in area under the curve (AUC) or C-statistic (for binary outcomes) | The change in the probability that a model with FRS + ABI will assign a higher risk for a subject who will have an event than to a subject who will not have an event, compared with a model with FRS alone
Risk reclassification Useful only when there are accepted risk categories | Percent reclassified from a reclassification table | Table showing distribution of subjects classified using FRS model compared with classification based on a model with FRS + ABI **Does not account for correctness of reclassification
Risk reclassification Useful only when there are accepted risk categories | Net reclassification index (NRI) or improvement | The sum of differences in proportions of individuals moving up minus those moving down with a CVD outcome, plus the proportion moving down minus those moving up without an outcome

Abbreviations: ABI = ankle-brachial index; CAD = coronary artery disease; CVD = cardiovascular disease.

Risk reclassification refers to the change in risk when a new predictor is added to an existing risk prediction model (i.e., subjects may be placed into a different risk category than the one they were in when the original model was used). This movement between risk categories may be displayed as a reclassification table. This table shows the number (and percent) of subjects in each risk category using the original model versus the number (and percent) of subjects in each risk category using the model with the new predictor. While studies may report the percent of subjects who change risk categories, this does not ensure subjects were correctly recategorized.74 Subjects who will have an outcome event should move to a higher risk category, while subjects who will not have an event should move to a lower risk category. For subjects who will have an event, movement to a higher risk category is improved classification, while movement to a lower risk category is worse (incorrect) classification; likewise, for subjects who will not have an event, movement to a lower risk category is improved classification, while movement to a higher risk category is worse classification.74-76 The NRI quantifies this as (proportion of subjects who will have an event moving higher minus proportion of subjects who will have an event moving lower) + (proportion of subjects who will not have an event moving lower minus proportion of subjects who will not have an event moving higher).75 Another way to think of the NRI is the sum of the improvement in sensitivity and the improvement in specificity.75

In a risk reclassification table, those cells representing no change in risk category between prediction models lie on a diagonal; the other cells represent a change in risk between the original model and the new model. If the original and new prediction models were the same, the numbers in the cells representing change would be symmetric about the cells representing no change. The number of subjects who will have an event moving to a higher risk category would equal the number moving to a lower risk category and the number of subjects who will not have an event moving to a lower risk category would equal the number moving to a higher risk category. If an NRI were calculated for the entire table, it would be zero.77 However, an NRI might be calculated only for certain risk categories, as defined by the original model. Only those cells lying in certain rows of the risk reclassification table would be used, and some of the symmetric cells from the reclassification table would be excluded. An NRI could be calculated; if it were positive, it would imply improvement, even though the models were identical. Therefore, an NRI for any subset of risk categories will be artificially inflated by this expected NRI simply because some of the symmetrically distributed cells are excluded. A corrected NRI may be calculated by subtracting the expected NRI from the apparent NRI.77 For risk prediction studies reporting NRI for subgroups (i.e., intermediate-risk groups), we calculated a corrected NRI for the intermediate risk category where data were available to do so.

The AUC—specifically, the area under the receiver operating characteristic curve—represents a model's ability to discriminate between subjects who will and will not have an event.78 The AUC is the probability that a model will assign a higher risk for an event to a randomly selected subject who will have an event than to a randomly selected subject who will not have an event.74, 79,80 The range of the AUC is 0.5 (no discriminatory ability) to 1 (perfect discrimination).76 For prognostic models, the AUC is typically 0.6 to 0.85.^80^ When a new predictor is added to a model, the improvement in the model's ability to discriminate may be measured by the difference between the AUC for the model with the new predictor and the AUC for the original model.74 An increase in the AUC of 0.025 is considered clinically relevant.81

For treatment trials, we extracted details about each study's location, recruitment, inclusion/exclusion criteria, patient characteristics, experimental and comparison intervention(s), internal validity, retention, method for ascertaining outcomes, analytic approach, outcomes, and adverse effects. A second reviewer verified all extracted data. We contacted study authors by email for clarification, when necessary.

At least two reviewers independently critically appraised articles meeting inclusion criteria using the USPSTF's design-specific quality criteria,82 supplemented with the National Institute for Health and Clinical Excellence (NICE) methodology checklists,83 Quality Assessment of Diagnostic Accuracy Studies (for studies of diagnostic accuracy [KQ 2]),84,85 and the Newcastle-Ottawa Scale86 and Hayden criteria87 (for prediction studies [KQ 4]). Articles were rated as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet (or it was unclear whether it met) at least one criterion but also had no known important limitation that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. The most common flaws leading to poor-quality ratings among studies about diagnostic accuracy were having an inappropriate reference standard, a biased spectrum of subjects, or verification bias. The most common flaw leading to poor-quality ratings among studies about prognosis was lack of relevant outcomes. However, the majority of prognostic studies were excluded because they did not include all the ATP III FRS factors in multivariable models and therefore did not meet our inclusion criteria. For treatment trials, we excluded the majority of studies because they were conducted in persons with intermittent claudication. We excluded poor-quality studies from this review.

## Synthesis and Analysis

We did not conduct any quantitative analyses for any of the KQs due to the low volume, heterogeneity, and nature of our included studies. We found no studies for KQ 1. For KQs 2 and 3, we included only one study and therefore describe the results of this single study along with our quality and applicability assessment. For KQ 4, we included 14 studies representing eight different cohorts and one large individual patient-level data meta-analysis. The meta-analysis included all but two of the cohorts represented in the 14 other studies. Given the available information, we were unable to attempt further quantitative syntheses. Instead, we qualitatively synthesized data from this pooled analysis, comparing and contrasting its results with findings from individual studies by outcomes, focusing primarily on measures of risk reclassification and secondarily on measures of association (HR and RR) adjusted for FRS factors (i.e., age, sex, smoking status, systolic blood pressure, total cholesterol, HDL cholesterol).43 We use summary tables to display differences between important study characteristics and outcomes across included studies. For KQs 5 and 6, we included only two treatment studies that were quite different from one another. Therefore, we summarize the results of these studies in the context of their quality and applicability.

For each KQ, we summarize the overall body of evidence, commenting on several domains, including quality of findings (including risk of bias), applicability of findings, consistency of findings (including possible clinical heterogeneity explaining inconsistencies), magnitude of findings, and precision around the magnitude of findings.82

## USPSTF Involvement

We worked with three USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs, to address methodological decisions on applicable evidence, and to resolve issues around scope for the final evidence synthesis. The Agency for Healthcare Research and Quality (AHRQ) funded this work under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.