# Excluded Studies

Exclusion Codes
- E1: Study relevance
- E2: Population
  - E2a: Patients with symptomatic PAD
  - E2b: Exclusively persons with known CVD, diabetes
- E3: No relevant outcomes
- E4. Quality
  - E4a. High or differential attrition
  - E4b. Poor study quality: other quality issue
  - E4c. Poor study quality: does not use reference standard
- E5: Setting: hospital, inpatient, LTC, vascular clinics
- E6. Not an included study design
  - E6a. Study design: case control (applies to KQ2 only)
  - E6b. Not an RCT, CCT, or SER
  - E6c. Study design: CER
  - E6d. Study design: followup from BL <3 months/12 weeks
  - E6e. Does not adjust for traditional Framingham risk factors
- E7a. Not a study of ABI
- E7b. Not an included treatment

1 Randomized placebo-controlled, double-blind trial of ketanserin in claudicants. Changes in claudication distance and ankle systolic pressure. PACK Claudication Substudy. Circulation. 1989;80:1544-8. KQ5E2a. [pmid: 2688971].
2 MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20, 536 high-risk individuals: a randomised placebo-controlled trial. Lancet. Jul. 6. 2002;360(9326):7-22. KQ5E2a. [pmid: 12114036].
3 Aboyans V, Lacroix P, Postil A, et al. Subclinical peripheral arterial disease and incompressible ankle arteries are both long-term prognostic factors in patients undergoing coronary artery bypass grafting. J Am Coll Cardiol. Sep. 6. 2005;46(5):815-20. KQ4E2b. [pmid: 16139130].
4 Aboyans V, Lacroix P. Regarding: “A modified calculation of ankle-brachial pressure index is far more sensitive in the detection of peripheral arterial disease”. Journal of Vascular Surgery. 2007;46(3):617-8. KQ2E6. [pmid: 17826263].
5 AbuRahma AF, Diethrich EB. Doppler ultrasound in evaluating the localization and severity of peripheral vascular occlusive disease. Southern Medical Journal. Nov. 1979;72(11):1425-8. KQ2E2a. [pmid: 505077].
6 Ahimastos AA, Lawler A, Reid CM, et al. Brief communication: ramipril markedly improves walking ability in patients with peripheral arterial disease: a randomized trial. Annals of Internal Medicine. 2006;144:660-4. KQ5E2a. [pmid: 16670135].
7 Ahimastos AA, Dart AM, Lawler A, et al. Reduced arterial stiffness may contribute to angiotensin-converting enzyme inhibitor induced improvements in walking time in peripheral arterial disease patients. Journal of Hypertension. 2008;26:1037-42. KQ5E2a. [pmid: 18398348].
8 Ahimastos AA, Pappas EP, Buttner PG, et al. A meta-analysis of the outcome of endovascular and noninvasive therapies in the treatment of intermittent claudication. Journal of Vascular Surgery. Nov. 2011;54(5):1511-21. KQ5E2a. [pmid: 21958561].
9 Allen J, Murray A. Comparison of three arterial pulse waveform classification techniques. Journal of Medical Engineering & Technology. May. 1996;20(3):109-14. KQ2E1. [pmid: 8877751].
10 Allison MA, Ho E, Denenberg JO, et al. Ethnic-specific prevalence of peripheral arterial disease in the United States. Am J Prev Med. Apr. 2007;32(4):328-33. KQ4E3. [pmid: 17383564].
11 Allison MA, Aboyans V, Granston T, et al. The relevance of different methods of calculating the ankle-brachial index: the multi-ethnic study of atherosclerosis. Am J Epidemiol. Feb. 1. 2010;171(3):368-76. KQ4E3. [pmid: 20042436].
12 Alnaeb ME, Boutin A, Crabtree VP, et al. Assessment of lower extremity peripheral arterial disease using a novel automated optical device. Vascular & Endovascular Surgery. Dec. 20. 2007;41(6):522-7. KQ2E2. [pmid: 18166634].
13 Alonso-Coello P, Bellmunt S, McGorrian C, et al. Antithrombotic therapy in peripheral artery disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2:Suppl). Suppl-90S. KQ5E6. [pmid: 22315275].
14 Alzamora MT, Baena-Diez JM, Sorribes M, et al. Peripheral Arterial Disease study (PERART): prevalence and predictive values of asymptomatic peripheral arterial occlusive disease related to cardiovascular morbidity and mortality. BMC Public Health. 2007;7:348. KQ4E3. [pmid: 18070367].
15 Alzamora MT, Fores R, Baena-Diez JM, et al. The peripheral arterial disease study (PERART/ARTPER): prevalence and risk factors in the general population. BMC Public Health. 2010;10:38. KQ4E6. [pmid: 20529387].
16 Angeli F, Reboldi G, Verdecchia P. Lowering blood pressure with beta-blockers in peripheral artery disease: the importance of comorbidity. Journal of Hypertension. Jul. 2011;29(7):1298-302. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4, KQ6E4. [pmid: 21659823].
17 Ankle Brachial Index Collaboration, Fowkes FG, Murray GD, et al. Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. Jul. 9. 2008;300(2):197-208. KQ4E2. [pmid: 18612117].
18 Antithrombotic TC. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. [Erratum appears in BMJ 2002 Jan 19;324(7330):141]. BMJ. Jan. 12. 2002;324(7329):71-86. KQ5E2a. [pmid: 11786451].
19 Aquarius AE, Smolderen KG, Hamming JF, et al. Type D personality and mortality in peripheral arterial disease: a pilot study. Archives of Surgery. Aug. 2009;144(8):728-33. KQ4E1. [pmid: 19687376].
20 Arain FA, Khaleghi M, Bailey KR, et al. White blood cell count predicts all-cause mortality in patients with suspected peripheral arterial disease. American Journal of Medicine. Sep. 2009;122(9):874-7. KQ4E1. [pmid: 19699384].
21 Arain FA, Ye Z, Bailey KR, et al. Survival in patients with poorly compressible leg arteries. J Am Coll Cardiol. Jan. 24. 2012;59(4):400-7. KQ4E5. [pmid: 22261162].
22 Aronow WS, Ahmed MI, Ekundayo OJ, et al. A propensity-matched study of the association of peripheral arterial disease with cardiovascular outcomes in community-dwelling older adults. American Journal of Cardiology. Jan. 1. 2009;103(1):130-5. KQ4E6e. [pmid: 19101243].
23 Aung PP, Maxwell HG, Jepson RG, et al. Lipid-lowering for peripheral arterial disease of the lower limb. [Update of Cochrane Database Syst Rev. 2000;(2):CD000123; PMID: 10796489]. Cochrane Database of Systematic Reviews. 2007;(4):CD000123. KQ5E6. [pmid: 17943736].
24 Auteri A, Angaroni A, Borgatti E, et al. Triflusal in the treatment of patients with chronic peripheral arteriopathy: multicentre double-blind clinical study vs placebo. International Journal of Clinical Pharmacology Research. 1995;15(2):57-63. KQ5E7. [pmid: 8593974].
25 Baena-Diez JM, Alzamora MT, Fores R, et al. Ankle-brachial index improves the classification of cardiovascular risk: PERART/ARTPER Study. Revista Espanola de Cardiologia. Mar. 2011;64(3):186-92. KQ4E6. [pmid: 21330032].
26 Bagi P, Sillesen H, Bitsch K, et al. Doppler waveform analysis in evaluation of occlusive arterial disease in the lower limb: comparison with distal blood pressure measurement and arteriography. European Journal of Vascular Surgery. Jun. 1990;4(3):305-11. KQ2E2a. [pmid: 2191879].
27 Baigent C, Keech A, Kearney PM, et al. Efficacy and safety of cholesterol-lowering treatment: prospective meta-analysis of data from 90,056 participants in 14 randomised trials of statins. Lancet. Oct. 8. 2005;366(9493):1267-78. KQ5E1, KQ6E1. [pmid: 16214597].
28 Baigent C, Blackwell L, Collins R, et al. Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet. May. 30. 2009;373(9678):1849-60. KQ5E1, KQ6E1. [pmid: 19482214].
29 Ballard JL, Mazeroll R, Weitzman R, et al. Medical benefits of a peripheral vascular screening program. Annals of Vascular Surgery. Mar. 2007;21(2):159-62. KQ1E6. [pmid: 17349356].
30 Bampi AB, Rochitte CE, Favarato D, et al. Comparison of non-invasive methods for the detection of coronary atherosclerosis. Clinics (Sao Paulo, Brazil). 2009;64(7):675-82. KQ4E2. [pmid: 19606245].
31 Bavry AA, Anderson RD, Gong Y, et al. Outcomes Among hypertensive patients with concomitant peripheral and coronary artery disease: findings from the INternational VErapamil-SR/Trandolapril STudy. Hypertension. Jan. 2010;55(1):48-53. KQ4E1, KQ5E6. [pmid: 19996066].
32 Baxter GM, Polak JF. Lower limb colour flow imaging: a comparison with ankle: brachial measurements and angiography. Clinical Radiology. Feb. 1993;47(2):91-5. KQ2E2a. [pmid: 8435971].
33 Beckman JA, Preis O, Ridker PM, et al. Comparison of usefulness of inflammatory markers in patients with versus without peripheral arterial disease in predicting adverse cardiovascular outcomes (myocardial infarction, stroke, and death). American Journal of Cardiology. Nov. 15. 2005;96(10):1374-8. KQ4E5. [pmid: 16275181].
34 Benchimol D, Pillois X, Benchimol A, et al. Accuracy of ankle-brachial index using an automatic blood pressure device to detect peripheral artery disease in preventive medicine. Archives of Cardiovascular Diseases. Jun. 2009;102(6-7):519-24. KQ2E4c, KQ3E4c. [pmid: 19664571].
35 Bennett CL, Weinberg PD, Rozenberg-Ben-Dror K, et al. Thrombotic thrombocytopenic purpura associated with ticlopidine. A review of 60 cases. Ann Intern Med. Apr. 1. 1998;128(7):541-4. KQ6E2. [pmid: 9518398].
36 Bennett CL, Connors JM, Carwile JM, et al. Thrombotic thrombocytopenic purpura associated with clopidogrel 1. N Engl J Med. Jun. 15. 2000;342(24):1773-7. KQ6E2. [pmid: 10852999].
37 Bertomeu V, Morillas P, Gonzalez-Juanatey JR, et al. Prevalence and prognostic influence of peripheral arterial disease in patients >or=40 years old admitted into hospital following an acute coronary event. European Journal of Vascular & Endovascular Surgery. Aug. 2008;36(2):189-96. KQ4E2b. [pmid: 18375154].
38 Bhasin N, Scott DJ. Ankle Brachial Pressure Index: identifying cardiovascular risk and improving diagnostic accuracy. Journal of the Royal Society of Medicine. Jan. 2007;100(1):4-5. KQ2E6, KQ4E6. [pmid: 17197670].
39 Bhatt DL, Topol EJ, Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization MaAEC. Clopidogrel added to aspirin versus aspirin alone in secondary prevention and high-risk primary prevention: rationale and design of the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance (CHARISMA) trial. Am Heart J. Aug. 2004;148(2):263-8. KQ5E6c. [pmid: 15308995].
40 Bhatt DL, Fox KA, Hacke W, et al. A global view of atherothrombosis: baseline characteristics in the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance (CHARISMA) trial. [Erratum appears in Am Heart J. 2006 Jan;151(1):247]. Am Heart J. Sep. 2005;150(3):401. KQ5E6c. [pmid: 16169314].
41 Bhatt DL, Fox KA, Hacke W, et al. Clopidogrel and aspirin versus aspirin alone for the prevention of atherothrombotic events. N Engl J Med. Apr. 20. 2006;354(16):1706-17. KQ5E2a. [pmid: 16531616].
42 Bianchi J, Zamiri M, Loney M, et al. Pulse oximetry index: a simple arterial assessment for patients with venous disease. [Erratum appears in J Wound Care. 2008 Jul;17(7):327]. Journal of Wound Care. 2008;17(6):253-4. KQ2E1. [pmid: 18666719].
43 Blanchard J, Carreras LO, Kindermans M. Results of EMATAP: a double-blind placebo-controlled multicentre trial of ticlopidine in patients with peripheral arterial disease. Nouvelle Revue Francaise D'hématologie. 1994;35:523-8. KQ5E2a. [pmid: 8152898].
44 Blanchard JF, Carreras LO, -on-behalf-of-the-EMATAP-Group. A double-blind, placebo-controlled multicentre trial of ticlopidine in patients with peripheral arterial disease in Argentina. Nouvelle Revue Francaise D'hematologie. 1992;34(2):149-53. KQ5E2a. [pmid: 1502021].
45 Bosch J, Yusuf S, Pogue J, et al. Use of ramipril in preventing stroke: double blind randomised trial. BMJ. 2002;324:699-702. KQ5E2. [pmid: 11909785].
46 Bounameaux H, Holditch T, Hellemans H, et al. Placebo-controlled, double-blind, two-centre trial of ketanserin in intermittent claudication. Lancet. 1985;2:1268-71. KQ5E2a. [pmid: 2866336].
47 Branchereau A, Rouffy J. Randomized double blind two parallel-groups Ifenprodil tartrate versus placebo-controlled trial in stage II peripheral arterial occlusive disease. Journal Des Maladies Vasculaires. 1995;20:21-7. KQ5E7b. [pmid: 7745355].
48 Brass EP, Hiatt WR. Review of mortality and cardiovascular event rates in patients enrolled in clinical trials for claudication therapies. Vascular Medicine. Nov. 2006;11(3):141-5. KQ4E2a. [pmid: 17288119].
49 Breddin HK, Lippold R, Bittner M, et al. Spontaneous platelet aggregation as a predictive risk factor for vascular occlusions in healthy volunteers? Results of the HAPARG Study. Haemostatic parameters as risk factors in healthy volunteers. Atherosclerosis. May. 1999;144(1):211-9. KQ4E1. [pmid: 10381294].
50 Brevetti G, Attisano T, Perna S, et al. Effect of L-carnitine on the reactive hyperemia in patients affected by peripheral vascular disease: a double-blind, crossover study. Angiology. 1989;40:857-62. KQ5E7. [pmid: 2679240].
51 Brevetti G, Silvestro A, Schiano V, et al. Endothelial dysfunction and cardiovascular risk prediction in peripheral arterial disease: additive value of flow-mediated dilation to ankle-brachial pressure index. Circulation. Oct. 28. 2003;108(17):2093-8. KQ4E2a. [pmid: 14530195].
52 Brevetti G, Giugliano G, Oliva G, et al. The impact of comorbidity burden on the cardiovascular risk in the Peripheral Arteriopathy and Cardiovascular Events study. Qjm. Jul. 2008;101(7):575-82. KQ4E6d. [pmid: 18463142].
53 Brevetti G, Laurenzano E, Giugliano G, et al. Metabolic syndrome and cardiovascular risk prediction in peripheral arterial disease. Nutrition Metabolism & Cardiovascular Diseases. Nov. 2010;20(9):676-82. KQ4E2a. [pmid: 19699069].
54 Brothers TE, Esteban R, Robison JG, et al. Symptoms of chronic arterial insufficiency correlate with absolute ankle pressure better than with ankle: brachial index. Minerva Cardioangiologica. Apr. 2000;48(4-5):103-9. KQ2E2a. [pmid: 10959146].
55 Bucek RA, Reiter M, Wirth S, et al. Influence of HMG-CoA-reductase inhibitors on the body fat status. Vasa. May. 2006;35(2):92-5. KQ5E6. [pmid: 16796007].
56 Buchwald H, Bourdages HR, Campos CT, et al. Impact of cholesterol reduction on peripheral arterial disease in the Program on the Surgical Control of the Hyperlipidemias (POSCH). Surgery. Oct. 1996;120(4):672-9. KQ5E7. [pmid: 8862377].
57 Burek KA, Sutton TK, Brooks MM, et al. Prognostic importance of lower extremity arterial disease in patients undergoing coronary revascularization in the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. 1999;34:716-21. KQ4E2b. [pmid: 10483952].
58 Burke GL, Arnold AM, Bild DE, et al. Factors associated with healthy aging: the cardiovascular health study. Journal of the American Geriatrics Society. Mar. 2001;49(3):254-62. KQ4E3. [pmid: 11300235].
59 Buzin A, Baranov A, Obukhov A, et al. Hypolipidemic and pleiotropic effects of atorvastatin treatment in peripheral artery disease patients with dyslipidemia. European Heart Journal. 2008;29(Suppl 1):144. KQ5E4b. [pmid: 18156617].
60 Cacoub PP, Bhatt DL, Steg PG, et al. Patients with peripheral arterial disease in the CHARISMA trial. European Heart Journal. Jan. 2009;30(2):192-201. KQ5E2a, KQ6E2a. [pmid: 19136484].
61 Catalano M, Carzaniga G, Fiore G, et al. Aspirin plus dipyridamole in the peripheral vascular disease. INT ANGIOL. 1985;4:29-30. KQ5E2a.
62 Catalano M, Tomasini M, Scandale G, et al. Isradipine in the treatment of peripheral occlusive vascular disease of the lower limbs: a pilot study. The Journal of International Medical Research. 1992;20:323-30. KQ5E4b. [pmid: 1387369].
63 Chacón-Quevedo A, Eguaras MG, Calleja F, et al. Comparative evaluation of pentoxifylline, buflomedil, and nifedipine in the treatment of intermittent claudication of the lower limbs. Angiology. 1994;45:647-53. KQ5E2a. [pmid: 8024164].
64 Charakida M, Masi S, Tousoulis D. Functional, genetic and biochemical biomarkers of peripheral arterial disease. Current Medicinal Chemistry. 2012;19(16):2497-503. KQ4E6. [pmid: 22489720].
65 Cittanti C, Colamussi P, Giganti M, et al. Technetium-99m sestamibi leg scintigraphy for non-invasive assessment of propionyl-L-carnitine induced changes in skeletal muscle metabolism. European Journal of Nuclear Medicine. 1997;24(7):762-6. KQ5E7. [pmid: 9211762].
66 Clairotte C, Retout S, Potier L, et al. Automated ankle-brachial pressure index measurement by clinical staff for peripheral arterial disease diagnosis in nondiabetic and diabetic patients. Diabetes Care. Jul. 2009;32(7):1231-6. KQ2E4c, KQ3E4c. [pmid: 19366974].
67 Clement DL, Duprez D, Van Wassenhove A, et al. Ketanserin in intermittent claudication. A double-blind placebo-controlled study. International angiology: a journal of the International Union of Angiology. 1989;8:92-6. KQ5E2a. [pmid: 2681451].
68 Coffman JD, Rasmussen HM. The peripheral circulation and treatment of hyperlipoproteinemias. Atherosclerosis. 1983;46(1):147-59. KQ5E6b. [pmid: 6838691].
69 Collins R, Armitage J, Parish S, et al. Effects of cholesterol-lowering with simvastatin on stroke and other major vascular events in 20536 people with cerebrovascular disease or other high-risk conditions. Lancet. Mar. 6. 2004;363(9411):757-67. KQ5E2a. [pmid: 15016485].
70 Collins TC, Johnson S. Risk factor modification for patients with peripheral arterial disease: a randomized controlled trial. Clinical Trials. 2005;2:S87-S88. KQ5E2a.
71 Collins TC, Johnson SL, Souchek J. Unsupervised walking therapy and atherosclerotic risk-factor management for patients with peripheral arterial disease: a pilot trial. Annals of behavioral medicine: a publication of the Society of Behavioral Medicine. 2007;33(3):318-24. KQ5E2a. [pmid: 17600459].
72 Collins TC, Krueger PN, Kroll TL, et al. Face-to-face interaction compared with video watching on use of physical activity in peripheral arterial disease: a pilot trial. Angiology. 2009;60:21-30. KQ5E6c, KQ6E6c. [pmid: 18586757].
73 Cordero A, Morillas P, Bertomeu-Gonzalez V, et al. Clustering of target organ damage increases mortality after acute coronary syndromes in patients with arterial hypertension. Journal of Human Hypertension. Oct. 2011;25(10):600-7. KQ4E1. [pmid: 21160527].
74 Coto V, Cocozza M, Oliviero U, et al. Clinical efficacy of picotamide in long-term treatment of intermittent claudication. Angiology. 1989;40:880-5. KQ5E2a. [pmid: 2679241].
75 Coto V, Oliviero U, Cocozza M, et al. A comparative trial of ketanserin and nifedipine in hypertension and obstructive peripheral arteriopathy. Advances in Therapy. 1991;8:133-40. KQ5E2a.
76 Creasy TS, McMillan PJ, Fletcher EW, et al. Is percutaneous transluminal angioplasty better than exercise for claudication? Preliminary results from a prospective randomised trial. European Journal of Vascular Surgery. 1990;4(2):135-40. KQ5E7. [pmid: 2140987].
77 Criqui MH, Coughlin SS, Fronek A. Noninvasively diagnosed peripheral arterial disease as a predictor of mortality: results from a prospective study. Circulation. Oct. 1985;72(4):768-73. KQ4E6e. [pmid: 4028377].
78 Criqui MH, Fronek A, Klauber MR, et al. The sensitivity, specificity, and predictive value of traditional clinical evaluation of peripheral arterial disease: results from noninvasive testing in a defined population. Circulation. Mar. 1985;71(3):516-22. KQ2E7a, KQ3E7a. [pmid: 3156007].
79 Criqui MH, Langer RD, Fronek A, et al. Coronary disease and stroke in patients with large-vessel peripheral arterial disease. Drugs. 1991;42(Suppl 5):16-21. KQ4E1. [pmid: 1726213].
80 Criqui MH, Langer RD, Fronek A, et al. Mortality over a period of 10 years in patients with peripheral arterial disease. N Engl J Med. Feb. 6. 1992;326(6):381-6. KQ2E7a, KQ3E7a, KQ4E7a. [pmid: 1729621].
81 Criqui MH, Ninomiya JK, Wingard DL, et al. Progression of peripheral arterial disease predicts cardiovascular disease morbidity and mortality. J Am Coll Cardiol. Nov. 18. 2008;52(21):1736-42. KQ4E5. [pmid: 19007695].
82 Criqui MH, McClelland RL, McDermott MM, et al. The ankle-brachial index and incident cardiovascular events in the MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. Oct. 26. 2010;56(18):1506-12. KQ4E6e. [pmid: 20951328].
83 Criqui MH, Ho LA, Denenberg JO, et al. Biomarkers in peripheral arterial disease patients and near- and longer-term mortality. Journal of Vascular Surgery. Jul. 2010;52(1):85-90. KQ4E5. [pmid: 20471776].
84 Cunha RG, Rodrigues KC, Salvador M, et al. Effectiveness of Laser treatment at acupuncture sites compared to traditional acupuncture in the treatment of peripheral artery disease. Conference proceedings: Annual International Conference of the IEEE Engineering in Medicine and Biology Society IEEE Engineering in Medicine and Biology Society Conference. 2010;2010:1262-5. KQ5E7. [pmid: 21095914].
85 Dal Lago A, De Martini D, Flore R, et al. Effects of propionyl-L-carnitine on peripheral arterial obliterative disease of the lower limbs: a double-blind clinical trial. Drugs Under Experimental and Clinical Research. 1999;25:29-36. KQ5E7. [pmid: 10337502].
86 Davis M, Atwal AS, Nair DR, et al. The effect of short-term lipid lowering with atorvastatin on carotid artery intima media thickness in patients with peripheral vascular disease: a pilot study. Current Medical Research & Opinion. 2000;16(3):198-204. KQ5E2a. [pmid: 11191010].
87 de GJ, Holewijn S, Stalenhoef AF, et al. Should preclinical vascular abnormalities be measured in asymptomatic adults to improve cardiovascular risk stratification?. Current Opinion in Lipidology. Dec. 2011;22(6):454-9. KQ4E6. [pmid: 21986644].
88 de Liefde II, Hoeks SE, van Gestel YR, et al. The prognostic value of impaired walking distance on long-term outcome in patients with known or suspected peripheral arterial disease. European Journal of Vascular & Endovascular Surgery. Oct. 2009;38(4):482-7. KQ4E5. [pmid: 19586784].
89 de Liefde II, van Domburg RT, Bax JJ, et al. A decline in walking distance predicts long-term outcome in patients with known or suspected peripheral artery disease. European Journal of Cardiovascular Prevention & Rehabilitation. Jun. 2010;17(3):321-8. KQ4E5. [pmid: 19838118].
90 de Liefde II, Verhagen HJ, Stolker RJ, et al. The value of treadmill exercise test parameters together in patients with known or suspected peripheral arterial disease. Eur J Cardiovasc Prev Rehabil. 2011. Mar. 1. KQ4E5. [pmid: 21450584].
91 Decrinis M, Doder S, Stark G, et al. A prospective evaluation of sensitivity and specificity of the ankle/brachial index in the follow-up of superficial femoral artery occlusions treated by angioplasty. Clinical Investigator. Aug. 1994;72(8):592-7. KQ2E2. [pmid: 7819715].
92 Dettori AG, Pini M, Moratti A, et al. Acenocoumarol and pentoxifylline in intermittent claudication. A controlled clinical study. The APIC Study Group. Angiology. 1989;40:237-48. KQ5E7. [pmid: 2650578].
93 Dhangana R, Murphy TP, Coll JR, et al. Prevalence of abnormal ankle-brachial index among individuals with low or intermediate Framingham Risk Scores. Journal of Vascular & Interventional Radiology. Aug. 2011;22(8):1077-82. KQ4E6. [pmid: 21705232].
94 Diehm C, Jacobsen O, Amendt K. The effects of tertatolol on lipid profile. Cardiology. Suppl 1. 1993;83:32-40. KQ5E2a. [pmid: 7903213].
95 Diehm C, Lange S, Darius H, et al. Association of low ankle brachial index with high mortality in primary care. Eur Heart J. Jul. 2006;27(14):1743-9. KQ4E6e. [pmid: 16782720].
96 Diehm C, Darius H, Burghaus I, et al. Ankle brachial index vs metabolic syndrome for risk prediction. Lancet. Oct. 4. 2008;372(9645):1221-2. KQ4E6. [pmid: 19094953].
97 Diehm C, Darius H, Pittrow D, et al. Prognostic value of a low post-exercise ankle brachial index as assessed by primary care physicians. Atherosclerosis. Feb. 2011;214(2):364-72. KQ4E6e. [pmid: 21167487].
98 Diehm C, Schuster A, Allenberg JR, et al. High prevalence of peripheral arterial disease and co-morbidity in 6880 primary care patients: cross-sectional study. Atherosclerosis. Jan. 2004;172(1):95-105. KQ4E3. [pmid: 14709362].
99 Diehm C, Allenberg JR, Pittrow D, et al. Mortality and vascular morbidity in older adults with asymptomatic versus symptomatic peripheral artery disease. Circulation. Nov. 24. 2009;120(21):2053-61. KQ4E6e. [pmid: 19901192].
100 Dormandy JA, Murray GD. The fate of the claudicant--a prospective study of 1969 claudicants. European Journal of Vascular Surgery. 1991;5:131-3. KQ4E1. [pmid: 2037083].
101 Drabaek H, Mehlsen J, Himmelstrup H, et al. A botanical compound, Padma 28, increases walking distance in stable intermittent claudication. Angiology. 1993;44:863-7. KQ5E7b. [pmid: 8239057].
102 Duerschmied D, Bode C. Vorapaxar expands antiplatelet options. Which patients may benefit from thrombin receptor antagonism?. Hamostaseologie. Aug. 1. 2012;32(3):221-7. KQ5E6. [pmid: 22777302].
103 Duprez DA, De Buyzere MM, De BL, et al. Small and large artery elasticity indices in peripheral arterial occlusive disease (PAOD). Vascular Medicine. Nov. 2001;6(4):211-4. KQ2E1. [pmid: 11958385].
104 Duval S, Massaro JM, Jaff MR, et al. An evidence-based score to detect prevalent peripheral artery disease (PAD). Vasc Med. 2012. Jun. 17. KQ4E3. [pmid: 20120619].
105 Egan DA, Garg R, Wilt TJ, et al. Rationale and design of the arterial disease multiple intervention trial (ADMIT) pilot study. American Journal of Cardiology. 1999;83:569-75. KQ5E2a. [pmid: 10073863].
106 Elam MB, Hunninghake DB, Davis KB, et al. Effect of niacin on lipid and lipoprotein levels and glycemic control in patients with diabetes and peripheral arterial disease: the ADMIT study: A randomized trial. Arterial Disease Multiple Intervention Trial. JAMA. Sep. 13. 2000;284(10):1263-70. KQ5E2a. [pmid: 10979113].
107 Eldrup N, Sillesen H, Prescott E, et al. Ankle brachial index, C-reactive protein, and central augmentation index to identify individuals with severe atherosclerosis. European Heart Journal. Feb. 2006;27(3):316-22. KQ2E4, KQ4E4. [pmid: 16278227].
108 Emler C, Jacomella V, Rufibach K, et al. Pressure Indices in Peripheral Arterial Disease Assessed by Infrared Photosensors. Angiology. 2012. May. 30. KQ2E4c. [pmid: 20120531].
109 Enoch A, Ijeoma A. The role of ankle-brachial index as a screening test for coronary artery disease in the Hispanic population. Southern Medical Journal. Nov. 2008;101(11):1117-20. KQ4E6. [pmid: 19088520].
110 Espinola-Klein C, Rupprecht HJ, Bickel C, et al. Different calculations of ankle-brachial index and their impact on cardiovascular risk prediction. Circulation. Aug. 26. 2008;118(9):961-7. KQ4E2. [pmid: 18697822].
111 European Association for Cardiovascular Prevention & Rehabilitation, Reiner Z, Catapano AL, et al. ESC/EAS Guidelines for the management of dyslipidaemias: the Task Force for the management of dyslipidaemias of the European Society of Cardiology (ESC) and the European Atherosclerosis Society (EAS). European Heart Journal. Jul. 2011;32(14):1769-818. KQ5E6. [pmid: 21712404].
112 Evans CD, Eurich DT, Taylor JG, et al. The Collaborative Cardiovascular Risk Reduction in Primary Care (CCARP) study. Pharmacotherapy. 2010;30:766-75. KQ5E1. [pmid: 20653352].
113 Fabris F, Steffan A, Randi ML, et al. Indobufen versus dipyridamole plus aspirin in the treatment of patients with peripheral atherosclerotic disease. Journal of Medicine. 1992;23:81-92. KQ5E7. [pmid: 1512524].
114 Fagher B. Long-term effects of ticlopidine on lower limb blood flow, ankle/brachial index and symptoms in peripheral arterioschlerosis. Angiology. 1994;45:777-88. KQ5E2a. [pmid: 8092543].
115 Feringa HH, van Waning VH, Bax JJ, et al. Cardioprotective medication is associated with improved survival in patients with peripheral arterial disease. J Am Coll Cardiol. Mar. 21. 2006;47(6):1182-7. KQ4E2a. [pmid: 16545650].
116 Feringa HH, Bax JJ, van Waning VH, et al. The long-term prognostic value of the resting and postexercise ankle-brachial index. Arch Intern Med. Mar. 13. 2006;166(5):529-35. KQ4E5. [pmid: 16534039].
117 Feringa HH, Elhendy A, Karagiannis SE, et al. Improving risk assessment with cardiac testing in peripheral arterial disease. American Journal of Medicine. Jun. 2007;120(6):531-8. KQ4E1. [pmid: 17524756].
118 Feringa HH, Karagiannis SE, Chonchol M, et al. Lower progression rate of end-stage renal disease in patients with peripheral arterial disease using statins or Angiotensin-converting enzyme inhibitors. Journal of the American Society of Nephrology. Jun. 2007;18(6):1872-9. KQ4E2a. [pmid: 17475817].
119 Feringa HH, Bax JJ, Hoeks S, et al. A prognostic risk index for long-term mortality in patients with peripheral arterial disease. Arch Intern Med. Dec. 10. 2007;167(22):2482-9. KQ4E5. [pmid: 18071171].
120 Feringa HH, Karagiannis SE, van Waning VH, et al. The effect of intensified lipid-lowering therapy on long-term prognosis in patients with peripheral arterial disease. Journal of Vascular Surgery. May. 2007;45(5):936-43. KQ5E6b. [pmid: 17360142].
121 Feringa HH, Karagiannis SE, Schouten O, et al. Prognostic significance of declining ankle-brachial index values in patients with suspected or known peripheral arterial disease. European Journal of Vascular & Endovascular Surgery. Aug. 2007;34(2):206-13. KQ4E5. [pmid: 17481930].
122 Fernandez S, Mas R, Gamez R, et al. A pharmacological surveillance study of the tolerability of policosanol in the elderly population. American Journal of Geriatric Pharmacotherapy. Dec. 2004;2(4):219-29. KQ6E7. [pmid: 15903280].
123 Flanigan DP, Ballard JL, Robinson D, et al. Duplex ultrasound of the superficial femoral artery is a better screening tool than ankle-brachial index to identify at risk patients with lower extremity atherosclerosis. Journal of Vascular Surgery. 2008;47(4):789-92. KQ2E5. [pmid: 18280098].
124 Forbes TL. Five-year results of the getABI study. Journal of vascular surgery: official publication, the Society for Vascular Surgery [and] International Society for Cardiovascular Surgery, North American Chapter. 2009;50:221. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6, KQ6E6. [pmid: 19563975].
125 Fowkes FG, Housley E, Cawood EH, et al. Edinburgh Artery Study: prevalence of asymptomatic and symptomatic peripheral arterial disease in the general population. Int J Epidemiol. Jun. 1991;20(2):384-92. KQ4E3. [pmid: 1917239].
126 Fowler B, Jamrozik K, Norman P, et al. Improving maximum walking distance in early peripheral arterial disease: randomised controlled trial. Aust J Physiother. 2002;48(4):269-75. KQ5E7b, KQ6E7b. [pmid: 12443521].
127 Freson K, Van GC. Novel targets for platelet inhibition. Handbook of Experimental Pharmacology. 2012;(210):369-94. KQ5E1. [pmid: 22918739].
128 Fronek A, Coel M, Bernstein EF. The importance of combined multisegmental pressure and Doppler flow velocity studies in the diagnosis of peripheral arterial occlusive disease. Surgery. Dec. 1978;84(6):840-7. KQ2E2a. [pmid: 715702].
129 Futran ND, Stack BC Jr., Zachariah AP. Ankle-arm index as a screening examination for fibula free tissue transfer. Annals of Otology, Rhinology & Laryngology. Aug. 1999;108(8):777-80. KQ2E1. [pmid: 10453786].
130 Galvin K, Webb C, Hillier V. Assessing the impact of a nurse-led health education intervention for people with peripheral vascular disease who smoke: the use of physiological markers, nicotine dependence and withdrawal. International Journal of Nursing Studies. Feb. 2001;38(1):91-105. KQ5E2a. [pmid: 11137727].
131 Gardner AW, Montgomery PS, Parker DE. Physical activity is a predictor of all-cause mortality in patients with intermittent claudication. Journal of Vascular Surgery. Jan. 2008;47(1):117-22. KQ4E2a. [pmid: 18178462].
132 Garg R, Elam MB, Crouse JR III, et al. Effective and safe modification of multiple atherosclerotic risk factors in patients with peripheral arterial disease. Am Heart J. Nov. 2000;140(5):792-803. KQ5E2a. [pmid: 11054628].
133 Giri J, McDermott MM, Greenland P, et al. Statin use and functional decline in patients with and without peripheral arterial disease. J Am Coll Cardiol. Mar. 7. 2006;47(5):998-1004. KQ5E6b. [pmid: 16516084].
134 Giugliano G, Brevetti G, Lanero S, et al. Leukocyte count in peripheral arterial disease: A simple, reliable, inexpensive approach to cardiovascular risk prediction. Atherosclerosis. May. 2010;210(1):288-93. KQ4E2a. [pmid: 19963213].
135 Goessens BM, Visseren FL, Algra A, et al. Screening for asymptomatic cardiovascular disease with noninvasive imaging in patients at high-risk and low-risk according to the European Guidelines on Cardiovascular Disease Prevention: the SMART study. Journal of Vascular Surgery. Mar. 2006;43(3):525-32. KQ6E6. [pmid: 16520167].
136 Goldhaber SZ, Manson JE, Stampfer MJ, et al. Low-dose aspirin and subsequent peripheral arterial surgery in the Physicians' Health Study. Lancet. Jul. 18. 1992;340(8812):143-5. KQ5E1. [pmid: 1352567].
137 Golledge J, Leicht A, Crowther RG, et al. Association of obesity and metabolic syndrome with the severity and outcome of intermittent claudication. Journal of Vascular Surgery. Jan. 2007;45(1):40-6. KQ4E2a. [pmid: 17123770].
138 Gomez-Marcos MA, Recio-Rodriguez JI, Rodriguez-Sanchez E, et al. Central blood pressure and pulse wave velocity: relationship to target organ damage and cardiovascular morbidity-mortality in diabetic patients or metabolic syndrome. An observational prospective study. LOD-DIABETES study protocol. BMC Public Health. 2010;10:143. KQ4E2b. [pmid: 20298558].
139 Gomez Marcos MA, Gonzalez-Elena LJ, Recio-Rodriguez JI, et al. Cardiovascular risk assessment in hypertensive patients with tests recommended by the European Guidelines on Hypertension. Eur J Cardiovasc Prev Rehabil. 2011. Mar. 10. KQ4E3. [pmid: 21450575].
140 Gornik HL, Garcia B, Wolski K, et al. Validation of a method for determination of the ankle-brachial index in the seated position. J Vasc Surg. Nov. 2008;48(5):1204-10. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 18829231].
141 Greenhalgh J, Bagust A, Boland A, et al. Clopidogrel and modified-release dipyridamole for the prevention of occlusive vascular events (review of Technology Appraisal No. 90): a systematic review and economic analysis. Health Technology Assessment (Winchester, England). Sep. 2011;15(31):1-178. KQ5E6. [pmid: 21888837].
142 Greenspan K, Lawrence PF, Esposito DB, et al. The role of biofeedback and relaxation therapy in arterial occlusive disease. J Surg Res. 1980;29:387-94. KQ5E2a. [pmid: 7421183].
143 Grodzinska L, Starzyk D, Bieron K, et al. Simvastatin effects in normo- and hypercholesterolaemic patients with peripheral arterial occlusive disease: a pilot study. Basic & Clinical Pharmacology & Toxicology. Jun. 2005;96(6):413-9. KQ5E6b. [pmid: 15910404].
144 Grondal N, Sogaard R, Henneberg EW, et al. The Viborg Vascular (VIVA) screening trial of 65-74 year old men in the central region of Denmark: study protocol. Trials. 2010;11:67. KQ1E3. [pmid: 20507582].
145 Guan H, Wang Y, Zhang B, et al. Comparison of beraprost and ticlopidine in chinese patients with chronic peripheral arterial occlusion: a multicenter, single-blind, randomized, controlled study. Current Therapeutic Research, Clinical & Experimental. 2003;64:488-503. KQ5E2a.
146 Guldager B, Jelnes R, Jųrgensen SJ, et al. EDTA treatment of intermittent claudication--a double-blind, placebo-controlled study. Journal of Internal Medicine. 1992;231:261-7. KQ5E2a. [pmid: 1556523].
147 Guo X, Li J, Pang W, et al. Sensitivity and specificity of ankle-brachial index for detecting angiographic stenosis of peripheral arteries. Circ J. Apr. 2008;72(4):605-10. KQ2E2a, KQ3E2a. [pmid: 18362433].
148 Harker LA, Boissel JP, Pilgrim AJ, et al. Comparative safety and tolerability of clopidogrel and aspirin: results from CAPRIE. CAPRIE Steering Committee and Investigators. Clopidogrel versus aspirin in patients at risk of ischaemic events. Drug Safety. Oct. 1999;21(4):325-35. KQ6E2a. [pmid: 10514023].
149 Hathial M. Safety and tolerability of ramipril 10 mg in patients at high risk of cardiovascular events: an observational study. Journal of the Indian Medical Association. 2008;106(7):468-70. KQ6E1. [pmid: 18975506].
150 Hathial M. Safety and tolerability of ramipril 10 mg in patients at high risk of cardiovascular events: an observational study. Indian Heart Journal. May. 2008;60(3):200-4. KQ6E2. [pmid: 19240307].
151 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. [Summary for patients in Curr Cardiol Rep. 2002 Nov;4(6):486-7; PMID: 12379169]. Lancet. Jul. 6. 2002;360(9326):7-22. KQ5E2a. [pmid: 12114036].
152 Heart Protection Study Collaborative Group. Randomized trial of the effects of cholesterol-lowering with simvastatin on peripheral vascular and other major vascular outcomes in 20,536 people with peripheral arterial disease and other high-risk conditions. Journal of Vascular Surgery. Apr. 2007;45(4):645-54. KQ5E2a. [pmid: 17398372].
153 Hennrikus D, Joseph AM, Lando HA, et al. Effectiveness of a smoking cessation program for peripheral artery disease patients: a randomized controlled trial. J Am Coll Cardiol. Dec. 14. 2010;56(25):2105-12. KQ5E2a, KQ6E2a. [pmid: 21144971].
154 Hess H, Mietaschk A, Deichsel G. Drug-induced inhibition of platelet function delays progression of peripheral occlusive arterial disease. A prospective double-blind arteriographically controlled trial. Lancet. Feb. 23. 1985;1(8426):415-9. KQ5E3, KQ6E3. [pmid: 2857803].
155 Hiatt WR, Wolfel EE, Meier RH, et al. Superiority of treadmill walking exercise versus strength training with patients with peripheral arterial disease. Implications for the mechanism of the training response. Circulation. 1994;90:1866-74. KQ5E2a. [pmid: 7923674].
156 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Engl J Med. May. 24. 2001;344(21):1608-21. KQ5E6, KQ6E6. [pmid: 11372014].
157 Hiatt WR, Goldstone J, Smith SC Jr., et al. Atherosclerotic Peripheral Vascular Disease Symposium II: nomenclature for vascular diseases. Circulation. Dec. 16. 2008;118(25):2826-9. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 19106403].
158 Hirsch AT, Criqui MH, Treat-Jacobson D, et al. Peripheral arterial disease detection, awareness, and treatment in primary care. JAMA. Sep. 19. 2001;286(11):1317-24. KQ2E4c, KQ3E4c. [pmid: 11560536].
159 Hirsch AT, Hartman L, Town RJ, et al. National health care costs of peripheral arterial disease in the Medicare population. Vascular Medicine. 2008;13(3):209-15. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 18687757].
160 Hoekstra JBL, Erkelens DW. Erratum: A double-BLIND, multicenter, PLACEBO-CONTROLled, dose COMPARison study of orally administered defibrotide: Preliminary results in patients with peripheral arterial disease. (Seminars in Thrombosis and Hemostasis (1991) Volume 17 (228-234)). SEMIN THROMB HEMOST. 1991;17:486. KQ5E7.
161 Hoogerbrugge N, de GE, de Heide LH, et al. Doxazosin and hydrochlorothiazide equally affect arterial wall thickness in hypertensive males with hypercholesterolaemia (the DAPHNE study). Doxazosin Atherosclerosis Progression Study in Hypertensives in the Netherlands. Neth J Med. Oct. 2002;60(9):354-61. KQ5E2a, KQ6E2a. [pmid: 12572707].
162 Hooi JD, Stoffers HE, Kester AD, et al. Peripheral arterial occlusive disease: prognostic value of signs, symptoms, and the ankle-brachial pressure index. Med Decis Making. Mar. 2002;22(2):99-107. KQ4E6e. [pmid: 11958503].
163 Hooi JD, Kester AD, Stoffers HE, et al. Asymptomatic peripheral arterial occlusive disease predicted cardiovascular morbidity and mortality in a 7-year follow-up study. J Clin Epidemiol. Mar. 2004;57(3):294-300. KQ4E6e. [pmid: 15066690].
164 HOPE STUDY INVESTIGATORS. The HOPE (Heart Outcomes Prevention Evaluation) Study: the design of a large, simple randomized trial of an angiotensin-converting enzyme inhibitor (ramipril) and vitamin E in patients at high risk of cardiovascular events. The HOPE study investigators. Can J Cardiol. Feb. 1996;12(2):127-37. KQ5E2a, KQ6E2a. [pmid: 8605634].
165 Hsia J, Criqui MH, Rodabough RJ, et al. Estrogen plus progestin and the risk of peripheral arterial disease: the Women's Health Initiative. Circulation. 2004;109:620-6. KQ5E7. [pmid: 14769684].
166 Hsia J, Criqui MH, Herrington DM, et al. Conjugated equine estrogens and peripheral arterial disease risk: The Women's Health Initiative. Am Heart J. 2006;152:170-6. KQ5E7. [pmid: 16824852].
167 Hummel BW, Hummel BA, Mowbry A, et al. Reactive hyperemia vs treadmill exercise testing in arterial disease. Arch Surg. Jan. 1978;113(1):95-8. KQ2E6, KQ3E6. [pmid: 619865].
168 Ingelsson E, Sullivan LM, Fox CS, et al. Burden and prognostic importance of subclinical cardiovascular disease in overweight and obese individuals. Circulation. Jul. 24. 2007;116(4):375-84. KQ4E6e. [pmid: 17620505].
169 Ishikawa Y, Yokoyama M, Saito Y, et al. Preventive effects of eicosapentaenoic acid on coronary artery disease in patients with peripheral artery disease. Circulation journal: official journal of the Japanese Circulation Society. 2010;74:1451-7. KQ5E2a. [pmid: 20484828].
170 Itaya H, Shiba M, Joki N, et al. Combined assessment of chronic kidney disease and subclinical peripheral artery disease used to predict future cardiac events. Nephrology. Mar. 2010;15(2):230-5. KQ4E2b. [pmid: 20470284].
171 Jackson SA, Burke GL, Thach C, et al. Incidence and predictors of coronary heart disease among older African Americans--the Cardiovascular Health Study. Journal of the National Medical Association. Nov. 2001;93(11):423-9. KQ4E6e. [pmid: 11730114].
172 Jaffery Z, Greenbaum AB, Siddiqui MF, et al. Predictors of mortality in patients with lower extremity peripheral arterial disease: 5-year follow-up. Journal of Interventional Cardiology. Dec. 2009;22(6):564-70. KQ4E2. [pmid: 19780889].
173 Jager A, Kostense PJ, Ruhe HG, et al. Microalbuminuria and peripheral arterial disease are independent predictors of cardiovascular and all-cause mortality, especially among hypertensive subjects: five-year follow-up of the Hoorn Study. Arteriosclerosis, Thrombosis & Vascular Biology. Mar. 1999;19(3):617-24. KQ4E7a. [pmid: 10073965].
174 Jahromi AS, Clase CM, Maggisano R, et al. Progression of internal carotid artery stenosis in patients with peripheral arterial occlusive disease. Journal of Vascular Surgery. Aug. 2009;50(2):292-8. KQ4E5. [pmid: 19631863].
175 Jaquinandi V, Mahe G, Noury B. Letter by Jaquinandi et al regarding article, “Different calculations of ankle-brachial index and their impact on cardiovascular risk prediction”. Circulation. May. 12. 2009;119(18):e527. KQ4E6. [pmid: 19433764].
176 Jeon CH, Han SH, Chung NS, et al. The validity of ankle-brachial index for the differential diagnosis of peripheral arterial disease and lumbar spinal stenosis in patients with atypical claudication. Eur Spine J. 2011. Nov. 22. KQ2E5, KQ3E5. [pmid: 22105308].
177 Joensen JB, Juul S, Henneberg E, et al. Can long-term antibiotic treatment prevent progression of peripheral arterial occlusive disease? A large, randomized, double-blinded, placebo-controlled trial. Atherosclerosis. 2008;196:937-42. KQ5E7. [pmid: 17418218].
178 Johnson W, Price JF, Rafnsson SB, et al. Ankle--brachial index predicts level of, but not change in, cognitive function: the Edinburgh Artery Study at the 15-year follow-up. Vascular Medicine. Apr. 2010;15(2):91-7. KQ4E3. [pmid: 20147579].
179 Jonsson B, Skau T. Ankle-brachial index and mortality in a cohort of questionnaire recorded leg pain on walking. European Journal of Vascular & Endovascular Surgery. Nov. 2002;24(5):405-10. KQ4E2a. [pmid: 12435339].
180 Kang Y, Lee J, Kwon K, et al. Dynamic fluorescence imaging of indocyanine green for reliable and sensitive diagnosis of peripheral vascular insufficiency. Microvascular Research. Dec. 2010;80(3):552-5. KQ2E6a. [pmid: 20637783].
181 Kannel WB. Risk factors for atherosclerotic cardiovascular outcomes in different arterial territories. J Cardiovasc Risk. Dec. 1994;1(4):333-9. KQ4E1. [pmid: 7621317].
182 Karthikeyan VJ, Lip GY. Peripheral artery disease and hypertension: the relation between ankle-brachial index and mortality. Journal of Human Hypertension. Oct. 2007;21(10):762-5. KQ4E6. [pmid: 17508016].
183 Khandanpour N, Armon MP, Jennings B, et al. Folate supplementation improves arterial function in patients with peripheral arterial disease: a randomised double-blind, placebo-controlled clinical trial. The Vascular Society of Great Britain & Ireland Yearbook. 2008;2008:81. KQ5E7.
184 Khandanpour N, Armon MP, Jennings B, et al. Randomized clinical trial of folate supplementation in patients with peripheral arterial disease. The British Journal of Surgery. 2009;96:990-8. KQ5E7, KQ6E7. [pmid: 19672935].
185 Kim ES, Wattanakit K, Gornik HL. Using the ankle-brachial index to diagnose peripheral artery disease and assess cardiovascular risk. Cleveland Clinic Journal of Medicine. Sep. 2012;79(9):651-61. KQ4E6. [pmid: 22949346].
186 Kimose HH, Bagger JP, Aagaard MT, et al. Placebo-controlled, double-blind study of the effect of verapamil in intermittent claudication. Angiology. 1990;41:595-8. KQ5E2a. [pmid: 2202231].
187 Kollar L, Menyhei G, Kasza G, et al. Assessement of Nashwan-ParasoundPLUS device for the treatment of patients suffering from Fontaine stage II infrainguinal arterial disease - a prospective, double-blind, crossover study. Perfusion. 2009;22:4-8. KQ4E1.
188 Korhonen PE, Vesalainen RK, Aarnio PT, et al. The assessment of total cardiovascular risk in hypertensive subjects in primary care. Annals of Medicine. Apr. 2010;42(3):187-95. KQ4E3. [pmid: 20350256].
189 Korhonen P, Vesalainen R, Aarnio P, et al. Assessment of cardiovascular risk in primary health care. Scandinavian Journal of Primary Health Care. Jun. 2012;30(2):101-6. KQ4E6e. [pmid: 22643155].
190 Kornitzer M, Dramaix M, Sobolski J, et al. Ankle/arm pressure index in asymptomatic middle-aged males: an independent predictor of ten-year coronary heart disease mortality. Angiology. Mar. 1995;46(3):211-9. KQ4E6e. [pmid: 7879961].
191 Kravos A, Bubnic-Sotosek K. Ankle-brachial index screening for peripheral artery disease in asymptomatic patients between 50 and 70 years of age. Journal of International Medical Research. Sep. 2009;37(5):1611-9. KQ2E4c, KQ3E4c. [pmid: 19930870].
192 Kroon AA, van Asten WN, Stalenhoef AF. Effect of apheresis of low-density lipoprotein on peripheral vascular disease in hypercholesterolemic patients with coronary artery disease. Annals of Internal Medicine. Dec. 15. 1996;125(12):945-54. KQ5E2b. [pmid: 8967704].
193 Kuller LH, Shemanski L, Psaty BM, et al. Subclinical disease as an independent risk factor for cardiovascular disease. Circulation. Aug. 15. 1995;92(4):720-6. KQ4E1. [pmid: 7641349].
194 Kwon JN, Lee WB. Utility of digital pulse oximetry in the screening of lower extremity arterial disease. Journal of The Korean Surgical Society. Feb. 2012;82(2):94-100. KQ2E2a. [pmid: 22347711].
195 Labropoulos N, Wierks C, Suffoletto B. Intermittent pneumatic compression for the treatment of lower extremity arterial disease: a systematic review. Vascular Medicine. 2002;7:141-8. KQ5E7. [pmid: 12402994].
196 Lacroix P, Aboyans V, Espaliat E, et al. Carotid intima-media thickness as predictor of secondary events after coronary angioplasty. International Angiology. Sep. 2003;22(3):279-83. KQ4E2b. [pmid: 14612855].
197 Lane DA, Lip GY. Treatment of hypertension in peripheral arterial disease. [Update of Cochrane Database Syst Rev. 2003;(4):CD003075; PMID: 14583959]. Cochrane Database of Systematic Reviews. 2009;(4):CD003075. KQ5E2a. [pmid: 19821300].
198 Lange S, Trampisch HJ, Haberl R, et al. Excess 1-year cardiovascular risk in elderly primary care patients with a low ankle-brachial index (ABI) and high homocysteine level. Atherosclerosis. Feb. 2005;178(2):351-7. KQ4E6e. [pmid: 15694945].
199 Lange SF, Trampisch HJ, Pittrow D, et al. Profound influence of different methods for determination of the ankle brachial index on the prevalence estimate of peripheral arterial disease. BMC Public Health. 2007;7:147. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 18293542].
200 LaRosa JC, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. JAMA. Dec. 22. 1999;282(24):2340-6. KQ5E1. [pmid: 10612322].
201 Laurent S, Becquemont L, Laloux X, et al. Improvement of arterial compliance by a converting enzyme inhibitor in patients with lower extremities arterial disease. Arch Mal Coeur Vaiss. 1994;87:987-90. KQ5E4b. [pmid: 7755478].
202 Laurin D, Masaki KH, White LR, et al. Ankle-to-brachial index and dementia: the Honolulu-Asia Aging Study. Circulation. Nov. 13. 2007;116(20):2269-74. KQ4E3. [pmid: 17967779].
203 Leng GC, Fowkes FG. The Edinburgh Claudication Questionnaire: an improved version of the WHO/Rose Questionnaire for use in epidemiological surveys. J Clin Epidemiol. Oct. 1992;45(10):1101-9. KQ2E7a, KQ3E7a. [pmid: 1474406].
204 Leng GC, Fowkes FG, Lee AJ, et al. Use of ankle brachial pressure index to predict cardiovascular events and death: a cohort study. BMJ. Dec. 7. 1996;313(7070):1440-4. kQ4E6e. [pmid: 8973232].
205 Leng GC, Lee AJ, Fowkes FG, et al. Incidence, natural history and cardiovascular events in symptomatic and asymptomatic peripheral arterial disease in the general population. Int J Epidemiol. Dec. 1996;25(6):1172-81. KQ4E1. [pmid: 9027521].
206 Leng GC, Lee AJ, Fowkes FG, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clinical Nutrition. 1998;17:265-71. KQ5E7. [pmid: 10205349].
207 Leng GC, Papacosta O, Whincup P, et al. Femoral atherosclerosis in an older British population: prevalence and risk factors. Atherosclerosis. Sep. 2000;152(1):167-74. KQ2E7a, KQ3E7a, KQ4E7a. [pmid: 10996352].
208 Lepäntalo M, Sundberg S, Gordin A. The effects of physical training and flunarizine on walking capacity in intermittent claudication. Scandinavian Journal of Rehabilitation Medicine. 1984;16:159-62. KQ5E2a. [pmid: 6397852].
209 Lewis RJ, Connor JT, Teerlink JR, et al. Application of adaptive design and decision making to a phase II trial of a phosphodiesterase inhibitor for the treatment of intermittent claudication. Trials. 2011;12:134. KQ5E2a. [pmid: 21612611].
210 Li J, Luo Y, Xu Y, et al. Risk factors of peripheral arterial disease and relationship between low ankle - brachial index and mortality from all-cause and cardiovascular disease in Chinese patients with type 2 diabetes. Circulation Journal. Mar. 2007;71(3):377-81. KQ4E2b. [pmid: 17322639].
211 Li X, Luo Y, Xu Y, et al. Relationship of ankle-brachial index with all-cause mortality and cardiovascular mortality after a 3-year follow-up: the China ankle-brachial index cohort study. Journal of Human Hypertension. Feb. 2010;24(2):111-6. KQ4E2. [pmid: 19516270].
212 Libby P, Ridker PM, Hansson GK. Progress and challenges in translating the biology of atherosclerosis. Nature. May. 19. 2011;473(7347):317-25. KQ5E6, KQ6E6. [pmid: 21593864].
213 Libretti A, Catalano M. Treatment of claudication with dipyridamole and aspirin. International Journal of Clinical Pharmacology Research. 1986;6:59-60. KQ5E2a. [pmid: 3514494].
214 Lievre M, Cucherat M. Aspirin in the secondary prevention of cardiovascular disease: an update of the APTC meta-analysis. Fundamental & Clinical Pharmacology. Jun. 2010;24(3):385-91. KQ5E2a, KQ6E2a. [pmid: 19678849].
215 Liew YP, Bartholomew JR, Demirjian S, et al. Combined effect of chronic kidney disease and peripheral arterial disease on all-cause mortality in a high-risk population. Clinical Journal of The American Society of Nephrology: CJASN. Jul. 2008;3(4):1084-9. KQ4E2. [pmid: 18337552].
216 Lijmer JG, Hunink MG, van den Dungen JJ, et al. ROC analysis of noninvasive tests for peripheral arterial disease. Ultrasound Med Biol. 1996;22(4):391-8. KQ2E5, KQ3E5. [pmid: 8795165].
217 Lim LS, Haq N, Mahmood S, et al. Atherosclerotic cardiovascular disease screening in adults: American College Of Preventive Medicine position statement on preventive practice. Am J Prev Med. Mar. 2011;40(3):381-10. KQ4E6. [pmid: 21335273].
218 Lindner JR, Womack L, Barrett EJ, et al. Limb stress-rest perfusion imaging with contrast ultrasound for the assessment of peripheral arterial disease severity. Jacc: Cardiovascular Imaging. May. 2008;1(3):343-50. KQ2E1. [pmid: 19356447].
219 Longstreth WT Jr., Dulberg C, Manolio TA, et al. Incidence, manifestations, and predictors of brain infarcts defined by serial cranial magnetic resonance imaging in the elderly: the Cardiovascular Health Study. Stroke. Oct. 2002;33(10):2376-82. KQ4E6e. [pmid: 12364724].
220 Loponen P, Taskinen P, Laakkonen E, et al. Peripheral vascular disease as predictor of outcome after coronary artery bypass grafting. Scandinavian Journal of Surgery: SJS. 2002;91(2):160-5. KQ4E2b. [pmid: 12164516].
221 Lowrie R, Morrison J, McConnachie A. A cluster randomised controlled trial of pharmacist led statin outreach support (SOS) in primary care: design and baseline characteristics. Contemporary Clinical Trials. Jul. 2010;31(4):303-11. KQ5E1. [pmid: 20348032].
222 Lundgren F, Dahllöf AG, Lundholm K, et al. Intermittent claudication--surgical reconstruction or physical training? A prospective randomized trial of treatment efficiency. Annals of Surgery. 1989;209:346-55. KQ5E2a. [pmid: 2647051].
223 Lundgren F, Dahllöf AG, Scherstén T, et al. Muscle enzyme adaptation in patients with peripheral arterial insufficiency: spontaneous adaptation, effect of different treatments and consequences on walking performance. Clinical Science. 1989;77:485-93. KQ5E1. [pmid: 2555105].
224 Luo Y, Li X, Li J, et al. Peripheral arterial disease, chronic kidney disease, and mortality: the Chinese Ankle Brachial Index Cohort Study. Vascular Medicine. Apr. 2010;15(2):107-12. KQ4E2. [pmid: 20133341].
225 Luo YY, Li J, Xin Y, et al. Risk factors of peripheral arterial disease and relationship between low ankle brachial index and mortality from all-cause and cardiovascular disease in Chinese patients with hypertension. Journal of Human Hypertension. Jun. 2007;21(6):461-6. KQ4E2b. [pmid: 17344909].
226 Mahoney EM, Wang K, Keo HH, et al. Vascular hospitalization rates and costs in patients with peripheral artery disease in the United States. Circ Cardiovasc Qual Outcomes. Nov. 2010;3(6):642-51. KQ4E6e. [pmid: 20940249].
227 Mannarino E, Pasqualini L, Innocente S, et al. Physical training and antiplatelet treatment in stage II peripheral arterial occlusive disease: alone or combined?. Angiology. Jul. 1991;42(7):513-21. KQ5E2a. [pmid: 1863010].
228 Manzano L, Mostaza JM, Suarez C, et al. Prognostic value of the ankle-brachial index in elderly patients with a stable chronic cardiovascular event. Journal of Thrombosis & Haemostasis. Jun. 2010;8(6):1176-84. KQ4E2b. [pmid: 20230414].
229 Marelli C, Belcaro G, Girardello R. Defibrotide in patients with intermittent claudication. Improvement in blood flow, fibrinolytic activity, and macrocirculation after six months of treatment. Curr Ther Res Clin Exp. 1990;47:459-65. KQ5E7.
230 Margolis J, Barron JJ, Grochulski WD. Health care resources and costs for treating peripheral artery disease in a managed care population: results from analysis of administrative claims data. J Manag Care Pharm. Dec. 2005;11(9):727-34. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 16300416].
231 Marrapodi E, Leanza D, Giordano S, et al. Effects of defibrotide on physical performance and hemorheologic picture in patients with peripheral arteriopathy. Clinical Trials & Meta-Analysis. Apr. 1994;29(1):21-30. KQ5E7. [pmid: 10150182].
232 Marso SP, Hiatt WR. Peripheral arterial disease in patients with diabetes. J Am Coll Cardiol. Mar. 7. 2006;47(5):921-9. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6, KQ6E6. [pmid: 16516072].
233 Marti R, Parramon D, Garcia-Ortiz L, et al. Improving interMediAte risk management. MARK study. BMC Cardiovascular Disorders. 2011;11:61. KQ4E6. [pmid: 21992621].
234 Mayfield JA, Reiber GE, Sanders LJ, et al. Preventive foot care in diabetes. Diabetes Care. Jan. Suppl 1. 2004;27:S63-S64. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 14693928].
235 Mazoyer E, Drouet L, Soria C, et al. Risk factors and outcomes for atherothrombotic disease in French patients: the RIVAGE study. RIsque VAsculaire Group d'Etude. Thrombosis Research. 1999;95:163-76. KQ4E2. [pmid: 10498386].
236 McDermott MM, Feinglass J, Slavensky R, et al. The ankle-brachial index as a predictor of survival in patients with peripheral vascular disease. Journal of General Internal Medicine. Aug. 1994;9(8):445-9. KQ4E5. [pmid: 7965239].
237 McDermott MM, Mehta S, Greenland P. Exertional leg symptoms other than intermittent claudication are common in peripheral arterial disease. Arch Intern Med. Feb. 22. 1999;159(4):387-92. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 10030313].
238 McDermott MM, Greenland P, Liu K, et al. Leg symptoms in peripheral arterial disease: associated clinical characteristics and functional impairment. JAMA. Oct. 3. 2001;286(13):1599-606. KQ2E4c, KQ3E4c. [pmid: 11585483].
239 McDermott MM, Liu K, Criqui MH, et al. Ankle-brachial index and subclinical cardiac and carotid disease: the multi-ethnic study of atherosclerosis. Am J Epidemiol. Jul. 1. 2005;162(1):33-41. KQ4E1. [pmid: 15961584].
240 McDermott MM, Tian L, Liu K, et al. Prognostic value of functional performance for mortality in patients with peripheral artery disease. J Am Coll Cardiol. Apr. 15. 2008;51(15):1482-9. KQ4E2. [pmid: 18402904].
241 McDermott MM, Liu K, Carroll TJ, et al. Superficial femoral artery plaque and functional performance in peripheral arterial disease: walking and leg circulation study (WALCS III). Jacc: Cardiovascular Imaging. Jul. 2011;4(7):730-9. KQ2E5. [pmid: 21757163].
242 McDermott MM, Ades P, Guralnik JM, et al. Treadmill exercise and resistance training in patients with peripheral arterial disease with and without intermittent claudication: a randomized controlled trial. JAMA. Jan. 14. 2009;301(2):165-74. KQ5E7b, KQ6E7b. [pmid: 19141764].
243 McDermott MM. Peripheral arterial disease: epidemiology and drug therapy. Am J Geriatr Cardiol. Aug. 2002;11(4):258-66. KQ2E6, KQ3E6, KQ5E6, KQ6E6. [pmid: 12091774].
244 McDermott MM, Guralnik JM, Greenland P, et al. Statin use and leg functioning in patients with and without lower-extremity peripheral arterial disease. Circulation. Feb. 11. 2003;107(5):757-61. KQ5E6b, KQ6E6b. [pmid: 12578881].
245 McKenna M, Wolfson S, Kuller L. The ratio of ankle and arm arterial pressure as an independent predictor of mortality. Atherosclerosis. Apr. 1991;87(2-3):119-28. KQ4E5. [pmid: 1854359].
246 McQuaid KR, Laine L. Systematic review and meta-analysis of adverse events of low-dose aspirin and clopidogrel in randomized controlled trials. Am J Med. Aug. 2006;119(8):624-38. KQ6E1. [pmid: 16887404].
247 Meijer WT, Hoes AW, Rutgers D, et al. Peripheral arterial disease in the elderly: The Rotterdam Study. Arterioscler Thromb Vasc Biol. Feb. 1998;18(2):185-92. KQ4E3. [pmid: 9484982].
248 Meijer WT, Grobbee DE, Hunink MG, et al. Determinants of peripheral arterial disease in the elderly: the Rotterdam study. Arch Intern Med. Oct. 23. 2000;160(19):2934-8. KQ4E3. [pmid: 11041900].
249 Menke A, Muntner P, Wildman RP, et al. Relation of borderline peripheral arterial disease to cardiovascular disease risk. American Journal of Cardiology. Nov. 1. 2006;98(9):1226-30. KQ4E3. [pmid: 17056334].
250 Merino J, Planas A, De MA, et al. The association of peripheral arterial occlusive disease with major coronary events in a mediterranean population with low coronary heart disease incidence. European Journal of Vascular & Endovascular Surgery. Jul. 2008;36(1):71-6. KQ4E6e. [pmid: 18396072].
251 Messa GL, Gelso E. Heparan sulfate in the treatment of intermittent claudication: results of a randomized, double-blind, placebo-controlled multicenter trial. Drugs Under Experimental and Clinical Research. 2002;28:37-48. KQ5E2a. [pmid: 12073766].
252 Meves SH, Diehm C, Berger K, et al. Peripheral arterial disease as an independent predictor for excess stroke morbidity and mortality in primary-care patients: 5-year results of the getABI study. Cerebrovasc Dis. 2010;29(6):546-54. KQ4E6e. [pmid: 20375496].
253 Mittalhenkle A, Stehman-Breen CO, Shlipak MG, et al. Cardiovascular risk factors and incident acute renal failure in older adults: the cardiovascular health study. Clinical Journal of The American Society of Nephrology: CJASN. Mar. 2008;3(2):450-6. KQ4E1. [pmid: 18256380].
254 Mohler ER III, Treat-Jacobson D, Reilly MP, et al. Utility and barriers to performance of the ankle-brachial index in primary care practice. Vasc Med. Nov. 2004;9(4):253-60. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 15678616].
255 Mondillo S, Ballo P, Barbati R, et al. Effects of simvastatin on walking performance and symptoms of intermittent claudication in hypercholesterolemic patients with peripheral vascular disease. American Journal of Medicine. Apr. 1. 2003;114(5):359-64. KQ5E2a. [pmid: 12714124].
256 Morrow DA, Scirica BM, Fox KA, et al. Evaluation of a novel antiplatelet agent for secondary prevention in patients with a history of atherosclerotic disease: design and rationale for the Thrombin-Receptor Antagonist in Secondary Prevention of Atherothrombotic Ischemic Events (TRA 2 degrees P)-TIMI 50 trial. Am Heart J. Sep. 2009;158(3):335-41. KQ5E2a. [pmid: 19699854].
257 Morrow DA, Braunwald E, Bonaca MP, et al. Vorapaxar in the secondary prevention of atherothrombotic events. New England Journal of Medicine. Apr. 12. 2012;366(15):1404-13. KQ5E2a. [pmid: 22443427].
256 Mosca L, Barrett-Connor E, Wenger NK, et al. Design and methods of the Raloxifene Use for The Heart (RUTH) study. American Journal of Cardiology. Aug. 15. 2001;88(4):392-5. KQ5E2. [pmid: 11545760].
257 Mourad JJ, Cacoub P, Collet JP, et al. Screening of unrecognized peripheral arterial disease (PAD) using ankle-brachial index in high cardiovascular risk patients free from symptomatic PAD. Journal of Vascular Surgery. Sep. 2009;50(3):572-80. KQ4E5. [pmid: 19560312].
258 Muntendam P, McCall C, Sanz J, et al. The BioImage Study: novel approaches to risk assessment in the primary prevention of atherosclerotic cardiovascular disease--study design and objectives. Am Heart J. 2010;160:49-57. KQ4E1. [pmid: 20598972].
259 Murabito JM, Evans JC, Larson MG, et al. The ankle-brachial index in the elderly and risk of stroke, coronary disease, and death: the Framingham Study. Arch Intern Med. Sep. 8. 2003;163(16):1939-42. KQ4E6e, X4. [pmid: 12963567].
260 Nam SC, Han SH, Lim SH, et al. Factors affecting the validity of ankle-brachial index in the diagnosis of peripheral arterial obstructive disease. Angiology. May. 2010;61(4):392-6. KQ2E2a. [pmid: 19759029].
261 Newman AB, Sutton-Tyrrell K, Vogt MT, et al. Morbidity and mortality in hypertensive adults with a low ankle/arm blood pressure index. JAMA. Jul. 28. 1993;270(4):487-9. KQ4E6e. [pmid: 8147959].
262 Newman AB, Tyrrell KS, Kuller LH. Mortality over four years in SHEP participants with a low ankle-arm index. Journal of the American Geriatrics Society. Dec. 1997;45(12):1472-8. KQ4E6e. [pmid: 9400557].
263 Newman AB, Shemanski L, Manolio TA, et al. Ankle-arm index as a predictor of cardiovascular disease and mortality in the Cardiovascular Health Study. The Cardiovascular Health Study Group. Arteriosclerosis, Thrombosis & Vascular Biology. Mar. 1999;19(3):538-45. KQ4E6e. [pmid: 10073955].
264 Nexoe J, Damsbo B, Lund JO, et al. Measurement of blood pressure, ankle blood pressure and calculation of ankle brachial index in general practice. Fam Pract. 2011. Oct. 23. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4, KQ6E4. [pmid: 22024665].
265 Niazi K, Khan TH, Easley KA. Diagnostic utility of the two methods of ankle brachial index in the detection of peripheral arterial disease of lower extremities. Catheter Cardiovasc Interv. Nov. 2006;68(5):788-92. KQ2E5, KQ3E5. [pmid: 17039537].
266 Nicolai SP, Kruidenier LM, Rouwet EV, et al. Ankle brachial index measurement in primary care: are we doing it right?. British Journal of General Practice. Jun. 2009;59(563):422-7. KQ2E4c. [pmid: 19520025].
267 Nilsson S, Kaijser L, Erikson U, et al. Correlation between computer-assisted femoral arteriography and physiological tests in hypercholesterolaemic patients: a methodological study with special reference to clinical trials. Clinical Physiology. Jan. 1992;12(1):53-68. KQ2E3. [pmid: 1541084].
268 Ogren M, Hedblad B, Isacsson SO, et al. Non-invasively detected carotid stenosis and ischaemic heart disease in men with leg arteriosclerosis. Lancet. Nov. 6. 1993;342(8880):1138-41. KQ4E6e. [pmid: 7901475].
269 Ogren M, Hedblad B, Jungquist G, et al. Low ankle-brachial pressure index in 68-year-old men: prevalence, risk factors and prognosis. Results from prospective population study “Men born in 1914”, Malmo, Sweden. European Journal of Vascular Surgery. Sep. 1993;7(5):500-6. KQ4E6e. [pmid: 8405492].
270 Oka RK, Umoh E, Szuba A, et al. Suboptimal intensity of risk factor modification in PAD. Vascular Medicine. May. 2005;10(2):91-6. KQ5E2a. [pmid: 16013192].
271 Oka RK, Conte MS, Owens CD, et al. Efficacy of optimal long-term management of multiple cardiovascular risk factors (CVD) on walking and quality of life in patients with peripheral artery disease (PAD): protocol for randomized controlled trial. Vascular Medicine. 2012;17(1):17-28. KQ5E2a. [pmid: 22363015].
272 Osinbowale OO, Milani RV. Benefits of exercise therapy in peripheral arterial disease. Prog Cardiovasc Dis. Jun. 2011;53(6):447-53. KQ5E6, KQ6E6. [pmid: 21545931].
273 Ostergren J, Sleight P, Dagenais G, et al. Impact of ramipril in patients with evidence of clinical or subclinical peripheral arterial disease. European Heart Journal. 2004;25:17-24. KQ5E2b, KQ6E2b. [pmid: 14683738].
274 Ostergren JB, Pogue J, Sleight P, et al. Ankle-brachial blood pressure index is a strong predictor for mortality and cardiovascular events: results from the HOPE-trial. J Am Coll Cardiol. 2001;37:277A. KQ4E6.
275 Ouriel K, McDonnell AE, Metz CE, et al. Critical evaluation of stress testing in the diagnosis of peripheral vascular disease. Surgery. Jun. 1982;91(6):686-93. KQ2E6a. [pmid: 7079971].
276 Ouriel K, Zarins CK. Doppler ankle pressure: an evaluation of three methods of expression. Archives of Surgery. Oct. 1982;117(10):1297-300. KQ2E6. [pmid: 7125893].
277 Paikin JS, Wright DS, Eikelboom JW. Effectiveness and safety of combined antiplatelet and anticoagulant therapy: a critical review of the evidence from randomized controlled trials. Blood Reviews. May. 2011;25(3):123-9. KQ5E2a. [pmid: 21354678].
278 Palmieri G, Ambrosi G, Agrati AM, et al. A new low molecular weight heparin in the treatment of peripheral arterial disease. International angiology: a journal of the International Union of Angiology. 1988;7:41-7. KQ5E2a. [pmid: 2850326].
279 Panchenko E, Eshkeeva A, Dobrovolsky A, et al. Effects of indobufen and pentoxifylline on walking capacity and hemostasis in patients with intermittent claudication: results of six months of treatment. Angiology. Mar. 1997;48(3):247-54. KQ5E7. [pmid: 9071201].
280 Pande RL, Perlstein TS, Beckman JA, et al. Secondary prevention and mortality in peripheral artery disease: National Health and Nutrition Examination Study, 1999 to 2004. Circulation. Jul. 5. 2011;124(1):17-23. KQ4E6e. [pmid: 21690489].
281 Parameswaran GI, Brand K, Dolan J. Pulse oximetry as a potential screening tool for lower extremity arterial disease in asymptomatic patients with diabetes mellitus. Arch Intern Med. Feb. 28. 2005;165(4):442-6. KQ2E2b, KQ3E2b. [pmid: 15738375].
282 Paraskevas KI, Kotsikoris I, Koupidis SA, et al. Ankle--brachial index: a marker of both peripheral arterial disease and systemic atherosclerosis as well as a predictor of vascular events. Angiology. Aug. 2010;61(6):521-3. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6, KQ6E6. [pmid: 20634224].
283 Pasqualini L, Vaudo G, Fedeli F, et al. Taurine therapy for intermittent claudication: Results of a controlled study. Adv Ther. 1993;10:245-51. KQ5E7.
284 Pearte CA, Furberg CD, O'Meara ES, et al. Characteristics and baseline clinical predictors of future fatal versus nonfatal coronary heart disease events in older adults: the Cardiovascular Health Study. Circulation. May. 9. 2006;113(18):2177-85. KQ4E3. [pmid: 16651468].
285 Pedersen TR, Kjekshus J, Pyorala K, et al. Effect of simvastatin on ischemic signs and symptoms in the Scandinavian simvastatin survival study (4S). Am J Cardiol. Feb. 1. 1998;81(3):333-5. KQ5E2b, KQ6E2b. [pmid: 9468077].
286 Pettinger MB, Waclawiw MA, Davis KB, et al. Compliance to multiple interventions in a high risk population. Annals of Epidemiology. Oct. 1999;9(7):408-18. KQ6E3. [pmid: 10501408].
287 Pignoli P, Ciccolo F, Villa V, et al. Comparative evaluation of buflomedil and pentoxifylline in patients with peripheral arterial occlusive disease. Curr Ther Res Clin Exp. 1985;37:596-606. KQ5E7.
288 Poredos P, Jezovnik MK. Antiplatelet and antithrombotic treatment of patients with peripheral arterial disease. International Angiology. Feb. 2010;29(1):20-6. KQ5E6b. [pmid: 20224527].
289 Premalatha G, Ravikumar R, Sanjay R, et al. Comparison of colour duplex ultrasound and ankle-brachial pressure index measurements in peripheral vascular disease in type 2 diabetic patients with foot infections. J Assoc Physicians India. Oct. 2002;50:1240-4. KQ2E2b, KQ3E2b. [pmid: 12568206].
290 Psaty BM, Furberg CD, Kuller LH, et al. Traditional risk factors and subclinical disease measures as predictors of first myocardial infarction in older adults: the Cardiovascular Health Study. Arch Intern Med. Jun. 28. 1999;159(12):1339-47. KQ4E6e. [pmid: 10386510].
291 Purroy F, Coll B, Oro M, et al. Predictive value of ankle brachial index in patients with acute ischaemic stroke. European Journal of Neurology. Apr. 2010;17(4):602-6. KQ4E2b. [pmid: 19968705].
292 Rabkin SW, Chan SH, Sweeney C. Ankle-Brachial Index as an Indicator of Arterial Stiffness in Patients Without Peripheral Artery Disease. Angiology. Feb. 2012;63(2):150-4. KQ2E1. [pmid: 21676966].
293 Racelis MC, Lombardo K, Verdin J. Impact of telephone reinforcement of risk reduction education on patient compliance. Journal of Vascular Nursing. Mar. 1998;16(1):16-20. KQ5E2a. [pmid: 9764028].
294 Rajagopalan S, Trachtenberg J, Mohler E, et al. Phase I study of direct administration of a replication deficient adenovirus vector containing the vascular endothelial growth factor cDNA (CI-1023) to patients with claudication. American Journal of Cardiology. 2002;90:512-6. KQ5E2a. [pmid: 12208412].
295 Ramaswami G, Al-Kutoubi A, Nicolaides AN, et al. The role of duplex scanning in decision making for patients with claudication. Annals of Vascular Surgery. Nov. 1999;13(6):606-12. KQ2E2a. [pmid: 10541615].
296 Ramos R, Quesada M, Solanas P, et al. Prevalence of symptomatic and asymptomatic peripheral arterial disease and the value of the ankle-brachial index to stratify cardiovascular risk. European Journal of Vascular & Endovascular Surgery. Sep. 2009;38(3):305-11. KQ4E6. [pmid: 19515589].
297 Reed JF III, Eid S, Edris B, et al. Prevalence of peripheral artery disease varies significantly depending upon the method of calculating ankle brachial index. Eur J Cardiovasc Prev Rehabil. Jun. 2009;16(3):377-81. KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 19369879].
298 Reijmer YD, van den Berg E, Dekker JM, et al. The metabolic syndrome, atherosclerosis and cognitive functioning in a non-demented population: the Hoorn Study. Atherosclerosis. Dec. 2011;219(2):839-45. KQ4E1. [pmid: 21959256].
299 Resnick HE, Lindsay RS, McDermott MM, et al. Relationship of high and low ankle brachial index to all-cause and cardiovascular disease mortality: the Strong Heart Study. Circulation. Feb. 17. 2004;109(6):733-9. KQ4E6e. [pmid: 14970108].
300 Rietzschel ER, De Buyzere ML, Bekaert S, et al. Rationale, design, methods and baseline characteristics of the Asklepios Study. European Journal of Cardiovascular Prevention & Rehabilitation. Apr. 2007;14(2):179-91. KQ4E1. [pmid: 17446795].
301 Roberts DH, Tsao Y, Linge K, et al. Double-blind comparison of captopril with nifedipine in hypertension complicated by intermittent claudication. Angiology. Sep. 1992;43(9):748-56. KQ5E2a. [pmid: 1514711].
302 Robless P, Mikhailidis DP, Stansby G. Systematic review of antiplatelet therapy for the prevention of myocardial infarction, stroke or vascular death in patients with peripheral vascular disease. British Journal of Surgery. Jun. 2001;88(6):787-800. KQ5E2a. [pmid: 11412247].
303 Roitman JL. Treadmill exercise and resistance training in patients with peripheral arterial disease with and without in intermittent claudication: A randomized controlled trial. Journal of cardiopulmonary rehabilitation and prevention. 2010;30:62. KQ5E6, KQ6E6.
304 Sander D. Stroke risk prediction beyond classical risk factors: the role of the Ankle-Brachial Index. Cerebrovascular Diseases. 2010;29(6):555-6. KQ4E6. [pmid: 20375497].
305 Sander D, Poppert H, Sander K, et al. The role of intima-media-thickness, ankle-brachial-index and inflammatory biochemical parameters for stroke risk prediction: a systematic review. Eur J Neurol. 2011. Sep. 6. KQ4E6. [pmid: 21895882].
306 Saunders J, Nambi V, Kimball KT, et al. Variability and persistence of aspirin response in lower extremity peripheral arterial disease patients. Journal of Vascular Surgery. Mar. 2011;53(3):668-75. KQ4E2a, KQ5E2a. [pmid: 21227624].
307 Schiano V, Brevetti G, Sirico G, et al. Functional status measured by walking impairment questionnaire and cardiovascular risk prediction in peripheral arterial disease: results of the Peripheral Arteriopathy and Cardiovascular Events (PACE) study. Vascular Medicine. Nov. 2006;11(3):147-54. KQ4E1. [pmid: 17288120].
308 Schroder F, Diehm N, Kareem S, et al. A modified calculation of ankle-brachial pressure index is far more sensitive in the detection of peripheral arterial disease. J Vasc Surg. Sep. 2006;44(3):531-6. KQ2E5, KQ3E5. [pmid: 16950430].
309 Schroll M, Munck O. Estimation of peripheral arteriosclerotic disease by ankle blood pressure measurements in a population study of 60-year-old men and women. J Chronic Dis. 1981;34(6):261-9. KQ2E1, KQ3E1. [pmid: 7240365].
310 Schweizer J, Kirch W, Koch R, et al. Effect of high dose verapamil on restenosis after peripheral angioplasty. J Am Coll Cardiol. May. 1998;31(6):1299-305. KQ5E2b, KQ6E2b. [pmid: 9581724].
311 Seino Y, Rose HB, Kanazawa M, et al. Double-blind study of papaverine hydrochloride on the efficacy in the treatment of intermittent claudication. Angiology. 1983;34:257-65. KQ5E7. [pmid: 6340562].
312 Selvin E, Erlinger TP. Prevalence of and risk factors for peripheral arterial disease in the United States: results from the National Health and Nutrition Examination Survey, 1999-2000. Circulation. Aug. 10. 2004;110(6):738-43. KQ4E3. [pmid: 15262830].
313 Serebruany VL, Malinin AI, Ferguson JJ, et al. Bleeding risks of combination vs. single antiplatelet therapy: a meta-analysis of 18 randomized trials comprising 129,314 patients. Fundamental & Clinical Pharmacology. Jun. 2008;22(3):315-21. KQ6E2b. [pmid: 18485150].
314 Shammas NW. Epidemiology, classification, and modifiable risk factors of peripheral arterial disease. Vasc Health Risk Manag. 2007;3(2):229-34. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6, KQ6E6. [pmid: 17580733].
315 Sheikh MA, Bhatt DL, Li J, et al. Usefulness of postexercise ankle-brachial index to predict all-cause mortality. American Journal of Cardiology. Mar. 1. 2011;107(5):778-82. KQ4E1. [pmid: 21247542].
316 Shigematsu H, Nishibe T, Obitsu Y, et al. Three-year cardiovascular events and disease progress in patients with peripheral arterial disease: results from the Japan Medication Therapy for Peripheral Arterial Disease (J-METHOD). International Angiology. Apr. 2010;29(2:Suppl). Suppl-13. KQ4E2a. [pmid: 20357743].
317 Shinsato T, Miyata M, Kubozono T, et al. Waon therapy mobilizes CD34+ cells and improves peripheral arterial disease. Journal of Cardiology. 2010;56:361-6. KQ5E7. [pmid: 20843662].
318 Sikkink CJ, van Asten WN, van 't Hof MA, et al. Decreased ankle/brachial indices in relation to morbidity and mortality in patients with peripheral arterial disease. Vascular Medicine. 1997;2(3):169-73. KQ4E5. [pmid: 9546965].
319 Silvestro A, Brevetti G, Schiano V, et al. Adhesion molecules and cardiovascular risk in peripheral arterial disease. Soluble vascular cell adhesion molecule-1 improves risk stratification. Thrombosis & Haemostasis. Mar. 2005;93(3):559-63. KQ4E2a. [pmid: 15735810].
320 Simon A, Papoz L, Ponton A, et al. Feasibility and reliability of ankle/arm blood pressure index in preventive medicine. Angiology. Jun. 2000;51(6):463-71. KQ2E4. [pmid: 10870855].
321 Singer E, Imfeld S, Hoffmann U, et al. Aspirin in peripheral arterial disease: breakthrough or pitfall?. Vasa. Aug. 2006;35(3):174-7. KQ5E2a. [pmid: 16941406].
322 Singh S, Bailey KR, Noheria A, et al. Frailty Across the Spectrum of Ankle-Brachial Index. Angiology. 2011. Jul. 6. KQ4E4b. [pmid: 21733950].
323 Skotnicki SH, van Gaal G, Wijn PFF. The effectiveness of isoxsuprine in patients with intermittent claudication. Angiology. 1984;35:685-93. KQ5E7. [pmid: 6388424].
324 Sloth-Nielsen J, Guldager B, Mouritzen C, et al. Arteriographic findings in EDTA chelation therapy on peripheral arteriosclerosis. American Journal of Surgery. 1991;162:122-5. KQ5E2a. [pmid: 1907432].
325 Sommerfield T, Price J, Hiatt WR. Omega-3 fatty acids for intermittent claudication. [Update of Cochrane Database Syst Rev. 2004;(3):CD003833; PMID: 15266504]. Cochrane Database of Systematic Reviews. 2007;(4):CD003833. KQ5E2a. [pmid: 17943801].
326 Sona A, Comba M, Brescianini A, et al. Implications of routinely measuring Ankle-Brachial Index (ABI) among patients attending at a Lipid Clinic. European Journal of Internal Medicine. May. 2009;20(3):296-300. KQ2E4c, KQ3E4c. [pmid: 19393497].
327 Sprengers RW, Janssen KJ, Moll FL, et al. Prediction rule for cardiovascular events and mortality in peripheral arterial disease patients: data from the prospective Second Manifestations of ARTerial disease (SMART) cohort study. Journal of Vascular Surgery. Dec. 2009;50(6):1369-76. KQ4E2b. [pmid: 19837547].
328 Spring S, Simon R, van der Loo B, et al. High-dose atorvastatin in peripheral arterial disease (PAD): effect on endothelial function, intima-media-thickness and local progression of PAD. An open randomized controlled pilot trial. Thrombosis & Haemostasis. Jan. 2008;99(1):182-9. KQ5E2, KQ6E2. [pmid: 18217152].
329 Stansby G, Mister R, Fowkes G, et al. High risk of peripheral arterial disease in the United Kingdom: 2-year results of a prospective registry. Angiology. Feb. 2011;62(2):111-8. KQ4E2a. [pmid: 21220371].
330 Steg PG, Bhatt DL, Wilson PW, et al. One-year cardiovascular event rates in outpatients with atherothrombosis. JAMA. Mar. 21. 2007;297(11):1197-206. KQ4E1. [pmid: 17374814].
331 Stoffers HE, Kester AD, Kaiser V, et al. The diagnostic value of the measurement of the ankle-brachial systolic pressure index in primary health care. J Clin Epidemiol. Dec. 1996;49(12):1401-5. KQ2E2. [pmid: 8970490].
332 Strano A, Pinto A, Galati D. Double-blind controlled study of the efficacy and pharmacological properties of heparan sulfate in patients with occlusive arterial disease of the lower limbs. Drugs Under Experimental & Clinical Research. 1990;16(10):543-50. KQ5E6d. [pmid: 2151628].
333 Strano A, Fareed J, Sabbį C, et al. A double-blind, multicenter, placebo-controlled, dose comparison study of orally administered defibrotide: preliminary results in patients with peripheral arterial disease. Seminars in Thrombosis and Hemostasis. Suppl 2. 1991;17:228-34. KQ5E2a. [pmid: 1948094].
334 Strano A. Propionyl-L-carnitine versus pentoxifylline: Improvement in walking capacity in patients with intermittent claudication. Clinical Drug Investigation. 2002;22:1-6. KQ5E7. [pmid: 23315429].
335 Stumpe KO, Overlack A. Angiotensin-converting enzyme inhibition in mild hypertension with concomitant diseases and therapies: an efficacy, safety, and compatibility study of novel design, the Perindopril Therapeutic Safety Study. American Journal of Medicine. Apr. 27. 1992;92(4B):98S-101S. KQ5E2a. [pmid: 1580290].
336 Subramaniyam V, Waller EK, Murrow JR, et al. Bone marrow mobilization with granulocyte macrophage colony-stimulating factor improves endothelial dysfunction and exercise capacity in patients with peripheral arterial disease. Am Heart J. 2009;158:53-60. KQ5E7. [pmid: 19540392].
337 Suominen V, Uurto I, Saarinen J, et al. PAD as a risk factor for mortality among patients with elevated ABI--a clinical study. European Journal of Vascular & Endovascular Surgery. Mar. 2010;39(3):316-22. KQ4E5. [pmid: 20089422].
338 Sutton-Tyrrell K, Venkitachalam L, Kanaya AM, et al. Relationship of ankle blood pressures to cardiovascular events in older adults. Stroke. Mar. 2008;39(3):863-9. KQ4E1. [pmid: 18258843].
339 Suurkula M, Fagerberg B, Wendelhag I, et al. Atherosclerotic disease in the femoral artery in hypertensive patients at high cardiovascular risk. The value of ultrasonographic assessment of intima-media thickness and plaque occurrence. Risk Intervention Study (RIS) Group. Arteriosclerosis, Thrombosis & Vascular Biology. Aug. 1996;16(8):971-7. KQ2E6a. [pmid: 8696961].
340 Svendsen TL, Jelnes R, Tųnnesen KH. The effects of acebutolol and metoprolol on walking distances and distal blood pressure in hypertensive patients with intermittent claudication. Acta Medica Scandinavica. 1986;219:161-5. KQ5E2a. [pmid: 3515864].
341 Svensson P, de FU, Sleight P, et al. Comparative effects of ramipril on ambulatory and office blood pressures: a HOPE Substudy. Hypertension. Dec. 1. 2001;38(6):E28-E32. KQ5E2a. [pmid: 11751742].
342 Symeonidis A, Kouraklis-Symeonidis A, Seimeni U, et al. Ticlopidine-induced aplastic anemia: two new case reports, review, and meta-analysis of 55 additional cases. American Journal of Hematology. Sep. 2002;71(1):24-32. KQ6E6b. [pmid: 12221670].
343 Syvanen K, Korhonen P, Jaatinen P, et al. High-sensitivity C-reactive protein and ankle brachial index in a finnish cardiovascular risk population. International Journal of Angiology. Mar. 2011;20(1):43-8. KQ4E3. [pmid: 22532770].
344 Taylor-Piliae RE, Fair JM, Varady AN, et al. Ankle brachial index screening in asymptomatic older adults. Am Heart J. May. 2011;161(5):979-85. KQ4E3. [pmid: 21570532].
345 Tellier P, Aquilanti S, Lecouffe P, et al. Comparison between exercise whole body thallium imaging and ankle-brachial index in the detection of peripheral arterial disease. International Angiology. Sep. 2000;19(3):212-9. KQ2E2. [pmid: 11201588].
346 Tepe G, Bantleon R, Brechtel K, et al. Management of peripheral arterial interventions with mono or dual antiplatelet therapy-the MIRROR study: a randomised and double-blinded clinical trial. European radiology. Sep. 2012;22(9):1998-2006. KQ5E2a. [pmid: 22569995].
347 Terenzi T, Gallagher D, DeMeersman R, et al. The age-related advancement of arterial disease measured by Doppler ultrasound diastolic flow analysis. Journal of Manipulative & Physiological Therapeutics. Oct. 1993;16(8):527-36. KQ2E1. [pmid: 8263432].
348 Terenzi T, Gallagher D, De MR. Smokers exhibit an altered Doppler analog waveform during peripheral arterial examination. Journal of Manipulative & Physiological Therapeutics. May. 1995;18(4):211-8. KQ2E1. [pmid: 7636410].
349 Thatipelli MR, Pellikka PA, McBane RD, et al. Prognostic value of ankle-brachial index and dobutamine stress echocardiography for cardiovascular morbidity and all-cause mortality in patients with peripheral arterial disease. Journal of Vascular Surgery. 1970;46(1):62-70. KQ4E2. [pmid: 17583463].
350 The Dutch BOA Study Group. Bleeding increases the risk for major ischemic events in patients with peripheral arterial disease using antithrombotic treatments. European Heart Journal. 2008;29(Suppl 1):143-4. KQ6E2a. [pmid: 17921516].
351 Thizon-de-Gaulle I. Antiplatelet drugs in secondary prevention after acute myocardial infarction. Revista Portuguesa de Cardiologia. Dec. 1998;17(12):993-7. KQ5E2a. [pmid: 9973860].
352 Thulesius O, Lundvall J, Kroese A, et al. Ketanserin in intermittent claudication: effect on walking distance, blood pressure, and cardiovascular complications. Journal of Cardiovascular Pharmacology. 1987;9:728-33. KQ5E2a. [pmid: 2442541].
353 Topol EJ, Easton JD, Amarenco P, et al. Design of the blockade of the glycoprotein IIb/IIIa receptor to avoid vascular occlusion (BRAVO) trial. Am Heart J. Jun. 2000;139(6):927-33. KQ5E7. [pmid: 10827369].
354 Toribatake Y, Komine N. Usefulness of stress-loading test for ankle brachial index using an originally developed exercise device to detect peripheral arterial disease. International Angiology. Apr. 2009;28(2):100-5. KQ2E1. [pmid: 19367239].
355 Tornwall M, Virtamo J, Haukka JK, et al. Effect of alpha-tocopherol (vitamin E) and beta-carotene supplementation on the incidence of intermittent claudication in male smokers. Arterioscler Thromb Vasc Biol. Dec. 1997;17(12):3475-80. KQ5E1, KQ6E1. [pmid: 9437195].
356 Tönnesen KH, Albuquerque P, Baitsch G, et al. Double-blind, controlled, multicenter study of indobufen versus placebo in patients with intermittent claudication. International Angiology: A Journal of the International Union of Angiology. 1993;12:371-7. KQ5E2a. [pmid: 8207316].
357 Trainor FS, Phillips RE, Michie DD, et al. Effects of ethaverine hydrochloride on the walking tolerance of patients with intermediate claudication. Angiology. 1986;37:343-51. KQ5E7. [pmid: 3521401].
358 Tsuchida H, Shigematsu H, Ishimaru S, et al. Effect of low-density lipoprotein apheresis on patients with peripheral arterial disease. Peripheral Arterial Disease LDL Apheresis Multicenter Study (P-LAS). International Angiology. Sep. 2006;25(3):287-92. KQ5E6b. [pmid: 16878078].
359 Tzoulaki I, Murray GD, Lee AJ, et al. Inflammatory, haemostatic, and rheological markers for incident peripheral arterial disease: Edinburgh Artery Study. European Heart Journal. Feb. 2007;28(3):354-62. KQ4E3. [pmid: 17213229].
360 U.S. Preventive Services Task Force. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. [Summary for patients in Ann Intern Med. 2009 Oct 6;151(7):I-38; PMID: 19805766]. Annals of Internal Medicine. Oct. 6. 2009;151(7):474-82. KQ4E6a. [pmid: 19805770].
361 Ubbink DT, Koopman B. Near-infrared spectroscopy in the routine diagnostic work-up of patients with leg ischaemia. European Journal of Vascular & Endovascular Surgery. Apr. 2006;31(4):394-400. KQ2E1. [pmid: 16359878].
362 Uchiyama S, Goto S, Matsumoto M, et al. Cardiovascular event rates in patients with cerebrovascular disease and atherothrombosis at other vascular locations: results from 1-year outcomes in the Japanese REACH Registry. Journal of the Neurological Sciences. Dec. 15. 2009;287(1-2):45-51. KQ4E2b. [pmid: 19815240].
363 Vainas T, Stassen FR, Schurink GW, et al. Secondary prevention of atherosclerosis through chlamydia pneumoniae eradication (SPACE Trial): a randomised clinical trial in patients with peripheral arterial disease. European Journal of Vascular & Endovascular Surgery. 2005;29:403-11. KQ5E1. [pmid: 15749042].
364 van Kuijk JP, Flu WJ, Bax JJ, et al. Prevalence of (a)symptomatic peripheral arterial disease; the additional value of ankle-brachial index on cardiovascular risk stratification. European Journal of Vascular & Endovascular Surgery. Sep. 2009;38(3):312-3. KQ4E6. [pmid: 19524459].
365 van Oijen M, de Jong FJ, Witteman JC, et al. Atherosclerosis and risk for dementia. Annals of Neurology. May. 2007;61(5):403-10. KQ4E1. [pmid: 17328068].
366 van Rij AM, Solomon C, Packer SG, et al. Chelation therapy for intermittent claudication. A double-blind, randomized, controlled trial. Circulation. 1994;90:1194-9. KQ5E2a. [pmid: 8087928].
367 Vega J, Romani S, Garciperez FJ, et al. Ankle-brachial index measurement in the primary care setting. Southern Medical Journal. Jun. 2010;103(6):590. KQ2E6, KQ3E6. [pmid: 20710151].
368 Ventura MR, Young DE, Feldman MJ, et al. Effectiveness of health promotion interventions. Nursing Research. 1984;33:162-7. KQ5E2a. [pmid: 6563534].
369 Vermeulen EG, Stehouwer CD, Twisk JW, et al. Effect of homocysteine-lowering treatment with folic acid plus vitamin B6 on progression of subclinical atherosclerosis: a randomised, placebo-controlled trial. Lancet. 2000;355:517-22. KQ5E7. [pmid: 10683000].
370 Vincent HK, Bourguignon CM, Vincent KR, et al. Effects of alpha-lipoic acid supplementation in peripheral arterial disease: a pilot study. Journal of Alternative & Complementary Medicine. Jun. 2007;13(5):577-84. KQ5E7. [pmid: 17604563].
371 Violi F, Criqui M, Longoni A, et al. Relation between risk factors and cardiovascular complications in patients with peripheral vascular disease. Results from the A.D.E.P. study. Atherosclerosis. Feb. 1996;120(1-2):25-35. KQ4E2a. [pmid: 8645368].
372 Vogt MT, Cauley JA, Newman AB, et al. Decreased ankle/arm blood pressure index and mortality in elderly women. JAMA. Jul. 28. 1993;270(4):465-9. KQ4E6e. [pmid: 8320785].
373 Vogt MT, McKenna M, Anderson SJ, et al. The relationship between ankle-arm index and mortality in older men and women. Journal of the American Geriatrics Society. May. 1993;41(5):523-30. KQ4E5. [pmid: 8486886].
374 Walden R, Bass A, Rabi I, et al. Randomized placebo-controlled, double-blind trial of ketanserin in treatment of intermittent claudication. The Journal of Cardiovascular Surgery. 1991;32:737-40. KQ5E2a. [pmid: 1752890].
375 Walldius G, Erikson U, Olsson AG, et al. The effect of probucol on femoral atherosclerosis: the Probucol Quantitative Regression Swedish Trial (PQRST). The American Journal of Cardiology. 1994;74:875-83. KQ5E7, KQ6E7. [pmid: 7977117].
376 Wang J, Zhou S, Bronks R, et al. Supervised exercise training combined with ginkgo biloba treatment for patients with peripheral arterial disease. Clinical Rehabilitation. 2007;21:579-86. KQ5E2a. [pmid: 17702699].
378 Wang JC, Criqui MH, Denenberg JO, et al. Exertional leg pain in patients with and without peripheral arterial disease. Circulation. Nov. 29. 2005;112(22):3501-8. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1, KQ6E1. [pmid: 16316971].
379 Warfarin Antiplatelet Vascular Evaluation Trial Investigators, Anand S, Yusuf S, et al. Oral anticoagulant and antiplatelet therapy and peripheral arterial disease. New England Journal of Medicine. Jul. 19. 2007;357(3):217-27. KQ5E2a. [pmid: 17634457].
380 Weimar C, Goertler M, Rother J, et al. Predictive value of the Essen Stroke Risk Score and Ankle Brachial Index in acute ischaemic stroke patients from 85 German stroke units. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2008;79(12):1339-43. KQ4E2b. [pmid: 18586863].
381 Weitz JI, Byrne J, Clagett GP, et al. Diagnosis and treatment of chronic arterial insufficiency of the lower extremities: a critical review. Circulation. Dec. 1. 1996;94(11):3026-49. KQ2E6, KQ3E6, KQ5E6, KQ6E6. [pmid: 8941154].
382 Williams DT, Harding KG, Price P. An evaluation of the efficacy of methods used in screening for lower-limb arterial disease in diabetes. Diabetes Care. Sep. 2005;28(9):2206-10. KQ2E2b, KQ3E2b. [pmid: 16123491].
383 Wilson AM, Shin DS, Weatherby C, et al. Asymmetric dimethylarginine correlates with measures of disease severity, major adverse cardiovascular events and all-cause mortality in patients with peripheral arterial disease. Vascular Medicine. Aug. 2010;15(4):267-74. KQ4E1. [pmid: 20484311].
384 Wolosker N, Rosoky RA, Nakano L, et al. Predictive value of the ankle-brachial index in the evaluation of intermittent claudication. Revista do Hospital das Clinicas; Faculdade de Medicina Da Universidade de Sao Paulo. Mar. 2000;55(2):61-4. KQ4E2a. [pmid: 10959125].
385 Xu D, Zou L, Xing Y, et al. Diagnostic Value of Ankle-Brachial Index in Peripheral Arterial Disease: A Meta-Analysis. Can J Cardiol. 2012. Aug. 24. KQ2E2a. [pmid: 22926041].
386 Xu Y, Li J, Luo Y, et al. The association between ankle-brachial index and cardiovascular or all-cause mortality in metabolic syndrome of elderly Chinese. Hypertension Research - Clinical & Experimental. Jul. 2007;30(7):613-9. KQ4E5. [pmid: 17785929].
387 Xu Y, Wu Y, Li J, et al. The predictive value of brachial-ankle pulse wave velocity in coronary atherosclerosis and peripheral artery diseases in urban Chinese patients. Hypertension Research - Clinical & Experimental. Jun. 2008;31(6):1079-85. KQ4E5. [pmid: 18716354].
388 Yao ST, Hobbs JT, Irvine WT. Ankle pressure measurement in arterial disease of the lower extremities. Br J Surg. Nov. 1968;55(11):859-60. KQ2E6a, KQ3E6a. [pmid: 5686989].
389 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. Jan. 20. 2000;342(3):145-53. KQ5E2a. [pmid: 10639539].
390 Zacharski LR, Chow BK, Howes PS, et al. Decreased cancer risk after iron reduction in patients with peripheral arterial disease: results from a randomized trial. Journal of the National Cancer Institute. 2008;100:996-1002. KQ5E2a. [pmid: 18612130].
392 Zacharski LR, Shamayeva G, Chow BK. Effect of controlled reduction of body iron stores on clinical outcomes in peripheral arterial disease. Am Heart J. 2011;162(5):949-57. KQ5E2a. [pmid: 22093213].
393 Zan S, Maselli M, Moniaci D, et al. Compliance of geriatric patients subjected to antiplatelet agents with Triflusal in peripheral arteriopathy. Preliminary data. Minerva Cardioangiologica. Jun. 2002;50(3):263-70. KQ6E7. [pmid: 12107407].
394 Zanchetti A, Julius S, Kjeldsen S, et al. Outcomes in subgroups of hypertensive patients treated with regimens based on valsartan and amlodipine: An analysis of findings from the VALUE trial. Journal of Hypertension. Nov. 2006;24(11):2163-8. KQ5E2a. [pmid: 17053536].
395 Zeymer U, Parhofer KG, Pittrow D, et al. Risk factor profile, management and prognosis of patients with peripheral arterial disease with or without coronary artery disease: results of the prospective German REACH registry cohort. Clinical Research in Cardiology. Apr. 2009;98(4):249-56. KQ4E1. [pmid: 19221687].
396 Zheng ZJ, Sharrett AR, Chambless LE, et al. Associations of ankle-brachial index with clinical coronary heart disease, stroke and preclinical carotid and popliteal atherosclerosis: the Atherosclerosis Risk in Communities (ARIC) Study. Atherosclerosis. May. 1997;131(1):115-25. KQ4E1. [pmid: 9180252].
397 Zusman RM, Chesebro JH, Comerota A, et al. Antiplatelet therapy in the prevention of ischemic vascular events: literature review and evidence-based guidelines for drug selection. Clinical Cardiology. Sep. 1999;22(9):559-73. KQ5E6. [pmid: 10486695].