# Inclusion/Exclusion Criteria

| Inclusion | Exclusion
Population | Screening (KQs 1–4): Community-dwelling, generally asymptomatic adults (may include populations with atypical symptoms or minor symptom not recognized as PAD); unselected, primary care–relevant populations or primary care–relevant populations selected based on Framingham or other traditional CVD risk factors (e.g, age, smoking history, hypertension, hyperlipidemia) Treatment (KQs 5–6): Asymptomatic or minimally symptomatic (mild claudication or Fontaine Stage I or IIa) | Symptomatic adults, populations exclusively of persons with known CVD, diabetes, or severe chronic kidney disease (stage 4–5)
Setting | KQs 1–4: Primary care, outpatient settings (ambulatory care) KQs 5–6: Outpatient settings | Hospital/inpatient settings, long-term care facilities, vascular clinics
Disease/Condition | Lower-extremity PAD secondary to atherosclerosis
Screening (KQs 1–4) | Resting ABI | History taking, questionnaires, digital subtraction arteriography, duplex ultrasound, magnetic resonance angiography, CT angiography, toe pressure measurement, treadmill testing (exercise ABI), pulse oximetry, near-infrared spectroscopy, and all invasive diagnostic testing
Treatment or management interventions (KQs 5–6) | Pharmacologic or lifestyle interventions primarily aimed at CVD reduction: interventions for smoking cessation, cholesterol lowering, weight loss, blood pressure control, antiplatelet therapy | Vitamins or nutritional or herbal supplement Interventions aimed only at symptomatic persons or persons with critical limb ischemia: pharmacologic symptom management (pentoxyfylline, cilostazol, prostaglandins); nonpharmacologic symptom management (lower-extremity rehabilitation, supervised exercise training and physical therapy*); revascularization (angioplasty, thrombolytics, stenting, bypass) * Exercise interventions whose primary aim is to reduce CVD risk or treat CVD risk factors are included
Comparisons | KQ 1: No screening KQ 2: Reference standard KQ 4: Framingham CVD risk factors (age, sex, blood pressure, total cholesterol, high-density lipoprotein cholesterol, smoking) KQ 5: True control group (receiving placebo, no intervention, or usual care), intervention/treatment at later or symptomatic stage of disease (vs. treatment at earlier or asymptomatic stage)
Outcomes | KQ 1: Cardiovascular morbidity (MI, CVA), PAD morbidity (ambulation, patient function, amputation), or mortality (all-cause, PAD-related, or CVD-related) KQ 2: Sensitivity, specificity, PPV, NPV for PAD, incidence or prevalence KQ 4: Risk of cardiovascular morbidity or mortality, reclassification of risk of morbidity/mortality KQ 5: Intermediate cardiovascular outcomes (blood pressure, cholesterol, smoking cessation), cardiovascular or lower extremity–related health outcomes (listed above for KQ 1) | Surrogate markers for atherosclerosis including imaging (e.g., carotid intima-media thickness) or biochemical markers (e.g., C-reactive protein) Patient satisfaction Cost-related outcomes (for screening and treatment)
Harms | KQ 3: Adverse outcomes related to ABI test itself (diagnostic inaccuracy) or harms of subsequent testing KQ 6: Serious adverse events (e.g., death, serious adverse drug reactions), unexpected medical attention (e.g., emergency department visits, hospitalizations) | Patient satisfaction
Study Designs | KQs 1, 5: Good-quality systematic reviews, randomized or clinically controlled trials KQ 2: Good-quality systematic reviews, diagnostic accuracy studies KQ 4: Good-quality systematic reviews, cohort risk prediction studies KQs 3, 6: Good-quality systematic reviews, trials (randomized or clinically controlled), cohort or case-control studies | Poor-quality studies based on established design-specific quality criteria KQs 2, 4: Case-control studies of diagnostic accuracy or risk prediction KQ 5: Less than 3 months followup
Language | English only | Non-English languages