# Search Results

Abbreviations: ABI = ankle-brachial index; BL = baseline; CVD = cardiovascular disease; PAD = peripheral artery disease.

Appendix D displays the literature search results and article flow for the review. A total of 4,317 articles were identified through database searching and 117 articles were identified through other searching. 4,434 articles were screened after duplicates were removed. 418 full-text articles were assessed for eligibility. No articles were included for key question 1; 2 articles were included for key question 2; 1 article was included for key question 3; 16 articles were included for key question 4; 3 articles were included for key question 5; and 3 articles were included for key question 6.