# Ongoing Studies and Trials Pending Assessment

Study reference | Study name NCT # | Relevant KQ Study design | Aim | Location | # of participants Inclusion criteria | Intervention description | Relevant outcomes | 2012 Status
Grøndal N et al. The Viborg Vascular (VIVA) screening trial of 65–74 year old men in the central region of Denmark: study protocol. Trials. 2010;11:67. PMID: 20507582 | Viborg Vascular Screening Trial (VIVA) 00662480 | KQ 1 RCT | To establish the effectiveness of a joint circulation screening program (AAA, ABI, hypertension) | Denmark | 40,000 Men ages 65 to 74 years | IG: Invitation to screening ultrasound of the aorta and ABI; interventions (risk factor reduction or AAA surgery) for those who screen positive CG: No invitation to screening; usual care | All-cause mortality, cardiovascular and AAA-related mortality; cardiovascular events at 3, 5, and 10 years | Currently recruiting participants Estimated primary completion date: September 2018
Marti R et al. Improving intermediate risk management. MARK study. BMC Cardiovasc Disord. 2011;11:6. PMID: 21992621 | Improving Intermediate Risk Management (MARK) 01428934 | KQ 4 Cohort | To analyze if ABI and other cardiovascular biomarkers are independently associated with incidence of vascular events and if they improve the prediction of current risk equations in the intermediate-risk population | Spain | 2,688 Men and women ages 35 to 74 years with intermediate cardiovascular risk by FRS or SCORE | ABI along with other cardiovascular biomarkers and CVD screening tests | Vascular events (fatal or nonfatal): MI, angina, stroke, or PAD at 18 months and 10 years | Currently recruiting participants Estimated primary completion date: January 2013
Muntendam P et al. The Bioimage Study: novel approaches to risk assessment in the primary prevention of atherosclerotic cardiovascular disease—study design and objectives. Am Heart J. 2010;160(1):49-57. PMID: 20598972 | BioImage 00738725 | KQ 4 Cohort | To identify imaging and serum biomarkers that predict atherothrombotic events after 3 years, with incremental improvement over the FRS | Chicago, IL; Louisville, KY; and Ft. Lauderdale, FL | 7,687 Men age >55 years and women age >60 years who are members of the Humana Health Plan | IG: CAC score; cIMT, carotid atherosclerotic Plaques, and AAA by ultrasound; ABI; and serum biomarkers; those with abnormal results are offered MRA, CTA, or PET/CT CG1: Survey only CG2: FRS only | MI (fatal and nonfatal), coronary death, unstable angina, ischemic stroke (fatal and nonfatal), and arterial revascularization at 3 years or when 600 major atherothrombotic events have occurred | Ongoing but not recruiting participants Estimated study completion date: July 2012
Evaluation of Non-invasive Measurements of Atherosclerosis in Cardiovascular Risk Stratification (NIMA) | NIMA Substudy of Nijmegen Biomedical Study 01555294 | KQ 4 Cohort | To evaluate whether noninvasive measurements of atherosclerosis are independent predictors of cardiovascular disease | The Netherlands | 1,960 Men and women ages 50 to 70 years without recent CVD | Noninvasive measurements of atherosclerosis (including ABI) | Cardiovascular events (fatal and nonfatal) | Completed May 2011 No study results posted on ClinicalTrials.gov or retrieved through PubMed
Casasnovas JA et al. Aragon workers' health study: design and cohort description. BMC Cardiovasc Disord. 2012;12:45. PMID: 22712826 | Aragon Workers' Health Study (NR) | KQ 4 Cohort | To characterize the factors associated with metabolic abnormalities and subclinical atherosclerosis in a middle-aged population in Spain free of clinical cardiovascular disease | Aragon, Spain | 5,400 Male and female workers of a large car assembly plant without clinically overt CVD or a condition limiting survival to <3 years | Subclinical atherosclerosis imaging (including ABI; CAC; and ultrasound of the carotid, aortic, femoral and iliac arteries); biobanking | Clinical events and hospitalizations | Recruitment and baseline examinations 2009–2010; planned 10 years' followup Estimated study completion date: 2020
Early detection of atherosclerosis: a randomized trial in the Primary Prevention of Cardiovascular Diseases. (PRIMARIA) http://www.udetma.com/documents/productes/pdf/38_1.pdf | PRIMARIA 00734123 | KQ 5 RCT | To quantify the burden of subclinical atherosclerosis using noninvasive techniques and to study the impact of this assessment and consequent treatment in the progression of atherosclerosis and in the incidence of cardiovascular diseases | Vilanova, Spain | 2,948 Men and women ages 40 to 74 years without history of cardiovascular events but with 1 major or 2 minor risk factors for CAD | All participants have cIMT (or CAC score, if problems measuring cIMT) and ABI. Those with abnormal results are randomized: IG: Intensive treatment CG: Usual care | cIMT/CAC score at 2 years Incidence of CVD at 5 years Secondary analysis will examine ABI at 2 years as outcome | Currently recruiting participants

Abbreviations: AAA = abdominal aortic aneurysm; ABI = ankle-brachial index; CAC = coronary artery calcium; CAD = coronary artery disease; CG = control group; cIMT = carotid intima media thickness; CTA = computed tomography angiography; CVD = cardiovascular disease; FRS = Framingham risk score; IG = intervention group; KQ = key question; MI = myocardial infarction; MRA = magnetic resonance angiography; PAD = peripheral artery disease; PET = positron emission tomography; RCT = randomized, controlled trial.