# Systematic Reviews Used for Reference

1 Aboyans V, Lacroix P. Regarding: “A modified calculation of ankle-brachial pressure index is far more sensitive in the detection of peripheral arterial disease”. Journal of Vascular Surgery. 2007;46(3):617-8. [pmid: 17826263].
2 Ankle Brachial Index Collaboration, Fowkes FG, Murray GD, et al. Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. Jul. 9. 2008;300(2):197-208. [pmid: 18612117].
3 Aung PP, Maxwell HG, Jepson RG, et al. Lipid-lowering for peripheral arterial disease of the lower limb. [Update of Cochrane Database Syst Rev. 2000;(2):CD000123. Cochrane Database of Systematic Reviews. 2007;(4):CD000123. [pmid: 17943736].
4 Baigent C, Keech A, Kearney PM, et al. Efficacy and safety of cholesterol-lowering treatment: prospective meta-analysis of data from 90,056 participants in 14 randomised trials of statins. Lancet. Oct. 8. 2005;366(9493):1267-78. [pmid: 16214597].
5 Banerjee A, Fowkes FG, Rothwell PM. Associations between peripheral artery disease and ischemic stroke: implications for primary and secondary prevention. Stroke. Sep. 2010;41(9):2102-7. [pmid: 20689082].
6 Beckman JA, Jaff MR, Creager MA. The United States Preventive Services Task Force Recommendation Statement on Screening for Peripheral Arterial Disease. Circulation. 2006;114(8):861-6. [pmid: 16923770].
7 Begelman SM, Jaff MR. Noninvasive diagnostic strategies for peripheral arterial disease. Cleveland Clinic Journal of Medicine. Oct. 2006;73. Suppl-9. [pmid: 17385388].
8 Bhasin N, Scott DJ. Ankle Brachial Pressure Index: identifying cardiovascular risk and improving diagnostic accuracy. Journal of the Royal Society of Medicine. Jan. 2007;100(1):4-5. [pmid: 17197670].
9 Burns P, Gough S, Bradbury AW. Management of peripheral arterial disease in primary care. BMJ. Mar. 15. 2003;326(7389):584-8. [pmid: 12637405].
10 Cao P, Eckstein HH, De RP, et al. Chapter II: Diagnostic Methods. European Journal of Vascular & Endovascular Surgery. Dec. 2011;42. Suppl-32. [pmid: 22172470].
11 Caruana MF, Bradbury AW, Adam DJ. The validity, reliability, reproducibility and extended utility of ankle to brachial pressure index in current vascular surgical practice. European Journal of Vascular & Endovascular Surgery. May. 2005;29(5):443-51. [pmid: 15966081].
12 Cassar K. Peripheral Arterial Disease. BMJ Clinical Evidence. 2011. [pmid: 21477401].
13 Cassar K, Bachoo P, Brittenden J. The role of platelets in peripheral vascular disease. European Journal of Vascular & Endovascular Surgery. Jan. 2003;25(1):6-15. [pmid: 12525805].
14 Chi YW, Jaff MR. Optimal risk factor modification and medical management of the patient with peripheral arterial disease. Catheterization & Cardiovascular Interventions. Mar. 1. 2008;71(4):475-89. [pmid: 18307227].
15 Clagett GP, Sobel M, Jackson MR, et al. Antithrombotic therapy in peripheral arterial occlusive disease: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. Sep. 2004;126(3:Suppl). Suppl-626S. [pmid: 15383487].
16 Coppola G, Novo S. Statins and peripheral arterial disease: effects on claudication, disease progression, and prevention of cardiovascular events. Archives of Medical Research. Jul. 2007;38(5):479-88. [pmid: 17560452].
17 Coutinho T, Rooke TW, Kullo IJ. Arterial dysfunction and functional performance in patients with peripheral artery disease: a review. Vascular Medicine. Jun. 2011;16(3):203-11. [pmid: 21447607].
18 De Schryver EL, Algra A, van Gijn J. Dipyridamole for preventing stroke and other vascular events in patients with vascular disease. Update in Cochrane Database Syst Rev. 2006;(2): CD001820; PMID: 16625549]. Cochrane Database of Systematic Reviews. 2003;(1):CD001820. [pmid: 12535415].
19 Doobay AV, Anand SS. Sensitivity and specificity of the ankle-brachial index to predict future cardiovascular outcomes: a systematic review. Arterioscler Thromb Vasc Biol. Jul. 2005;25(7):1463-9. [pmid: 15879302].
20 Feldman DN, Moussa ID. Efficacy of aspirin for secondary prevention in patients with peripheral artery disease. Expert Review of Cardiovascular Therapy. Oct. 2009;7(10):1203-7. [pmid: 19814663].
21 Ferket BS, Spronk S, Colkesen EB, et al. Systematic Review of Guidelines on Peripheral Artery Disease Screening. Am J Med. 201. Nov. 11. [pmid: 22079018].
22 Fernandes VR, Cheng S, Lima JA. Atherosclerosis imaging and heart failure. Heart Failure Reviews. Dec. 2006;11(4):279-88. [pmid: 17131074].
23 Ferreira AC, Macedo FY. A review of simple, non-invasive means of assessing peripheral arterial disease and implications for medical management. Annals of Medicine. Mar. 2010;42(2):139-50. [pmid: 20156042].
24 Flu HC, Tamsma JT, Lindeman JH, et al. A systematic review of implementation of established recommended secondary prevention measures in patients with PAOD. Eur J Vasc Endovasc Surg. Jan. 2010;39(1):70-86. [pmid: 19910222].
25 Fowkes FG, Murray GD, Butcher I, et al. Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. Jul. 9. 2008;300(2):197-208. [pmid: 18612117].
26 Gardner AW, Afaq A. Management of lower extremity peripheral arterial disease. Journal of Cardiopulmonary Rehabilitation & Prevention. Nov. 2008;28(6):349-57. [pmid: 19008688].
27 Gey DC, Lesho EP, Manngold J. Management of peripheral arterial disease. Erratum appears in Am Fam Physician. 2004 Apr 15;69(8):1863]. Am Fam Physician. Feb. 1. 2004;69(3):525-32. [pmid: 14971833].
28 Greenhalgh J, Bagust A, Boland A, et al. Clopidogrel and modified-release dipyridamole for the prevention of occlusive vascular events (review of Technology Appraisal No. 90): a systematic review and economic analysis. Health Technology Assessment (Winchester, England). Sep. 2011;15(31):1-178. [pmid: 21888837].
29 Hankey GJ, Norman PE, Eikelboom JW. Medical treatment of peripheral arterial disease. JAMA. Feb. 1. 2006;295(5):547-53. [pmid: 16449620].
30 Heald CL, Fowkes FG, Murray GD, et al. Risk of mortality and cardiovascular disease associated with the ankle-brachial index: Systematic review. Atherosclerosis. Nov. 2006;189(1):61-9. [pmid: 16620828].
31 Helfand M, Buckley DI, Freeman M, et al. Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. [Summary for patients in Ann Intern Med. 2009 Oct 6;151(7):I-38; PMID: 19805766]. Annals of Internal Medicine. Oct. 6. 2009;151(7):496-507. [pmid: 19805772].
32 Helfand M, Buckley D, Fleming C, et al. Screening for Intermediate Risk Factors for Coronary Heart Disease: Systematic Evidence Synthesis. 10-05141-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
33 Hiatt WR, Krantz MJ. Masterclass series in peripheral arterial disease. Antiplatelet therapy for peripheral arterial disease and claudication. Vascular Medicine. Feb. 2006;11(1):55-60. [pmid: 16669416].
34 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease): endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; and Vascular Disease Foundation. Circulation. Mar. 21. 2006;113(11):e463-e654. [pmid: 16549646].
35 Hirsch AT, Gotto AM Jr. Undertreatment of dyslipidemia in peripheral arterial disease and other high-risk populations: an opportunity for cardiovascular disease reduction. Vascular Medicine. 2002;7(4):323-31. [pmid: 12710848].
36 Holewijn S, den HM, Stalenhoef AF, et al. Non-invasive measurements of atherosclerosis (NIMA): current evidence and future perspectives. Netherlands Journal of Medicine. Dec. 2010;68(12):388-99. [pmid: 21209464].
37 Karthikeyan VJ, Lip GY. Peripheral artery disease and hypertension: the relation between ankle-brachial index and mortality. Journal of Human Hypertension. Oct. 2007;21(10):762-5. [pmid: 17508016].
38 Khan S, Cleanthis M, Smout J, et al. Life-style modification in peripheral arterial disease. European Journal of Vascular & Endovascular Surgery. Jan. 2005;29(1):2-9. [pmid: 15570264].
39 Kikano GE, Brown MT. Antiplatelet therapy for atherothrombotic disease: an update for the primary care physician. Mayo Clinic Proceedings. May. 2007;82(5):583-93. [pmid: 17511957].
40 LaRosa JC, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. JAMA. Dec. 22. 1999;282(24):2340-6. [pmid: 10612322].
41 Loualidi A, Bredie SH, Janssen MC. Indications of combined vitamin K antagonists and aspirin therapy. Journal of Thrombosis & Thrombolysis. May. 2009;27(4):421-9. [pmid: 18516500].
42 Lumsden AB, Rice TW, Chen C, et al. Peripheral arterial occlusive disease: magnetic resonance imaging and the role of aggressive medical management. World Journal of Surgery. Apr. 2007;31(4):695-704. [pmid: 17345122].
43 Matsagas MI, Jagroop IA, Mikhailidis DP, et al. Is aspirin still the antiplatelet drug of choice for patients with peripheral arterial disease?. European Journal of Vascular & Endovascular Surgery. Mar. 2003;25(3):281-2. [pmid: 12624855].
44 McDermott MM. The magnitude of the problem of peripheral arterial disease: epidemiology and clinical significance. Cleveland Clinic Journal of Medicine. Oct. 2006;73. Suppl-7. [pmid: 17385385].
45 Mohler E III, Giri J. Management of peripheral arterial disease patients: comparing the ACC/AHA and TASC-II guidelines. Curr Med Res Opin. Sep. 2008;24(9):2509-22. [pmid: 18664318].
46 Nayak KR, Cavendish JJ. Risk reduction with clopidogrel in the management of peripheral arterial disease. Vascular Health & Risk Management. 2007;3(3):289-97. [pmid: 17703636].
47 Norgren L, Hiatt WR, Dormandy JA, et al. Inter-Society Consensus for the Management of Peripheral Arterial Disease (TASC II). J Vasc Surg. Jan. Suppl S. 2007;45:S5-67. [pmid: 17223489].
48 Paraskevas KI, Kotsikoris I, Koupidis SA, et al. Ankle--brachial index: a marker of both peripheral arterial disease and systemic atherosclerosis as well as a predictor of vascular events. Angiology. Aug. 2010;61(6):521-3. [pmid: 20634224].
49 Poredos P, Jezovnik MK. Antiplatelet and antithrombotic treatment of patients with peripheral arterial disease. International Angiology. Feb. 2010;29(1):20-6. [pmid: 20224527].
50 Regensteiner JG, Hiatt WR. Current medical therapies for patients with peripheral arterial disease: a critical review. American Journal of Medicine. Jan. 2002;112(1):49-57. [pmid: 11812407].
51 Sander D. Stroke risk prediction beyond classical risk factors: the role of the Ankle-Brachial Index. Cerebrovascular Diseases. 2010;29(6):555-6. [pmid: 20375497].
52 Sander D, Poppert H, Sander K, et al. The role of intima-media-thickness, ankle-brachial-index and inflammatory biochemical parameters for stroke risk prediction: a systematic review. Eur J Neurol. 2011. Sep. 6. [pmid: 21895882].
53 Shanmugasundaram M, Ram VK, Luft UC, et al. Peripheral arterial disease--what do we need to know?. Clinical Cardiology. Aug. 2011;34(8):478-82. [pmid: 21717473].
54 Simon A, Chironi G, Levenson J. Comparative performance of subclinical atherosclerosis tests in predicting coronary heart disease in asymptomatic individuals. European Heart Journal. Dec. 2007;28(24):2967-71. [pmid: 17967818].
55 Society for Cardiovascular Angiography and Interventions, Society for Interventional Radiology, Hirsch AT, et al. 2011 ACCF/AHA Focused Update of the Guideline for the Management of Patients With Peripheral Artery Disease (Updating the 2005 Guideline): A Report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. Sep. 29. 2011:j. [pmid: 21963765].
56 Sontheimer DL. Peripheral vascular disease: diagnosis and treatment. Am Fam Physician. Jun. 1. 2006;73(11):1971-6. [pmid: 16770929].
57 Timaran CH. Invited commentary. Journal of Vascular Surgery. Nov. 2009;50(5):1056. [pmid: 19878786].
58 Tran H, Anand SS. Oral antiplatelet therapy in cerebrovascular disease, coronary artery disease, and peripheral arterial disease. JAMA. Oct. 20. 2004;292(15):1867-74. [pmid: 15494585].
59 U.S. Preventive Services Task Force. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. [Summary for patients in Ann Intern Med. 2009 Oct 6;151(7):I-38; PMID: 19805766]. Annals of Internal Medicine. Oct. 6. 2009;151(7):474-82. [pmid: 19805770].
60 van Kuijk JP, Flu WJ, Bax JJ, et al. Prevalence of (a)symptomatic peripheral arterial disease; the additional value of ankle-brachial index on cardiovascular risk stratification. European Journal of Vascular & Endovascular Surgery. Sep. 2009;38(3):312-3. [pmid: 19524459].
61 Willigendael EM, Teijink JA, Bartelink ML, et al. Influence of smoking on incidence and prevalence of peripheral arterial disease. Journal of Vascular Surgery. Dec. 2004;40(6):1158-65. [pmid: 15622370].
62 Xu D, Li J, Zou L, et al. Sensitivity and specificity of the ankle-brachial index to diagnose peripheral artery disease: a structured review. Vascular Medicine. 2010;15(5):361-9. [pmid: 20926495].