# Literature Search Strategies

## SER Search

### Cochrane Database of Systematic Reviews

(peripheral):ti,ab,kw and (arterial or artery or vascular):ti,ab,kw and (disease*):ti,ab,kw, from 2006 to 2011

### DARE

(peripheral):TI AND ((artery):TI OR (arterial):TI OR (vascular):TI OR (angiopathy):TI OR (angiopathies):TI) IN DARE FROM 2006 TO 2011

### PubMed search strategy

1. “Peripheral Vascular Diseases”[Mesh]
2. #1 AND systematic[sb] Limits: English, Publication Date from 2006 to 2011
3. peripheral[Title/Abstract] AND (vascular[Title/Abstract] OR artery[Title/Abstract] OR arterial[Title/Abstract]) AND (disease[Title/Abstract] OR diseases[Title/Abstract])
4. peripheral[Title/Abstract] AND (angiopathy[Title/Abstract] OR angiopathies[Title/Abstract])
5. #3 OR #4
6. #5 AND systematic[sb]
7. #6 AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb]) Limits: English, Publication Date from 2006 to 2011
8. #2 OR #7

## Key Question Search

Databases searched
■ MEDLINE
■ Cochrane Central Register of Controlled Trials
■ PubMed (publisher subset only)

Key
- / = MeSH subject heading
- ti = word in title
- ab = word in abstract
- $ = truncation
- adj# = adjacent within × number of words
- pt = publication type
- fs = MeSH subheading
- next = words next to each other
- * = truncation
- kw = keyword
- sb = subset of articles in PubMed

### Ovid MEDLINE(R) 1946 to December Week 4 2011, Ovid MEDLINE(R) Daily Update January 10, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 10, 2012

All key questions except KQ4

# | Searches | Results
1 | Peripheral Arterial Disease/ | 581
2 | peripheral arter$ disease$.ti,ab. | 5699
3 | peripheral arter$ occlusive disease$.ti,ab. | 1572
4 | Arterial Occlusive Diseases/ | 23526
5 | Peripheral Vascular Diseases/ | 10268
6 | 1 or 2 or 3 or 4 or 5 | 36089
7 | Ankle Brachial Index/ | 598
8 | (brachial adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab. | 2985
9 | (arm adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab. | 492
10 | ankle index$.ti,ab. | 29
11 | Ankle/bs [Blood Supply] | 1049
12 | Brachial Artery/ph, pp, us [Physiology, Physiopathology, Ultrasonography] | 3972
13 | 7 or 8 or 9 or 10 or 11 or 12 | 7560
14 | 6 and 13 | 2284
15 | Mass Screening/ | 72046
16 | screen$.ti,ab. | 376815
17 | 15 or 16 | 399357
18 | 14 and 17 | 232
19 | “Sensitivity and Specificity”/ | 239856
20 | “Predictive Value of Tests”/ | 114990
21 | False Negative Reactions/ | 14837
22 | False Positive Reactions/ | 22287
23 | Diagnostic Errors/ | 27861
24 | “Reproducibility of Results”/ | 221956
25 | ROC Curve/ | 20968
26 | Reference Values/ | 134590
27 | Reference Standards/ | 29007
28 | Observer Variation/ | 26726
29 | specificit$.ti,ab. | 293693
30 | sensitivit$.ti,ab. | 456717
31 | predictive value.ti,ab. | 46653
32 | accuracy.ti,ab. | 180121
33 | false positive$.ti,ab. | 36725
34 | false negative$.ti,ab. | 21640
35 | miss rate$.ti,ab. | 171
36 | error rate$.ti,ab. | 6743
37 | 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 | 1322092
38 | 13 and 37 | 1539
39 | “tobacco use cessation”/ or smoking cessation/ | 16838
40 | smoking cessation.ti,ab. | 12552
41 | Hypercholesterolemia/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] | 9813
42 | Hyperlipidemias/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] | 8442
43 | Anticholesteremic Agents/ | 11981
44 | (lower$ adj3 cholesterol).ti,ab. | 12415
45 | (reduc$ adj3 cholesterol).ti,ab. | 9864
46 | Diabetes Mellitus/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] | 25997
47 | Diabetes Mellitus, Type 2/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] | 25341
48 | Hypoglycemic Agents/ | 34196
49 | Hemoglobin A, Glycosylated/ | 18177
50 | Blood Glucose/an, me [Analysis, Metabolism] | 96225
51 | Glycemic Index/ | 1411
52 | glycemic control$.ti,ab. | 10136
53 | glycaemic control$.ti,ab. | 4338
54 | glucose control$.ti,ab. | 4877
55 | body weight changes/ or weight loss/ | 19206
56 | weight loss.ti,ab. | 44006
57 | Hypertension/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy] | 68525
58 | Antihypertensive Agents/ | 46382
59 | blood pressure control$.ti,ab. | 6379
60 | (hypertension adj2 control$).ti,ab. | 5028
61 | Platelet Aggregation Inhibitors/ | 22492
62 | Blood Platelets/de [Drug Effects] | 15910
63 | ((anti platelet or antiplatelet) adj2 (therapy or treatment$)).ti,ab. | 4949
64 | 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 | 393959
65 | 6 and 64 | 1920
66 | limit 65 to yr=“1990 -Current” | 1730
67 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. | 612912
68 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ | 234057
69 | Meta-Analysis as Topic/ | 11683
70 | random$.ti,ab. | 573069
71 | clinical trial$.ti,ab. | 170249
72 | controlled trial$.ti,ab. | 86330
73 | 67 or 68 or 69 or 70 or 71 or 72 | 1130823
74 | 66 and 73 | 537
75 | Safety/ | 30253
76 | safety.ti,ab. | 216625
77 | adverse event*.ti,ab. | 56621
78 | adverse effects.fs. | 1199031
79 | adverse effect*.ti,ab. | 82091
80 | side effect*.ti,ab. | 152404
81 | product surveillance, postmarketing/ | 4891
82 | Adverse reaction*.ti,ab. | 19973
83 | Adverse drug reaction*.ti,ab. | 6919
84 | drug toxicity/ | 4685
85 | drug toxicity.ti,ab. | 3106
86 | Harm*.ti,ab. | 78767
87 | 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 | 1578372
88 | 66 and 87 | 428
89 | 18 or 38 or 74 or 88 | 2440
90 | limit 89 to english language | 2251
91 | remove duplicates from 90 | 2244

### Database(s): Ovid MEDLINE(R) without Revisions 1996 to January Week 3 2012, Ovid MEDLINE(R) Daily Update January 26, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 26, 2012

Key question 4 only (Does ABI predict cardiovascular morbidity?)

# | Searches | Results
1 | Ankle Brachial Index/ | 602
2 | (brachial adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab. | 2609
3 | (arm adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab. | 242
4 | ankle index$.ti,ab. | 6
5 | Ankle/bs [Blood Supply] | 725
6 | Brachial Artery/ph, pp, us [Physiology, Physiopathology, Ultrasonography] | 3525
7 | 1 or 2 or 3 or 4 or 5 or 6 | 6261
8 | exp Cardiovascular Diseases/ | 791061
9 | cardiovascular.ti,ab. | 166393
10 | heart.ti,ab. | 294993
11 | cardiac.ti,ab. | 220598
12 | Myocardial.ti,ab. | 124490
13 | Coronary.ti,ab. | 161894
14 | Stroke.ti,ab. | 87660
15 | cerebral.ti,ab. | 127147
16 | Cerebrovascular.ti,ab. | 19654
17 | 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 | 1177740
18 | 7 and 17 | 5107
19 | meta analysis.pt. | 28737
20 | Meta-Analysis as Topic/ | 9737
21 | cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ | 808203
22 | cohort$.ti,ab. | 174319
23 | followup stud$.ti,ab. | 354
24 | follow up stud$.ti,ab. | 18510
25 | 19 or 20 or 21 or 22 or 23 or 24 | 915791
26 | 18 and 25 | 1623
27 | limit 26 to english language | 1528
28 | limit 27 to yr=“2007 -Current” | 791
29 | remove duplicates from 28 | 791

### Cochrane Central Register of Controlled Trials (Central)

Issue 4 of 4, Oct 2011

#1 (peripheral next arter* next disease*):ti,ab,kw, from 1990 to 2012 = 449
#2 ankle:ti,ab,kw AND (brachial OR arm):ti,ab,kw AND (index* OR indices OR ratio* OR gradient* OR pressure):ti,ab,kw = 494
#3 (ankle next index*):ti,ab,kw = 2
#4 (#1 OR #2 OR #3) = 843

### PubMed (publisher subset only)

1/11/2012

All key questions except KQ4

#1 (peripheral artery disease OR peripheral arterial disease) AND screening AND publisher[sb] = 33
#2 (peripheral artery disease OR peripheral arterial disease) AND (cholesterol OR smoking OR glycemic OR glycaemic OR glucose OR weight loss OR blood pressure OR hypertension OR anti platelet OR antiplatelet) AND (random* OR trial OR trials OR systematic OR meta analysis OR metaanalysis) AND publisher[sb] = 26
#3 ankle AND (brachial OR arm) AND (index* OR indices OR ratio* OR gradient* OR pressure) AND publisher[sb] = 98
#4 ankle index AND publisher[sb] = 127
#5 #1 OR #2 OR #3 OR #4 = 190
#6 #1 OR #2 OR #3 OR #4 Limits: English = 183

### PubMed (publisher subset only)

1/26/2012

Key question 4 only (Does ABI predict cardiovascular morbidity?)

#1 ankle AND (brachial OR arm) AND (index* OR indices OR ratio* OR gradient* OR pressure) = 4487
#2 ankle index = 5413
#3 (#1 OR #2) AND publisher[sb] = 147
#4 (cardiovascular[tiab] OR heart[tiab] OR cardiac[tiab] OR myocardial[tiab] OR coronary[tiab] OR cerebral[tiab] OR stroke[tiab] OR cerebrovascular[tiab]) AND publisher[sb] = 20913
#5 #3 AND #4 = 18
#6 cohort*[tiab] OR “follow up study”[tiab] OR “follow up studies”[tiab] OR “followup study”[tiab] OR “followup studies”[tiab] = 232247
#7 #5 AND #6 Limits: English, Publication Date from 2007 to 3000 = 7