# Evidence Tables

Evidence Table 1. HRT and CVD: Incidence and Mortality - Cohort Studies of Primary Prevention

Author, Journal, Date | Setting, Study Population Date | Measurement of Hormone Exposure, Co-morbidity, Other Risk Factors | Type Controls | Outcomes Evaluated, Documentation | FU Length Loss to FU | Assessment of CVD risk factors | RR CVD Among Users Compared to Non-Users | RR by Duration HRT | RR CVD Associated With Current Use and By Duration | RR CVD Associated With Pass Use and By Duration | CVD Mortality RR Among Users Compared to Non-Users | Comments
Byrd BF, Jr., Burch JC, Vaughn WK. The impact of long term estrogen support after hysterectomy. A report of 1016 cases. Ann Surg. 1977;185(5):574–580. | 1016 with hysterectomy ages 22–78 and placed on estrogen who used over 3 years. Caucasian females from middle TN. | Medical records | | Death cert. | 100% FU | No adjustment | | | | | Heart dis | Premarin 1.25 mg/day
| | | | | | | | | | | [underlined: SMR] 0/E | No adj. for confounding
| | | | | | | | | | | 13/35 | Poor generalizability
| | | | | | | | | | | SMR 0/E - CVA 8/15 | Quality: poor
McMahon B. Cardiovascular disease and non-contraceptive oestrogen therapy. Edinburgh, Scotland: Churchill Livingstone; 1978. | Use data of Hoover and Gray, 1977 | | | | Average 12 years | No adj. | | CVD Mortality use/non use: | | All cause: | | Highest risk stroke in women taking higher doses E.
| | | | | | | | < 5 yr: 0 deaths | | 40% expected | | Quality: poor
| | | | | | | | > 15 yr: 0.8 NS | | CVD: RR 0.4
| | | | | | | | Stroke Mortality: | | Stroke: RR 0.8
| | | | | | | | >15 y: 1.7 NS
Hammond CB, Jelovsek FR, Lee KL, Creasman WT, Parker RT. Effects of long-term estrogen replacement therapy. I. Metabolic effects. Am J Obstet Gynecol. 1979;133(5):525–536. | Duke University cohort of hypoestrogenic women diagnosed 1940-1969. Only followed if returned for FU for 5 years and must have been seen after Jan. 1, 1974 | | | Medical record review | 5 years at least. | Adj. for age, race, duration FU: | | | | | | Poor generalizability
| 2 groups: | | | | | 37 events CVD in NoE | | | | | | Survivors not clear how outcome defined.
| no HRT: n = 309 | | | | | 7 events CVD in E p<.001 | | | | | | Quality: poor
| yes HRT: n = 301
Wilson, 1985 ^11^ | Framingham | Biennial exam only includes information on HRT use at baseline | Internal | Physician review of notes and death certificates | 8 years | Adj for Cholesterol, BMI, smoking BP, age and alcohol | Total CVD | | | | [underlined: Death total CVD] 1.94 (NS) | Throughout the study (exams 1–7) age adjusted, wt, and cholesterol lower in women who later reported ERT use.
| Age >50 and post-menopausal | Almost all conjugated estrogen | | [underlined: Coronary heart disease] includes: | | Not Adj for DM | 1.76, P < 0.01 | | | | Death cancer | Evaluated confounding by surgical menopause and no relationship
| Patients included if they participated in 12^th^ biennial survey | Progestin use rare (>5%) | | Angina, MI, SCD and coronary death | | FMH | Cerebrovascular | | | | 0.7 (p=NS) | + interaction with smoking.
| n=1234 | HRT use classified as ever use if reported in any 8–12 biennial exams. | | [underlined: Cerebrovascular disease (CVD)] includes: | | | 2.27 ( P < 0.01) | | | | [underlined: Death all causes] 0.97 (NS) | 35% MI's unrecognized (by ECG)
| | Duration assessed, dose not assessed | | 1^st^ CVA or TIA | | | CHD | | | | | Quality: good
| | Overall rate use 24% | | [underlined: Cardiovascular disease (CVD)] includes: | | | 1.9 ( P < 0.1)
| | | | CHD, CVA, Claudication & CHF | | | [underlined: CHF]
| | | | | | | 1.15
Henderson BE, Ross RK, Paganini-Hill A, Mack TM. Estrogen use and cardiovascular disease. Am J Obstet Gynecol. 1986;154(6):1181–1186. | Leisure world retirement community, 1981. White, affluent, well educated. After 3 mailings 62% returned questionnaires. N = 7610 | Detailed mailed health questionnaire all hospital admissions evaluated. Biannual remailings. Hormone use = ever/never, | Internal | 435 deaths all cause acute MI. Death certificates used to code deaths | | No adj. except age | | | | | All cause: | Dose/duration not eval
| Mean age 74 | | | | | | | | | | 0.84(p = .06) | No. adj. confounding
| | | | | | | | | | | MI: 0.54(p = .07) | Definitions use unclear
| | | | | | | | | | | | Definition MI unclear
| | | | | | | | | | | | Poor generalizability
| | | | | | | | | | | | Quality: poor
Bush, 1987 ^22^ | 2270 white women ages 40–69 in Lipid Research Clinics Prevalence Study recruited. 1972-1976, n=2270, 593 used, 1677 non-use | Lab, questionnaire, EKG exam, ETT, obtained at 2^nd^ visit (current users) | Internal | 44 deaths | | Adj for: Age, HTN, Tobacco, education, BMI, LDL | Age adj. | | | | All cause: | E use only evaluated at one time.
| | | | Death certificates, Medical record review. | | [underlined: Not Adj:] | [underlined: Current] | | | | [underlined: Age adj.] | Adding HDL/LDL to model B from - 0.82 to - 0.47
| | | | Interview next of kin. | | DM, exercise, FMH, alcohol | 0.34(0.12–0.81) among all | | | | 0.54(0.29–0.79) | Users/non-users similar in CVD disease prevalence. Very important paper in suggesting much, though not all decreased risk due to Inc HDL.
| | | | | | | cox model | | | | SMR of non-users | Quality: good
| | | | | | | B= -0.47 | | | | 67 sug “healthy participant effect”
| | | | | | | P= 0.29
| | | | | | | Stroke
| | | | | | | 0.40(0.01–3.07)
Eaker, 1987 ^63^ | Reanalysis of Framingham as above excluding angina | Biennial exam only includes information on HRT use at baseline | Internal | Coronary heart disease - no angina | 8 years | | [underlined: Ages 50–59:] | | | | | Excludes angina as endpoint
*Reanalysis of Framingham study excluding angina - adapted from Stampfer | | Almost all conjugated estrogen | | | | | 0.4 p>.05 | | | | | Quality: good
| | Progestin use rare (>5%) | | | | | [underlined: Ages 60–69:]
| | HRT use classified as ever use if reported in any 8–12 biennial exams. | | | | | 2.2 p>.05
| | Duration assessed, dose not assessed
| | Overall rate use 24%
Pettiti, 1987 ^49^ | 12/68–2/72 | Complete multiphasic examination through 1977 contacted yearly or returned for exam. | Internal | Deaths, NDI, death certificates | 1983 | DM | | | | | [underlined: All diseases of circulatory systems (adj)] | Overall mortality in users from accidents, homicide, suicide was lower (RR 0.8)
| 16,638 women 18–54 | Classified: ever/never | | | | Lipids | | | | | 0.6 (0.3–1.1) | Almost all ERT
| Walnut Creek | | | | | FMH | | | | | Multivariate adj | No information on occupation or income but differences persisted after adj. edu/marital.
| California | | | | | | | | | | [underlined: Ischemic heart disease (age - adj)] | FU through 83 but no data on HRT past 77
| N= 6093 | | | | | | | | | | 1.3 (0.2–7.7) | Quality: fair (misclassification potential problem)
| | | | | | | | | | | [underlined: Acute MI] (age-adj)
| | | | | | | | | | | 0.3 (0.1–1.3)
| | | | | | | | | | | [underlined: All cerebrovascular disease (age-adj)]
| | | | | | | | | | | 0.6 (0.2–2.2)
Criqui, 1988 ^54^ | 1868 50–79 women residing in planned community, California 1972. | Interview, exam, lab 1972; Re-eval 1981 and these women followed. | Internal | Vital status, death certificates reviewed by nosologist coded ICD. | 12 | [underlined: Adj. for] | | Mortality by duration | | | Age adj | Relied on death certificate review
| White, upper-middle class | Current use, non-use | | Compared 3 year subsequent mortality among 9 year survivors. | 99.8% complete | BMI | | [underlined: < 8 y use (on-off)] | | | All cause | Definitions CVD, CHD not provided
| 39.9% used HRT | | | | | Chol | | [underlined: all:] 0.88(0.56–1.36) | | | 0.69(0.55–0.87) | 70% women discontinued estrogen
| | | | | | GWC | | [underlined: CVD:] 1.20(0.62 –2.35) | | | CVD | Interaction with tobacco highly significant
| | | | | | BP | | [underlined: CHD:] 1.24(0.55–2.78) | | | 0.81(0.61–1.08) | Never/current users:
| | | | | | Age | | [underlined: < 8 y use (off-on)] | | | CHD | lower risk
| | | | | | Social class | | [underlined: all:] 1.58(0.68–3.65) | | | 0.75(0.45–1.24) | Past users:
| | | | | | Not adj. for | | [underlined: CVD:] 1.55(0.32–6.62) | | | [underlined: Multivar adj.] | higher risk
| | | | | | Family history | | [underlined: CHD:] 2.62(0.59–11.61) | | | All cause: 0.79(0.62–1.01) | Quality: fair
| | | | | | Exercise | | ≥ [underlined: 8 y use] | | | CVD: 0.96(0.65–1.43)
| | | | | | Alcohol | | [underlined: all:] 0.35(0.1–1.22) | | | CHD: 0.99(0.59–1.67)
| | | | | | | | [underlined: CVD:] 0.40(0.05–3.19) | | | CVD mortality not decreased in women who never smoked
| | | | | | | | [underlined: CHD:] 0.36(0.04–3.02)
Hernandez-Avila, 1990 ^62^ | All female members group health Seattle, ages 50–64 | Pharmacy and medical records. Current users for 12 mos. after filling prescription year, dose, duration evaluated | Internal | First MI | 1978-1983 | Not adj: | [underlined: Age/calendar year adj.] | First MI | | | | Drug prescriptions used as markers for risk factors.
see Evidence Table 2 case-control | 1978-1984 | | Also preformed nested case control study to control for confounding | N=120 | | BMI | [underlined: Current/non] | [underlined: duration > 1 year] | | | | Survivors (made it to hospital)
| | | N=721 controls | | | Smoking | 0.7(0.4–1.3) | 0.7(0.3–1.3) | | | | No evaluation for type of menopause.
| | | | | | Lipids | CCS analysis | | | | | Quality: fair - poor control of confounding
| | | | | | | current:
| | | | | | | 0.7(0.4–1.4)
| | | | | | | past:
| | | | | | | 0.6(0.12.1)
Hunt K, Vessey M, McPherson K. Mortality in a cohort of long-term users of hormone replacement therapy: an updated analysis. Br J Obstet Gynaecol. 1990;97(12):1080–1086. | 4544 long term HRT users (≥ 1 year) England & Wales recruited from menopause clinics ages 45–54 | Interview, exam, detailed HRT history | External | All cause, CVD, mortality. Deaths coded using ICD codes. | 1988 | No adj. | | | | | SMR | Not generalizable.
| | | | | | | | | | | All cause: | Tended to be of higher social class.
| | | | | | | | | | | 0.56(0.47–0.66) | Mean duration use 66.9 months
| | | | | | | | | | | [underlined: Ischemic heart dis:] | No definition IHD
| | | | | | | | | | | 0.41(0.20–0.61) | Quality: poor
| | | | | | | | | | | All CVD
| | | | | | | | | | | 0.44(0.28–0.59)
| | | | | | | | | | | Stroke
| | | | | | | | | | | 0.54(0.24–0.84)
Henderson BE, Paganini-Hill A, Ross RK. Decreased mortality in users of estrogen replacement therapy. Arch Intern Med. 1991;151(1):75–78. | Leisure world retirement community. 8881 women returned health questionnaire. | Mailed health questionnaire. | Internal | Death | Dec. 88 | [underlined: Adj. for:] | | | | | Multivar | Mean duration use 10 years
| Mean age 73. | Estrogen use: | | Death certificates obtained | 56,020 py | BP | | | | | [underlined: adj. use/non] | >50% used HRT
| | ever/never | | Follow-up mailings '83, '85. | | History angina/MI | | | | | All cause: 0.79(0.71–0.88) | Quality: poor - no adjustment for CVD RF/confounding in CVD analyses.
| | | | 1477 deaths | | Smoking | | | | | Only age adjusted; use/non
| | | | | | Alcohol | | | | | [underlined: Acute MI:]
| | | | | | BMI | | | | | 0.60 p< .001
| | | | | | Exercise | | | | | [underlined: Ischemic HD:]
| | | | | | Age menopause | | | | | 0.79 p
| | | | | | [underlined: Not Adj.] | | | | | [underlined: Other heart Dis:]
| | | | | | Lipids | | | | | 0.68 NS
| | | | | | DM | | | | | Occlusive Stroke/age
| | | | | | Family hst. | | | | | 0.63 NS
Wolf, 1991 ^52^ | National sample n=1944 White post-menopausal women ≥ 55 from epidemiologic follow up of NHANE's I 1971-1975. Mean age 66 | Baseline exam, lab Categorized as ever never | Internal | 631 deaths. Outcomes CVD death. Death certificate review ICD, codes, underlying cause. Hospital, medical record review, vital status ascertained 82–84, 86, 87 | 16 years | [underlined: Adj for:] | | | | | Multivar (CVD) ever/never
| | | | | | HTN | | | | | 0.66(0.48–0.90)
| | | | | | DM | | | | | natural [underlined: menopause]
| | | | | | BMI | | | | | 0.69(0.45–1.06)
| | | | | | Tos | | | | | surgical [underlined: menopause]
| | | | | | CHOL | | | | | 0.80(0.39–1.67)
| | | | | | MI
| | | | | | Age
| | | | | | Age men.
| | | | | | Education
Falkeborn, 1992 ^76^ | Population based prospective study of 23,247 who had at least 1 prescription for estrogen 1977-1980 in Uppsala, Sweden | Random sample of 735 provided data on confounders | External; Population rates used | 1^st^ MI | 133,372 p-y | Not adj for | Univariate ERT SIR:
| | | | | Average observation time per persons 5.8 years. | DM | 0.81 (0.71–0.92)
| | | | | | HTN | Univariate CHRT SIR:
| | | | | | Lipids | 0.50 (0.28–0.80)
| | | | | | FMH | Multivariate SIR (conjugated or estradiol) ERT:
| | | | | | Exercise | 0.73 (0.59–0.90)
| | | | | | BMI | Multivar SIR all ERT (0.88 (0.64–1.19)
| | | | | | SES
| | | | | | Only age adjusted
Lafferty FW, Fiske ME. Postmenopausal estrogen replacement: a long-term cohort study. Am J Med. 1994;97(1):66–77. | Non-random prospective 1964 - 1983 | 0.625–1.25 mg premarin all 1964-1983 no progesterone used | 76 women with same eligibility declined HRT | Prospective: biennial exams, labs EKG | Followed until 1989 | No adjustment | Age-adjusted RR user/non-users | | | | | Small numbers
| All post-menopausal women 43–60 from private practice offered | 1983 on the remaining 24 women with uterus received progesterone days 14–25 of every 6^th^ months | | Outcome: MI, EKG changes | | | Ischemic changes on EKG | | | | | Poor design
| ERT candidates: healthy, white normal exam, EKG, labs | Follow-up | | | | | 0.84 (0.39–1.03) | | | | | Non-random
| 76 declined ERT | Annual PE, labs, EKG | | | | | MI | | | | | Non-population based
| 96 used ERT | | | | | | 0.34 (0.09–1.34) | | | | | Not generalizable
| 58 ineligible | | | | | | CVA (no strokes in ERT cohort) | | | | | RR estimate without adjustment for confounders
| | | | | | | p ≤ 0.025 | | | | | Unconventional progesterone use
| | | | | | | | | | | | Quality: poor, bias
Sturgeon, 1995 ^92^ | Cohort of 49,000 women followed 1979-1989 in BCDDP follow-up study menopausal | Baseline questionnaire up to 6 annual follow-up interviews | Internal | Death- | | Only age adjusted | [underlined: < 5yr use] | [underlined: >5 yr use] | | | Ever/never | Current use all cause mortality 0.3 (0.2–0.4)
| | Use, duration, repeated measures | | Vital status evaluated by phone interview, tracing by mail death certificates obtained/reviewed underlying cause death code | | | CVD 0.9 | CVD 0.8 | | | CVD:0.7(0.6–0.8) | All cause mortality (0.7 (0.7–0.8)
| | | | | | | CHD 1.0 | CHD 0.8 | | | CHD 0.7(0.6–0.9) | Women recently stop HRT have all cause mortality 1.4 (1.2–1.7)
| | | | | | | Stroke 0.8 | Stroke 1.1 | | | Stoke 1.0(0.7–1.4) | (stopped 2–3 years prior
| | | | | | | [underlined: Mortality stroke] | | | | | Women stopping more distant past similar to non-users
| | | | | | | Current/never:0.4 (0.2–1.0) | | | | | Quality: Poor
| | | | | | | 2–3.9 years since use:3.3 (1.9–5.8)
| | | | | | | [underlined: Mortality CHD]
| | | | | | | Current/never: 0.3 (0.2–0.5)
| | | | | | | 2–3.9 yrs since last use 0.9 (0.5–1.9)
Folsom, 1995 ^55^ | Iowa 41,837 ages 55–69 analyses restricted to post-menopausal with information on HRT n=41,070 | Mailed questionnaire anthopometric measure used, HRT use categorized as current, former, never and duration | Internal | Coronary disease, mortality, stroke | 6 years | Excellent control of confounders | | | | | CHD Mortality | No data on prog use
| | | | | | | | | | | Former/never: | All Cause mortality:
| | | | | | | | | | | 0.57 (0.38–0.85) | RR 0.95(0.76–1.19)
| | | | | | | | | | | Current: | Quality: good
| | | | | | | | | | | 0.82 (0.47–1.43)
| | | | | | | | | | | [underlined: <5 yrs:]
| | | | | | | | | | | 0.57 (0.18–1.75)
| | | | | | | | | | | >5 yrs:
| | | | | | | | | | | 0.90 (0.47–1.72)
| | | | | | | | | | | Stroke
| | | | | | | | | | | Former
| | | | | | | | | | | 0.88 (0.48–1.61)
| | | | | | | | | | | Current
| | | | | | | | | | | 0.95 (0.37–2.43)
| | | | | | | | | | | [underlined: <5 yrs:]
| | | | | | | | | | | 2.08 (0.74–5.82)
| | | | | | | | | | | >5 yrs:
| | | | | | | | | | | 1.05 (0.41–2.64)
Ettinger, 1996 ^84^ | Kaiser-women identified 1969-1973 who had used HRT ≥5yrs and women with ≤1 yr use | Prescription filled known date menopause | Same cohort age matched had filled prescription for ERT but not used >1yr. | [underlined: Deaths] 68% validated | | Adj. for Age, tob, BMI, alcohol TC, EKG | | | | | Coronary disease | 5.6% ever use progesterone.
| Date menopause known for ERT begun within 3 yrs. of menopause exclusions (many) | Medical records reviewed | n=222 | CHD | | | | | | | 0.40 (0.16–1.02) | Mean ERT 0.9 mg. then 0.5 mg.
| n=232 ERT users | | 13% had used estrogen | CVD | | | | | | | [underlined: Cardiovascular] disease | Biased cohort.
| Non-users age matched and not used | | | | | | | | | | 0.27 (0.10–0.71) | Fair control of confounding
| E >1yr. n=222 | | | | | | | | | | All cause | Quality: poor
| | | | | | | | | | | 0.54 (0.38–0.76)
Grodstein, 1996 ^8^ | Nurses Health Study began 1976 | Mailed questionnaire with biennial follow-up | Internal | [underlined: CVD -] Who criteria | | Age, HTN, FMH, Chol, Age men., DM and BMI | Time since last use | Major Coronary dis | [underlined: Major CHD (adj)] | [underlined: Multivar adj major CHD] | | Coronary heart disease by dose
| n=59,337 post-menopausal | 1976 - HRT use assessed | | Non-fatal MI | | | <3 yrs. | <2 yrs HRT current | ERT 0.60 (0.43–0.83) | 0.85 (0.71–1.01) | | 0.3 ERT RR 0.57
| | 1978 - Type HRT | | Fatal CHD | | | 0.69 (0.48–1.0) | 0.53 (0.31–0.93) | CHRT 0.39 (0.19–0.78) | Stroke | | *0.625 E RR 0.53
| | 1980 - Dose, menopause classified | | CABG/PTCA | | | 3–4.9 yrs. | >10yrs HRT current | HRT 0.60 (0.47–0.76) | 0.99(0.80–1.22) | | 1.25 E RR 0.82
| | | | CVA Medical records reviewed when possible | | | 0.81 (0.5–1.2) | 0.70 (0.47–1.04) | Stroke (adj) | | | >1.25 RR 0.92
| | | | NDI also used | | | p trend ≤0.05 | Stroke | ERT 1.27 (0.95–1.69) | | | trend 0.22
| | | | 584 non-fatal MI | | | | ≥10yrs | CHRT 1.09 (0.66–1.8) | | | Stroke
| | | | 186 CHD deaths | | | | 1.01 (0.69–1.46) | HRT 1.03(0.82–1.31) | | | 0.64
| | | | 572 CVA's | | | | | Ischemic Stroke (adj) | | | 1.24
| | | | 553 PTCA/CABG | | | | | ERT 1.63 (1.10–2.39) | | | 1.44
| | | | Maj. CHD = non fatal + fatal MI | | | | | CHRT 1.42 (0.73–2.75) | | | >1.25 1.86
| | | | | | | | | HRT 1.40(1.02–1.92) | | | p tend 0.047
| | | | | | | | | Subarachnoid | | | No significant interaction
| | | | | | | | | ERT 1.35 | | | No change RR with # visits
| | | | | | | | | CHRT 0.53 | | | Silent MI excluded.
| | | | | | | | | HRT 0.90(0.57–1.41) | | | Current Users:
| | | | | | | | | CABG/PTCA | | | Decrease FMH, TOB and DM,
| | | | | | | | | HRT 0.99 | | | Increase MVI, ASA, ETOH, Vitamin E and leaner
| | | | | | | | | | | | Quality: good
Sourander, 1998 ^51^ | 7944 women ages 57–64 who participated in mam screening program Turku, Finland 1987-1988 | Biennial questionnaire linked hospital data, death registry | Internal | CVD | 53,305 person-years | Not adj. for lipids.. exercise, alcohol | CVD morbidity | | | | CVD | Mean oral dose 1.46 mg
| | Trained nurses helped with questionnaire baseline +3 for most Exposure = never, ever, current, former | | CAD | | | Former | | | | Former | Lipids not in model
| | | | AMI | | | 1.11 (0.89–1.39) | | | | 0.75 (0.41–1.37) | Adj. for social class
| | | | CVA | | | Current | | | | Current | Quality: fair
| | | | | | | 1.07 (0.86–1.32) | | | | 0.21 (0.08–0.59)
| | | | | | | CAD morbidity | | | | CAD death
| | | | | | | Former | | | | Former
| | | | | | | 1.23 (0.88–1.71) | | | | 0.64 (0.27–1.47)
| | | | | | | Current | | | | Current
| | | | | | | 1.05 (0.76–1.46) | | | | 0.19 (0.05–0.77)
| | | | | | | Stroke morbidity | | | | CVA death
| | | | | | | Former | | | | Former
| | | | | | | 1.08 (0.55–2.10) | | | | 1.05 (0.41–2.68)
| | | | | | | Current | | | | Current
| | | | | | | 0.86 (0.42–1.75) | | | | 0.16 (0.02–1.18)
Schairer, 1996^75^ | Uppsala Health Care Regiou, Sweden | [underlined: 3 groups] | External | Mortality | 199,810 p-y | | | | | | [underlined: SMR circulatory disease] | No adj for confounding
| Cohort = all women prescribed | 1. Estradiol or CE-more potent | | | 1472 deaths | | | | | | 0.69 (0.64–0.75) | All cause mortality decreased 23%
| HRT 4/77 - 3/80 | 2. Other estrogens | | | | | | | | | IHD: | Compare: Falkeborn 92 incidence rates (lower) - ? selection for low risk
| n=23, 246 women >35 yrs. Mean age 54.5 | 3. combined | | | | | | | | | 0.69 (0.55–0.69) | Quality: poor
| | | | | | | | | | | Cerebrovasc:
| | | | | | | | | | | 0.79 (0.67–0.91)
| | | | | | | | | | | IHD:
| | | | | | | | | | | other 0.7 (0.6–0.8)
| | | | | | | | | | | more potent 0.6 (0.5–0.7)
| | | | | | | | | | | CHRT 0.4 (0.2–0.6)
| | | | | | | | | | | Cerebrovasc:
| | | | | | | | | | | other 0.9 (0.7–1.0)
| | | | | | | | | | | more potent 0.7(0.6–0.9)
| | | | | | | | | | | CHRT 0.6 (0.3–1.1)
Cauley, 1997 ^50^ | 9704 > 65 yrs. Recruited osteoporotic fractures analyses restricted to women with known HRT use | Detailed information collected at baseline interview | External- US | Death - ascertained through study protocol | | SES | | | | [underlined: Death- use 1–9 yrs:] | Current | Women using HRT
| | Updated at 3rd visit | Internal- white women | 99% complete | | | | | | CVD: | All CVD deaths | All cause mortality
| | 14% currently using oral HRT (of those, 20% CHRT, 88% ERT | | Copies of discharge summaries and death certificates obtained | | | | | | 6.78 (0.44–1.38) | 0.46 (0.29–0.73) | current 0.69(0.54–0.87)
| | | | | | | | | | CHD: | All CHD deaths | past 0.79(0.66–0.95)
| | | | | | | | | | 0.97 (0.46–2.05) | 0.49 (0.26–0.93) | Quality: good
| | | | | | | | | | CVA: | CVA
| | | | | | | | | | 0.66 (0.2–2.2) | 0.47 (0.2–1.08)
| | | | | | | | | | [underlined: Death - use > 10 year:] | Past
| | | | | | | | | | CVD: | All CVD:
| | | | | | | | | | 0.3 (0.16–0.57) | 0.86 (0.65–1.15)
| | | | | | | | | | CHD: | All CHD:
| | | | | | | | | | 0.25 (0.09–0.68) | 0.82 (0.55–1.23)
| | | | | | | | | | CVA: | CVA:
| | | | | | | | | | 0.38 (0.13–1.10) | 0.85 (0.48–1.49)

Evidence Table 2. HRT and CVD - Case Control Studies of Primary Prevention

Study, Year, Journal | Setting/Study Population Date | Cases | Controls | Exposure Assessment/Classification | Important Confounders Not adjusted for | Major Findings Multivariable Adjusted Odds Rating (MAOR) 95% CI | Major Findings by Duration Use HRT (MAOR) 95% CI | | Time Since Last Use | Time Since Starting Estrogen | Findings by Other Sub-group Analyses (MAOR) | Comments
Rosenberg L, Armstrong B, Jick H. Myocardial infarction and estrogen therapy in post-menopausal women. N Engl J Med. 1976;294(23):1256–1259. | US | 2 sets hospitalized patients Set from several countries Set from Boston post-menopausal women ages 40–75 | Women without Estrogen related or possible Estrogen related admissions | Nurse interview | Lipids | 49% CO | No difference in duration use | | | | | Premarin most commonly used
| UK | n=336 with acute MI | n=2536 | | | HRT users | | | | | | Quality: fair
| New Zealand | | n=4194 | | | 4.3% CA
| Canada | | considered controls | | | HRT users
| Germany | | | | | 0.97 (0.48–1.95)
| Italy | | | | | Conjugated estrogen alone
| Israel | | | | | 0.85 (0.38–1.91)
| 24 Boston area hospitals
Talbott E, Kuller LH, Detre K, Perper J. Biologic and psychosocial risk factors of sudden death from coronary disease in white women. Am J Cardiol. 1977;39(6):858–864. | Allegheny County, Penn | All cases sudden death from otheroslerotic heart disease while women ages 25–64 without known heart disease. Identified using coroner's records, death certificates, letters to physicians n=64. | Matched by block age +/- 1–10 yr., n = 64 | Family interview, some physician contact | | 3 cases use HRT | | | | | | Few cases
| | | | | | 8 controls use HRT | | | | | | No eval if post menopausal
| | | | | | | | | | | | No adj. confounding
| | | | | | | | | | | | Exposure collected from case proxy
| | | | | | | | | | | | Quality: poor: no evaluation control
Jick H, Dinan B, Rothman KJ. Noncontraceptive estrogens and nonfatal myocardial infarction. JAMA. 1978;239(14):1407–1409. | | Non-fatal MI discharged from hospital | n=165 | Telephone interview | Adjusted for type of sterilization | Not adjusted (non-fatal MI) | | | | | | Duration E use in users ave. 2.6 years in cases and 1.7 years in controls
| | 1–6/1975 | ? discharged from hospital - not explicitly stated | | | RR 7.5 (2.4–24) | | | | | | *Non-fatal MI
| | n=107<age 46 | 86 had natural menopause or she or spouse sterilized | | | | | | | | | Of the 17 MI's 16 use tobacco
| | 47/107 had natural menopause, hysterectomy, tubule laceration, spouse vasectomy | n=89 of these 61 apparently healthy | | | | | | | | | Quality; poor, based on poor inclusion criteria, no adjustment, poor characterization of estrogen use.
| | n=30 MI 39–46, but only 17 healthy prior to MI
| | Final n=17 healthy menopausal
Pfeffer ^64^ | Cohort of 15, 500 living in community | Potential cases first MI, history angnia, unattended death of cardiac etiology | File of all women residents | Medical records, necropsy reports, EKG's, laboratory, all reviewed. | Exercise | Adjusted | | | | | | Mean daily dose 0.408 mg. in cases
| 3/64–12/74 | Cases: | 3:1 ratio | | Alcohol | For age, DM, HTN | | | | | | 0.315 mg. in controls
| ages 57–98 | n=274 | | | | Ever use: | | | | | | Quality: fair (little assessment of confounding)
| No African Americans | MI=220 | | | | 0.86 (0.54–1.37) | | | | | | Mean duration recent use 72 days
| Southern California | Sudden death = 13 | | | | Current use:
| Retirement community with centralization of care | Angina = 14 | | | | 0.68 (0.32–1.42)
| | | | | | For severe CAD: adj, age, DM, HTN
| | | | | | Ever use:
| | | | | | 0.87 (0.57–1.34)
| | | | | | Current use:
| | | | | | 0.78 (0.38–1.63)
Rosenberg L, Slone D, Shapiro S, Kaufman D, Stolley PD, Miettinen OS. Noncontraceptive estrogens and myocardial infarction in young women. JAMA.1980;244(4):339–342. | US | Women 30–49 admitted to coronary care units with MI | Women 30–49 admitted to hospitals with diagnosis other than MI from medical, ortho, surg wards. | Nurse interviews | Lipids | Unadjusted | <1 yr | 1.9 | | | | Most estrogen used 1.25 mg or less
| Northeast | N=477 | n=1832 | Standard questionnaire | | Recent 1.3 (0.8–2.1) | 0.8 | | | | | 90% recent, 75% past, used for symptoms of menopause
| 7/76–7/77 | Median age 45 | Median age 41 | | | Past 1.2 (0.8–1.8) | 1.1 | | | | | Young women.
| | | | | | Adjusted | >5 | 0.6 | | | | Quality: good
| | | | | | Recent 1.0 (0.6–1.7) | Non stat sig
| | | | | | Past 1.2 (0.8–1.8)
| | | | | | No increase in smokers
Adam S, Williams V, Vessey MP. Cardiovascular disease and hormone replacement treatment: a pilot case-control study. British Medical Journal Clinical Research Ed.1981;282(6272):1277–1278. | Wales, England | 248 death certificates | Controls drawn from practice list of the general practioner submitting names of cases randomly selected by procedure and age | Post-mortem wrote to general practitioners who used hospital records to fill out questionnaire | | | | | | | Mortality | Cases excluded if MI or SAH terminal event in long-standing chronic disease
| | Women ages 50–59 during 11/78 with cause of death MI or SAH | | | | | | | | | No OR given | No blinding so GP's aware CA/C0 status
| | Exclusions: | | | | | | | | | No relationship identified | Only 3% using HRT
| | n=58 see comments | | | | | | | | | | Quality: poor, non-blind ascertainment, many exclusions ? bias
| | n=76 MI
| | n=23 SAH
Ross RK, Paganini-Hill A, Mack TM, Arthur M, Henderson BE. Menopausal oestrogen therapy and protection from death from ischaemic heart disease. Lancet.1981;1(8225):858–860. | Retirement community, 1 yr 20,000 white, highly educated | All females whose primary or underlying cause of death was ischemic, dying 1971-1975 < age 80 | Living controls matched by race, age (year), date of entry into the community | Medical record interview | Only adj. for matching factors. | | | | | | Mortality | When using living controls 1.25 conferred same protection
| High SES 1971 | N=133 | Selected by resident registry | | | | | | | | Univariate | Findings similar, when analyzed using only autopsy cases
| | | N=124 | | | | | | | | OR 0.57 p< .05 (deceased control) or | No adjustment for confounding
| | | 2^nd^ control set chosen from register of all who had died 71–76 matched on date of death (year) + above n=124 | | | | | | | | 0.43 p<.01 (living control) | Quality: poor
| | | Exclusions: | | | | | | | | In women with no history of MI, CVA, angio, DM, HTN,
| | | breast, ovary, uterine cancer, fractures, cerebrovascular, peripheral vascular disease | | | | | | | | RR living (co) 0.43
| | | | | | | | | | | RR deceased (co) 0.39
| | | | | | | | | | | When these factors present
| | | | | | | | | | | OR 0.48–0.58
Szklo M, Tonascia J, Gordis L, Bloom I. Estrogen use and myocardial infarction risk: a case-control study. Prev Med.1984;13(5):510–516. | 5 general hospitals | White females 35–64 admitted with first MI | 2 controls per case from same hospital Discharged lists matched by age ± 2 years and date admission n=45 | Records abstracted | DM | Unadjusted OR | | | | | | Unclear how case limited to 1^st^ MI
| Maryland 1971-1972 | n=39 | Patients with old MI excluded. | Interviews conducted 3 months - 3 years of index date (similar time for cases/co | Lipids | Past use 0.83 | | | | | | No proxies
| | | Only post-menopausal CA/CO pairs analyzed | | BMI | Adjusted OR | | | | | | Long time between interview and event (≤3 yrs.)
| | | Controls with possible estrogen linked diseases excluded | | Exercise | Past use 0.61 (0.20–1.87) | | | | | | Hospital controls
| | | | | ASA | Natural MP (Adjusted OR) | | | | | | ? fatal MI excludes
| | | | | | Used/never compared with surgical | | | | | | Nothing on dose, duration, composition
| | | | | | Never = 0.38 (0.08–1.71) | | | | | | ? Bias
| | | | | | Used = 0.29 (.04–1.94) | | | | | | Excluded controls with possible exposure to estrogen (gall bladder, gynecologic d/o breast cancer.)
| | | | | | Surgical MP (Adj) | | | | | | Quality: poor
| | | | | | Never = 1.0
| | | | | | Used = 0.37 (0.04–3.23)
La Vecchia C, Franceschi S, Decarli A, Pampallona S, Tognoni G. Risk factors for myocardial infarction in young women. Am J Epidemiol.1987;125(5):832–843. | Cases derived from women < age 55 admitted to 5 hospitals in Italy with acute MI | 156 women under age 55 with MI. 98% participation | Admitted to same hospitals with acute conditions other than CVD, malignant, hormonal, or gynecologic disease Diagnosed within year of index case. N = 251, ages 23–54, mean 47. Many from orthopedics 98% participation. | Trained interviewers, Physicians. Standard questionnaire. Non fatal MI | [underlined: Adj. for:] | [underlined: 7 cases:] | | | | | | Only 7 cases in post-menopausal women. Non-fatal MI
| | | | | Region | multivar adj. | | | | | | Quality: poor - pre-menopausal
| | | | | Lipids | current: 2.95(0.8–10.80)
| | | | | Tobacco | past: 0.77(0.16–3.60)
| | | | | DM
| | | | | HTN
| | | | | BMI
| | | | | OcP
| | | | | Alcohol
| | | | | Education
| | | | | SES
Thompson, 1989 ^59^ | Northwick, UK | Cases from 83 general practices | 2 controls each matched by age, race, and general practitioner chosen from registry. | Research nurse completed a questionnaire for each case and controls, which included information from medical notes, hospital records clinical laboratory tests, autopsy findings, personal interview. | Cholesterol | Univariate (>1 prescription) | Univariate (months) | | | | Adjusted for: | Good agreement between nurses HRT assessment
| | N=603 white women ages 45–69 | 79% were 1^st^ eligible | HRT= receiving ≥2 prescriptions | | OR 1.36 | 1–3 m | 2.14 | | | Marital status | Poor ascertainment of confounders among controls.
| | Cases were fatal or non-fatal stroke or MI using “WHO” criteria | Response rate NR | | | P = 0.04 | 4–6 m | 1.09 | | | Smoking | Quality: fair -good
| | 9/81–9/82 retrospectively identified | | | | MI 1.48 | 7–12 m | 1.06 | | | FMH
| | 9/82–1/86 prospectively identified | | | | CVA 1.20 | 13–24 m | 1.14 | | | HTN, DVT/TE, MI, CVA, DM
| | Fatal cases less represented in first group | | | | | >24 m | 1.19 | | | Fatal/non-fatal MI/CVA
| | 244 CVA's | | | | | p trend = 0.09 | | | | Any HRT
| | 359 MI's | | | | | | | | | 1.29 (0.82–2.0)
| | Response rate - NR | | | | | | | | | ERT
| | | | | | | | | | | 1.09 (0.65–1.82)
| | | | | | | | | | | Progestin alone
| | | | | | | | | | | 1.02 (0.45–2.32)
| | | | | | | | | | | CHRT
| | | | | | | | | | | 1.16 (0.43–3.12)
Mann, 1994 ^68^ | 6/87–5/93 | Incident MI-fatal and non-fatal among all women in general medical practices in British National Health Service ages 45–64 | 45–64 without MI recorded in their medical histories | Current HRT use defined as computer record of HRT prescription within 6 months prior to event | Family history | Adjusted | | | | | | HRT use only evaluated 6 months prior to event
| U.K. | n=1521 | Matched within 5 years | HRT/CHRT | BMI | 0.83 (0.66–1.03) | | | | | | Past use not evaluated
| | | n=6084 | Computer records used to identify risk factors | Exercise | 0.70 (0.49–1.0) Non-smoker and/or unknown | | | | | | Prior CAD not excluded
| | | | | Alcohol | 1.05 (0.71–1.53) in smokers | | | | | | Large #: unknown smoking
| | | | | ASA | CHRT (adj) | | | | | | Quality-fair
| | | | | | 0.68 (0.47–0.97)
| | | | | | ERT (adj)
| | | | | | 0.93 (0.47–1.86)
Psaty BM, Heckbert SR, Atkins D, et al. The risk of myocardial infarction associated with the combined use of estrogens and progestins in postmenopausal women. Arch Intern Med. 1994;154(12):1333–1339. | Population-based Group Health, Seattle | Post-menopausal women with incident fatal or non-fatal MI 1986-1990 | Stratified GH/random sample frequency matched by age & calendar year. | Pharmacy database | Family history | Current ERT/(non adj.) | | | Past/CHRT adj | | | See Heckbert
See Heckbert, 1997 ^69^ | | n=502 | n=1193 | [underlined: 3 categories use] | Exercise | 0.69 (0.47–1.02) | | | 1.04 (0.53–2.05) | | | Quality: good
| | participation 97%; exclusion: prior MI | exclusion: prior MI | non-users | Alcohol | Current CHRT/(non adj) | | | [underlined: Past ERT adj.] | | | Most MPA sequential
| | | participation 96% | ERT | ASA | 0.68 (0.38–1.22) | | | 0.69(0.44–1.07) | | | Average duration
| | | | CHRT | BMI | | | | | | | ERT/CHRT ≤ 2y
| | | | Use = filling 2 prescriptions
| | | | Medical reviewed for potential confounder
| | | | Telephone intervews
Grodstein, 1997 ^53^ | Nested case - control study within Nurses Health Cohort | 3637 deaths | 10 controls per case randomly chosen, matched by age, age at menopause, type menopause, period of cases death. | Biennial questionnaire ascertained prior to fatal illness to decrease “sick-quitter” bias. | Good adjustment | Mortality | | | | | | No benefit past exposure
| | 1976-1994 | | | | Coronary | | | | | | ? do women quit when ill, “healthy user” good control
| | | | | | Current: | | | | | | Quality: good
| | | | | | 0.47 (0.32–0.69)
| | | | | | Past:
| | | | | | 0.99(0.75–1.30)
| | | | | | CVA
| | | | | | Current:
| | | | | | 0.68 (0.39–1.16)
| | | | | | Past:
| | | | | | 1.07 (0.68–1.69)
| | | | | | By CVD Risk
| | | | | | Current Use:
| | | | | | HI 0.51 (0.45–0.57)
| | | | | | Low 0.89 (0.62–1.28)
Heckbert, 1997 ^69^ | Group Health | Post-menopausal age 30–79 incident | Stratified random sample | All collected before index date | Lipids | Ever: HRT adj. | Ever use (adj) | | Current (adj) | Past duration | | Median interval between index date and phone interview 24 mos.CHRT use <14%
(see Psaty BM, Heckbert SR, Atkins D, et al. The risk of myocardial infarction associated with the combined use of estrogens and progestins in postmenopausal women. Arch Intern Med. 1994;154(12):1333–1339.) | Seattle | Fatal or non-fatal MI 7/86–12/93 | Frequency matched by age (decade) and year | Review of record | Family history | 0.72 (0.59–0.88) | <1.8 yr: 0.77 (0.58–1.02) | | (0.60–1.38) | 0.69 (0.49–0.97) | | Adjustment for HDL attenuated association between duration and riskof MI
| | Index date=date 1^st^ MI or death | n=1974 | Telephone interviews | SES | [underlined: Current:] HRT adj. | 1.8–4.2: 0.70 (0.49–1.00) | | (0.45–1.10) | 0.70 (0.41–1.18) | | Quality: fair
| | n=850 (participation 94%) women < age 55 of uncertain menopause excluded. | (participation 94%) | Pharmacy database reviewed | BMI | 0.70 (0.55–0.89) | 4.2–8.2: 0.74 (0.51–1.06) | | (0.42–1.01) | 0.93 (0.51–1.69)
| | | | Type, dose, date only obtained from pharmacy data | Exercise | [underlined: Past:] HRT adj. | >8.2: 0.60 (0.39–0.93) | | (0.34–0.88) | 0.96 (0.36–2.52)
| | | | Use=filling 2 prescriptions | Alcohol | 0.74 (0.57–0.96) | No trend | | trend .05 | No trend
Sidney, 1997 ^12^ | Kaiser | Women 45–74 hospitalized for MI in 10 medical centers | Age facility matched | Medical records abstracted | Major RF were adj for (tob, DM, HTN, educ) | Overall ERT use 34% | No trend | | | | By hysterectomy | 84% of current users conjugated
| | 11/91–11/94 (Kaiser) | Post-menopausal | Interviews | Family history not adj for exercise, BMI, alcohol | Unadjusted | [underlined: ERT (yr)] | | | | With hysterectomy ERT current: | Of current E+P users, 98% used MPA in several regimens
| | Exclusions:prevalent heart disease;excluded < 55 if hysterectomy;n=438 | Participation 80% | Lifetime use | | Current ERT: | <1: 0.71(0.15–3.34) | | | | 0.95(0.50–1.80) | Quality: good
| | Post-menopausal | N=438 | Among women with hysterectomy only evaluated ERT | | 0.85 (0.6–1.21), among women with out hysterectomy | 1–4: 0.91(0.28–2.92) | | | | w/out hysterectomy
| | | | Women without hysterectomy only evaluated CHRT | | Current CHRT | 5–9: 0.75(0.27–2.07) | | | | CHRT current:
| | | | Outcome: | | 0.59 (0.38–0.94) | ≥10: 1.08(0.54–2.14) | | | | 0.89(0.52–1.53)
| | | | | | OR adj | [underlined: CHRT (yr)]
| | | | | | Current: (ERT or CHRT) | <1: 1.27(0.4–4.02)
| | | | | | 0.96 (0.66–1.40) | 1–4: 0.64(0.27–1.51)
| | | | | | [underlined: OR adj] | 5–9: 0.97(0.41–2.29)
| | | | | | Past: (ERT or CHRT) | ≥10: 0.73(0.29–1.80)
| | | | | | 1.07 (0.72–1.58)
Beard, 1989 ^66^ | Rochester, MN | Female residents 40–59 with incident CHD(SCD, MI, angina) 1960-1982 | 2 age matched residents with Mayo health care within 1 year of index date without CHD | Medical record review | [underlined: Adj. for:] | MI/SCD: | | | | | | Young cases Menopausal status unclear
| | N=133 | | | Age | Ever/never | | | | | | # menopausal
| | | | | Dm | 0.55(0.24–1.30) | | | | | | Quality: fair
| | | | | HTN | angina: | | | | | | Limited by size, age, incomplete control confounding.
| | | | | Tob | 0.82(0.46–1.47)
| | | | | Menopausal status
| | | | | [underlined: Not adj.]
| | | | | Alcohol
| | | | | BMI
| | | | | Exercise
| | | | | Family history
Croft, 1989 ^65^ | Nested case control within cohort of 23,000 women using OCD and 23, 000 not in Britain. | All women with 1^st^. MI (fatal/non fatal) n=158 | 3 controls each case matched by age +/-2, | Diagnosis by GD | Adj. for social class | Adj. RR 1^st^. MI: | | | | | | Major RF not adj. for
| | | n=158 | Death cert. | Tobacco | 0.8(0.3–1.8) | | | | | | Exposure not defined.
| | | | Physician records | OCP | | | | | | | Quality: fair
| | | | Record review | HTN
| | | | | Hysterectomy
| | | | | No adj.
| | | | | Lipids
| | | | | DM
| | | | | BMI
Hernandez-Avila, 1990 ^62^ | Group Health Women ages 50–64 with pharmacy use in last 2 years | First MI 1978-84 | No history of MI, from records GH lists and pharmacy users n=721 | Pharmacy records | Used medicines as surrogates | Current/ non use: | | | | | | Only adjusted for other drugs, only survivors
see Evidence Table 1 Cohort | | ages | | | Not adj. for chol, HTN, FMH, DM, smoking, BMI, exercise. | 0.8(0.4–1.4) | | | | | | Quality: poor
| | 50–64 | | | | Past use:
| | n=102 | | | | 0.7(0.2–2.4)
| | | | | | Multivar adj:
| | | | | | Current 0.7(0.4–1.4)
| | | | | | Past 0.6(0.1–2.1)
Rosenberg, 1993 ^67^ | Massachusetts | 1^st^ non fatal MI identified by calling CCU's of 52 hospitals weekly | Geographically matched | Questionnaire | None | Ever ERT | ERT | | Past ERT | Recent ERT | Recent Use | Conjugated estrogen most commonly used
| 1986-1990 | n=858 (97% Caucasians) | 5 yrs age, no prior MI | Nurse administered by telephone or in person (27%) | | 0.9 (0.7–1.2) | <1 yr. 0.9 (0.6–1.5) | | Total: 0.9(0.7–1.3) | Total: 0.8(0.4–1.3) | 0.8 (0.4–1.3) | Only survivors
| Ages 45–69 | Participation 90% | Identified by use of books | Use <1 month=non-user | | Ever Progestin Only | 1.1 (0.6–2.0) | | <1y: 0.9(0.5–1.5) | <1y: 1.5(0.3–8.0) | Past Use | Good participation and adjustment for confounding
| | 21% used ERT | n=85% | | | 1.3 (0.4–4.9) | 0.8 (0.3–1.9) | | 1–4: 1.0(0.6–1.7) | 1–4: 1.2(0.4–3.7) | 0.9 (0.7–1.3) | Quality: good, best
| | | 83% participation | | | Ever CHRT | 0.6 (0.3–1.3) | | 5–9: 0.7(0.3–1.7) | 5–9: 0.6(0.2–2.0) | Recent >5
| | | | | | 1.2 (0.6–2.4) | ≥15 0.4 (0.2–1.0) | | ≥10: (0.3–3.6) | ≥10: 0.5(0.2–1.1) | 0.5 (0.3–1.1)
| | | | | | | p=0.08 trend | | | | Past >5
| | | | | | | CHRT | | | | 0.8 (0.3–1.7)
| | | | | | | ≤5 | 0.5 (0.2–1.5) | | | Trend for risk increases duration mostly in recent users
| | | | | | | ≥5 | 2.6 (0.8–8.4)
| | | | | | | ERT
| | | | | | | ≥5 | 0.6 (0.4–1.1)

Evidence Table 3. HRT and stroke - cohort studies

Reference | Setting/Study Population | Exposure Measurement/ Risk Factors | Outcomes | Follow-up | Exposure Adjustment | MARR of stroke in users vs. nonusers | | | | Stroke Mortality in users compared to nonusers | | RR of stroke + Other | | Quality of Study | Comments
Hammond CB, Jelovsek FR, Lee KL, Creasman WT, Parker RT. Effects of long-term estrogen replacement therapy. I. Metabolic effects. Am J Obstet Gynecol. 1979;133(5):525–536. | Retrospective Cohort | Primarily used CEE, ~96% (31% at 0.625 mg; 33% at 1.25 mg), usually given in cyclic fashion (88%). 27.6% received progestins, in addition to CEE. | stroke syndromes, F/NF | 5+ years | none | P<0.05, no RR given. | | | | | | CAD | | Poor; not adjusted for confounders; subjects hypoestrogenic, but young age and at low risk of stroke. | Users significantly different from nonusers. Users tended to be younger, lower BMI, have lower blood pressures, white; while nonusers tended to be older, black, hypertensive, lower SES, higher BMI, higher gravidity.
| 610 women identified through medical records retrieval system of Duke University Medical Center and by systematic review of office records from OB/GYN faculty, likely to have an estrogen-deficient state identified by diagnoses of premature ovarian failure, hypogonadism due to hypopituitarism, osteoporosis, atrophic vaginitis, menopausal syndrome, surgical removal of ovaries, not due to cancer, gonadal dysgenesis. Patients identified from 1940 through 1969; | Estrogen reported as never use (n= 309) and estrogen users (n=301). | CAD | | | 14 cases in the never users and 3 cases in the estrogen users. | | | | | | p<0.01, no RR given
| Ages 10 to >50 yr | | Details of stroke or CAD outcomes were not given in this analysis, but presumed to be verified by medical records and discharge diagnosis. | | | | | | | | | 44 cases in never users
| Must have estrogen exposure of at least 5 years, and must have been seen in exam after 1/1/74. | | | | | | | | | | | 14 cases in estrogen users
Byrd BF, Jr., Burch JC, Vaughn WK. The impact of long term estrogen support after hysterectomy. A report of 1016 cases. Ann Surg. 1977;185(5):574–580. | 1016 White women with hysterectomies performed by co-author JC Burch, age 22–78 y/o (avg 44), on estrogen for at least 3+ yrs. 1948-1971, Tennessee | Primarily used CEE, 1.25 mg - no distinction between cyclic therapy; Exposure measurement at contact and questionnaire f/u. Avg yr on estrogen 13.5 yr. | Cancer | 100% f/u | none | | | | | CVA death | | | | Poor Unadjusted;External controls 100% f/u. Probable not a generalizable population.
| | | cerebrovascular accident death | 14,318 person-yr | | | | | | SMR (8/15) = 0.53
| | | Heart Disease | +E2 | | | | | | heart dx death = (13/35) = 0.37, p<0.005
| | | Death verified by death certificates; cancer data from the Third National Cancer Survey for the Atlantic area; mortality statistics from Dept. of Vital Statistics, State of Tennessee Public Health Department.
Burch JD. Discussion of the effects of long-term estrogen on hysterectomized women. Am J Obstet Gynecol. 1974;118:782. | 737 white women with hysterectomies performed by author, ages 20–80's, from 1940's to 1967. | Primarily used CEE, 1.25 mg - no distinction between cyclic therapy; Exposure measurement at contact. | cerebrovascular accident death | 100% | none | 8 cases of stroke | | | | | | | | Poor; Unadjusted; external controls. 713/737 s/o hysterectomy
| | | | 9,899 patient years
| | | | 1973
Petitti DB, Wingerd J, Pellegrin F, Ramcharan S. Risk of vascular disease in women. Smoking, oral contraceptives, noncontraceptive estrogens, and other factors. JAMA. 1979;242(11):1150–1154 | Walnut Creek Contraceptive Drug Study. N=16,759 primarily white, suburban middle class women aged 18–54 appearing for routine check ups from 1969-1971. | Annual Routine Exam between 1969-1971, F/U exam and yearly questionnaires, hospital discharge records and California Death certificates. Info obtained on hormonal use (OCP's, and noncontraceptive estrogen and progestins) | Subarachnoid hemorrhage (SAH) | 470(2.8%) lost to f/u. 107 (0.7%) deaths; 922 (5.5%) withdrew; f/u from 1969-12/76, avg 6.5 yr. | Excluded at start of study women with h/o stroke and DM | SAH (fatal/nonfatal) n=11 | | | | | | MI (F/NF) | | Fair; Unsure if confounders were adjusted for, except for DM and stroke which were eliminated at start of study. F/U 97.2% complete. | *90%CI
| Controls were matched to cases by age/birth year, with varying numbers of controls matched to each case, ranging from 60->200. | | Other Stroke | | | RR 1.6(0.7–3.8)* | | | | | | RR 1.2(0.6–2.3)* | | | Analyzed as a case control study.
| | | MI | | | Other stroke (F/NF) n=23
| | | Venous thromboembolism | | | RR 0.9(0.4–1.8)*
| | | Outcomes evaluated by patient self-report; and verified MI's by discharge records with clinical s+sx/EKG changes or inc. CK; SAH by death cert/autopsy, discharge summary and confirmed by angiography or operation; Other stroke by h/o of sudden onset of sx c/w cerebrovascular dx (CVD), absence of predisposing condition, at least one the following: acute onset of hemiplegia, angiographic data of cerebral thrombosis, embolism or hemorrhage or transient episode of one-sided weakness with assoc. sensory or ocular symptoms.
Wilson 1985 ^11^ | Framingham cohort, exam 12–16. | Exposure measured on initial exam. Biennial exams were done, but no info on estrogen use during f/u. | Cerebrovascular disease (F/NF) | 8 years | Adjusted for surgical menopause, age, SBP, BMI, TC:HDL, smoking, ETOH | cerebrovascular disease (F/NF), n=45 | | | | | | CVD/HRT: | | Good; not adjusted for diabetes
| Postmenopausal women age 50–83. Recruitment from 1970-1972. | Almost all were CEE, <5% used progestins; | Atherothrombotic brain infarction | | Not adjusted for DM | RR 2.27, p<0.01 | | | | | | Smokers: RR 1.96, not significant
| N=1234; Controls = 932; Cases = 302 | Exposure classified if subject ever reported use during exams 8–12 | All cause mortality | | | Atherothrombotic brain infarction, n=21 | | | | | | Non-smokers: RR 2.35, p<0.05
| | | | | | RR = 2.60, p<0.01 | | | | | | Coronary heart dz/HRT:
| | | | | | | | | | | | Smokers RR 4.17, p<0.01
| | | | | | | | | | | | Non-smokers RR 1.44, not sig.
| | | | | | | | | | | | Total cardiovascular disease/HRT:
| | | | | | | | | | | | Smokers: RR 3.16, p<0.01
| | | | | | | | | | | | Nonsmokers: RR 1.26, not sig.
| | | | | | | | | | | | All cause mortality, n=130
| | | | | | | | | | | | RR 0.97, not sig.
Bush 1987 ^22^ | Participants in Lipid Research Clinics Prevalence Study for CVD from 10 N. American clinics between 1972-1976. Women aged 40–69, white. | Estrogen use determined at baseline by standardized interview -OCP or ERT use before visit 2. Verified by samples drug containers. Estrogen use validated in ~95% (with 2/3 taking premarin and 1% taking progesterone (6 ERT users) | Cerebrovascular death | 99% f/u; Average 8.5 yr. 10,080 py | Age, BP, smoking, LDL, BMI, education | | | | | 0.40 (0.01–3.07) | | All cause Mortality | | Good; Adjusted for most important confounders; fair response rate; good f/u. | 4% of users (n=23) and nonusers (n=60) reported prior MI or stroke.
| N=2270 | never user = 1677; | Death verified by hospital/physician records, interviews with next of kin. | | Not adjusted for fhx, DM | | | | | | | RR= 0.54(0.29–0.79) | | | Estrogen type, dose, duration not consistently obtained.
| Participants initially identified in selected target populations (ie. Occupational grp, school children and parents, whole county surveys) | ERT = 593 | | | | | | | | | | Cardiovascular disease mortality (age adj) | | | Estrogen use ascertained only at one point in time.
| Visit 1 (74% response rate) | | | | | | | | | | | RR = 0.34(0.12–0.81),
| Visit 2 (84% of invited) - 3449 randomly selected from target groups (58%); 2350 persons with elevated lipids (40%) and 127 taking lipid meds (2%). | | | | | | | | | | | after adjustment for prevalent cases RR=0.42(0.13–1.10)
The American-Canadian Co-Operative Study Group. Persantine aspirin trial in cerebral ischemia--Part III: Risk factors for stroke. Stroke. 1986;17(1):12–18. | 890 subjects with one or more TIA's in the carotid territory from 15 centers. 10% female, n=293 | Baseline history obtained at time of admission to study. Estrogen never or ever user. Information on confounders obtained in a similar fashion. | Stroke | ?100% | Unadjusted | F/NF Stroke or Retinal Infarction (n=36, 35 never users, 1 user) | | | | nr | | | | Poor; did not adjust for confounding; Exposure assessment not consistent and possibly unreliable. | Smoking and estrogen use not on questionnaire initially. Included in the study after 1 mos. Some data collected retrospectively.
| | 293 women (262 never use, 31 ever use) | Retinal Infarction Death | median f/u `25 mos. | | RR = 0.23, p=0.06
Hunt K, Vessey M, McPherson K, Coleman M. Long-term surveillance of mortality and cancer incidence in women receiving hormone replacement therapy. Br J Obstet Gynaecol. 1987;94(7):620–635. | UK (England and Wales); | HRT info obtained from recruitment interview and PMHx. Risk factor info collected in the same manner. | All-Cause mortality | June 1983 | Not adjusted for DM, HTN, smoking, lipids, family h/o, etc. | | | | | SMR for cerebrovascular disease | | SMR suicide or suspected suicide | | Poor; Uncontrolled; Not adjusted for confounding; Response rate approx. 80%; ? F/U 100%; | Over 175 different hrt preparations, premarin accounted for only 17%.
| 4544 women recruited from 21 specialty menopause clinics, aged 45–54 (60%) | Uncontrolled. | Cancer Mortality | | | | | | | 0.65(0.35–1.09) | | 2.53(1.26–4.54) | | | Full HRT histories available for 70% of cohort. 51% had taken HRT for more than 5 years; average duration of use 67 months. 43% “opposed estrogen“.
| Primarily white, affluent, h/o hysterectomiy ~36%) | | Cerebrovascular Disease
| Retrospective recruitment from before 1974 to 1978 (7% prior to 1974, 29% between 1974-1977) | | Deaths flagged by the Nat'l Health Service Central Registries.
| Prospective recruitment from 1978 (53% between 1978-1981, and 11% 1982).Postal questionnaire sent out in 1983 to 4387 of 4544 women recruited. (response rate was almost 80%). Illicited info on HRT use since entry to study and about major morbidity.
| All on HRT for at least 1 year prior to recruitment, plus attend one of the participating clinics.
Petitti 1987 ^49^ | 16,638 women aged 18–54 from Walnut Creek Facility at Kaiser Permanente. | Health exam, with history obtained on past and current hormone use, as well as info on potential confounders. Final analysis on: Controls: 3437 women who never used OCP or ERT and Cases: 2656 women who used ERT, but not OCP. | Death Outcomes evaluated by: next of kin questionnaires, search of California Death Index, and obtained death certificates coded by ICD-8 | 1968-1977 (active follow up) through 12/31/83 by computer search in CDI | age, smoking, ETOH, Quetelet index, h/o htn, marital status and education. | Cerebrovascular Death (4 nonuser deaths/5 user deaths) | | | | nr | | all-Cause Mortality | | Fair; Not adjusted for major confounders; Exposure use equally measured, but only up until 1977, although f/u continued until 1983; Only death as an outcome is measured and losses to f/u not mentioned.
| Recruitment from 12/68 to 2/72 | Estrogen type not mentioned | | Loss to followup not reported | Not adjusted for DM. Lipids, family h/o. | RR 0.6 (0.2–2.2) | | | | | | RR = 0.80(0.6–1.1)
| Controls were women who never used OCP or ERT (n=3437) | | | | | | | | | | | Death from Acute MI (7 nonusers/4 users)
| | | | | | | | | | | | RR = 0.3(0.1–1.3)
| | | | | | | | | | | | Death from all ischemic heart disease
| | | | | | | | | | | | RR 1.3(0.2–7.7)
Paganini-Hill A, Ross RK, Henderson BE. Postmenopausal oestrogen treatment and stroke: a prospective study. Br Med J. 1988;297(6647):519–522. | California Retirement Community - Laguna Hills. Leisure World Cohort Study from 6/81 to 1985. | Health questionnaire mailed to residents (initial 60% response rate), 6/82, 6/83, 10/85. | Stroke death | 13 lost to follow-up (search by National Death Index, negative);8/86 | Age, HTN, h/o angina, MI or stroke, ETOH, smoking, Quetelet's index, last menstral period. | | | | | N=63 stroke deaths | | Duration of use | | Poor; Good f/u; Important confounder not adjusted for, DM. Only evaluated for mortality/fatal stroke. 60% response rate. | 3845 nonusers
| N=13986, 8882 women, primarily white, affluent, well-educated, median age 73, 2/3 women. | Assessed estrogen use and duration as well as confounding factors by questionnaire. | Deaths were ascertained by death certificates, records at local county health dept.; obituary columns, info from friends and relatives; | | No adjustment for DM, lipids | | | | | RR = 0.53(0.31–0.91), p=0.02 | | <=8 y = 0.55(0.28–1.08) | | | 4962 users
| | | | | | | | | | | | >=8 y = 0.50(0.23–1.08) | | | Primarily CEE
| | | | | | | | | | | | Dose
| | | | | | | | | | | | <= 0.625 mg = 0.73(0.32–1.66)
| | | | | | | | | | | | >= 1.25 mg = 0.49(0.19–1.27)
Hunt K, Vessey M, McPherson K. Mortality in a cohort of long-term users of hormone replacement therapy: an updated analysis. Br J Obstet Gynaecol. 1990;97(12):1080–1086. | UK (England and Wales); | HRT info obtained from recruitment interview and PMHx. | All-Cause mortality | 1980-12/31/88 | Not adjusted for DM, HTN, smoking | | | | | Stroke Mortality (up to 1988), n=23 | | | | Poor; Uncontrolled; Not adjusted for confounding; F/U 100%; | Select population of women, from specialty menopause clinics. All affluent. Not adjusted for significant confounders.
| 4544 women recruited from 21 specialty menopause clinics, aged 45–54 | Uncontrolled. | CV Mortality | F/u 100% | | | | | | SMR = 0.54(0.24–0.84)
| Different from general population - | | Deaths flagged by the Nat'l Health Service Central Registries.
| 36% had hysterectomy (2–2.5 that of gen pop).
| 46% social class I or II (affluent)
| All on HRT for at least 1 year prior to recruitment.
| Mean duration of HRT use 66.9 mos., 59% still using HRT.
Henderson 1991 ^85^ | All residents of Leisure World, Laguna Hills; Retirement community in Southern Ca. Primarily white, affluent, well educated, mean age 73; | Questionnaires sent 6/81, 6/82, 6/83, 10/85. (PMHx, type and duration of estrogen use.) | Stroke death | 7.5 years; 56,020 py | Age only. | | | | | 0.63 (primarily CEE), not statistically significant | | Age-adjusted data: | | Poor; | Premarin used most commonly.
| N=13987 (respondents out of 22,781, men and women). | N=4988 of 8853 used ERT | Deaths were ascertained by death certificates, records at local county health dept.; obituary columns, info from friends and relatives. | 22 subjects unavailable for f/u (review of Nat'l Death Index) | | | | | | Actual # of deaths due to stoke = 92 (60 in nonusers, 32 in users) | | All-Cause Mortality: RR by h/o of use of ERT, users vs. never users | | Good f/u; Not adjusted for major confounders in CVD and stroke analysis. Only evaluated for mortality/fatal stroke.
| N=8853 women (8881-28 b/c no info given on HRT) | Mean duration of use ~10 yr. | | | | | | | | RR of death from occlusive stroke by duration of use: | | RR 0.8 (0.70–0.87); p<0.0001.
| Internal controls. | 932 (19%) took ERT <=1 yr. | | | | | | | | <3 y | 0.51 | All-Cause Mortality and RR by h/o of ERT use:
| 1981-1985. | 37 took ERT > 40 yr. | | | | | | | | 4–14 y | 0.74 | Duration of use (yr):
| | Majority of ERT taken immediately postmenopausal years and d/c'd prior to study entry. | | | | | | | | >= 15 y | 0.53, p<0.05 | <= 3 | 0.83(0.71–0.96), p<0.05
| | | | | | | | | | RR of death from occlusive stroke by time since last use: | | 4–14 | 0.76(0.65–0.89)
| | | | | | | | | | >= 15 y | 0.67 | >= 15 | 0.69(0.58–0.82), p<0.001, test for trend
| | | | | | | | | | 2–14 y | 0.63 | years since last use:
| | | | | | | | | | 0–1 y | 0.30, p<0.05 | >= 15 | 0.80(0.70–0.92), p<0.01
| | | | | | | | | | | | 2–14 | 0.79(0.68–0.92), p<0.01
| | | | | | | | | | | | 0–1 | 0.64(0.52–0.78), p<0.001, test for trend
Stampfer 1991 ^9^ | 48,470 postmenopausal women, nurses, aged 30–63 who participated in the Nurses' Health Study. Overall healthy, white, no h/o cvd and cancer. | Hormone use obtained by biennial questionnaire. HRT use and duration obtained. | Strokes F/NF | F/u up to 10 years (337,854 person years) | Adjusted for age, smoking, HTN, DM, hypercholesterolemia, FH of MI before 60 y, quetelet index, past OCP use. | Total strokes (F=52/NF=172) - (ischemic 113, SAH 36, NOS 75) | | | | | | All-Cause Mortality | | Good; Good f/u; confounders adjusted for; important outcomes measured, comparable groups maintained. | No association between current estrogen use and total stroke. RR = 0.97.
| 1976-1986. (initial cohort 22,950 in 1976, up to 48,470 as women became menopausal). | | Ischemic Stroke | F/U 88.4% complete for NF outcomes and 98% complete for fatal outcomes. | | Never use (n=123) | 1.0 | | | | | RR = 0.89 (0.78–1.00)
| | | SAH | F/u ended with diagnosis of stroke or death. | | Current (n=39) | 0.97(0.65–1.45) | | | | | CV mortality
| | | Major coronary disease (NF MI, death due to coronary dz) | Women were excluded from analysis who reported CVD at the start of each 2 year interval. | | Former (n=62) | 0.99(0.72–1.36) | | | | | RR = 0.72 (0.55–0.95), p=0.02
| | | CABG | | | Ischemic stroke (113)
| | | All-cause mortality | | | Never use (n=56) | 1.0
| | | Info from PMHx/questionnaire verified by medical records. | | | Current (n=23) | 1.46(0.85–2.51)
| | | NF strokes verified by med record if typical neurologic symptoms lasting at least 24 hours and meeting criteria of the Nat'l Survey of Stroke. Stroke classified as ischemic (thrombotic or embolic), SAH, IPH. If no medical record available, case defined as probable if they required hosp-italization and letter of interview corroborated event. | | | Former (n=34) | 1.19(0.77–1.86)
| | | Death reported by subjects family; verified by medical & autopsy records. Non-respondents - searched Nat'l Death Index | | | SAH (36)
| | | | | | Never use (n=19) | 1.0
| | | | | | Current (n=5) | 0.53(0.18–1.57)
| | | | | | Former (n=12) | 1.03 (0.47–2.25)
| | | | | | Number of Strokes (177 confirmed, 47 probable)
| | | | | | 224 total strokes
| | | | | | 52 fatal and 172 nonfatal
Folsom 1995 ^55^ | Subjects are part of the Iowa Women's Health Study cohort, consisting of 41,837 (41,070 after exclusions) women aged 55–69 with valid IA drivers license in 1985. | Estrogen exposure obtained from initial mailed questionaire and updated in follow up | CHD death | 6 years | Adjustment for age, marital status, physical activity, ETOH use, pack-years of smoking, BMI, waist/hip ratio, HTN, DM | | | | | current users | RR= 0.95(0.37–2.43) | Duration of use | | Good; f/u 100%; All important confounders adjusted for. | Estimated ~20% CHRT current users
| Analyses restricted to PM women with HRT data. 1986-1991. | Estrogen use = current, former and never use at baseline; duration of use, <=5 y or >5 yr. | Stroke death | | Not adjusted for lipids, SES | | | | | former users | RR= 0.88(0.48–1.61) | <=5 y | RR = 2.08(0.74–5.82)
| | | All cause mortality | | | | | | | | | >5 y | RR = 1.05(0.41–2.64)
| | | Death identified through the Health Registry and national Death Index, with recorded underlying cause of death coded by ICD9.
Finucane 1993 ^56^ | Subjects were participants in the NHANES I trial. Women were white, civilian, noninstitutionalized women, without h/o of stroke, aged 55–74 y/o. Out of total 2371 women, N=1910 after exclusions; | HRT use is obtained at first f/u appt (NHEFS) and not at NHANES baseline. | Nonfatal and fatal stroke. | 1971-1987 average f/u ~11.9 yr. | adjustment for age, SBP, DM, smoking, BMI, h/o HTN, MI, education, poverty ratio. | RR of stroke (subject + proxy/ n=1910) = 0.69(0.47–1.00) | | | | RR of stroke (subject + proxy): | | | | good; F/u complete; Important confounders adjusted for; pertinent outcomes studied | 21% of study subjects took HRT (n=397).
| 1971-1975 | Dose, duration of use of HRT was not obtained. | Stroke determined from discharge diagnosis coded from hospital/nursing home records, death certificates and f/u up interviews. | 4% of original cohort is lost to f/u. | Not adjusted for family hx, lipids | RR of stroke (subject only/n=1474) = 0.82 (0.46–1.47) | | | | 0.37 (0.14–0.92)
| | Info obtained by interview and classified as ever users vs. never users. (Ever users may have taken HRT years ago; never users may have begun taking HRT after the first f/u appt.) | | | | | | | | RR of stroke (subject only):
| | | | | | | | | | 0.86 (0.28–2.66)
Lindenstrom E, Boysen G, Nyboe J. Lifestyle factors and risk of cerebrovascular disease in women. The Copenhagen City Heart Study. Stroke. 1993;24(10):1468–1472. | Subjects were participants in the Copenhagen City Heart Study. Random sample(after age stratification) of Danish women from urban population in Copenhagen, served by Rigshospitalet. | Exposure history obtained from questionnaires and by 2 exams. | First stroke and TIA (SAH excluded) | F/U of 12 years (1976-1988) | Adjusted for age, education, income, smoking, ETOH, BMI, activity, current use of OCP or HRT. | RR not reported, 95% CI = 0.5–1.9. | | | | | | In Smokers + HRT: | | Poor; % of F/U uncertain; Did not adjust for DM and HTN; 68% response rate. | Interaction between smoking and HRT, p<0.041; (HRT protective among smokers RR 0.57, compared to non-users RR 1.50)
| 10,317 women invited by letter for exam. N =7060; | Type of estrogen, duration of use, past use, not specified. | Outcomes evaluated by history and PE with neurologic assessment; Natl pt. Register (hospital records); Nat'l health service register of deaths; patient's MD, family or nursing home. | | Did not account for HTN and DM. | | | | | | | RR = 0.57 (0.29–1.13) | | | In non-smokers, use of HRT did not influence risk of stroke.
| Exam 1: 3/76–3/78; Exam 2: 4/81–7/83; | | | | | | | | | | | In Smokers/ no HRT:
| N=4716 postmenopausal women. | | | | | | | | | | | RR = 1.50 (1.09–2.08)
| | | | | | | | | | | | Nonsmokers/HRT:
| | | | | | | | | | | | RR = 1.01 (0.55–1.84)
| | | | | | | | | | | | Nonsmokers/no HRT:
| | | | | | | | | | | | RR = 1
Boysen G, Nyboe J, Appleyard M, et al. Stroke incidence and risk factors for stroke in Copenhagen, Denmark. Stroke. 1988;19(11):1345–1353. | Participants in the Copenhagen City Heart Study (see above). | Questionnaire | First stroke/TIA | 5 years | HTN, DM, age, income, smoking, cholesterol | In model with age, income, smoking, SBP, DM and cholesterol, no indication that PM estrogen influences stroke risk. | | | | | | stroke cases= 238 | | Poor | Unable to calculate RR from data presented in study
| N = 5602 women age 45–74 | | ICD-9 430–438 | Between 4/1981 and 9/1983 | | RR= not reported
| | | | | | 95% CI = 0.5–1.9
Falkeborn M, Persson I, Terent A, Adami HO, Lithell H, Bergstrom R. Hormone replacement therapy and the risk of stroke. Follow-up of a population-based cohort in Sweden. Arch Intern Med. 1993;153(10):1201–1209. | 23,088 women older than age 35, from Uppsala, Sweden Health Care Region. | Hormone use established by pharmacies in Uppsala Health Care Region from 1977-1980. Random sample of 1/30 of cohort received questionnaires. Subcohort, N=735. | First stroke: | f/u started at date of first prescription or 1977 - 12/31/83 | Age only. Could not adjust for confounders b/c database was from prescriptions. | Stroke All | E2/CE | Comb. | OE | | | | | Poor. Unable to adjust for confounders; however small subset analyzed. | Distribution of risk factors between subcohort and female population were found to be no different in respect to age at menarche, menopause and DM, HTN.
| 1977-1983 | External controls | -acute stroke (AS) | 133,718 person years of observation; avg. observation time per person = 5.8 yrs. | | All strokes | | | | | | | | | 361 cases of first stroke.
| N=23,247(-159 w/hx of stroke) | Questionnaire to age-matched sample, n=1039 (78% response rate). | -subarachnoid hemorrhage (SAH) | 26 women emigrated and were lost to f/u. | | 0.9 | 0.79 | 0.61 | 1.02 | | | | | | - hormone use before and after study not ascertained. Only one brand of estrogen-progestin combination included; but classified all women on estrogenic compounds
| Median age 53.9 yr. | Median duration of ERT was 3.5 years & 23% continued treatment through 1983. | -intracerebral hemorrhage (ICH) | 876 deaths | | (0.81–0.99) | (0.67–0.92) | (0.40–0.88) | (0.88–1.17)
| | Groups: | -thromboembolic stroke (including TIA) (TES) | | | Acute strokes
| | Potent estrogens (estradiol cmpds, CEE)-N=17,143 (5639 combined e+p; 81% of subcohort) | Outcomes evaluated by record linkages by National Registration number and verified with hospital admissions and the Inpatient Registry. | | | 0.85 | 0.72 | 0.56 | 1.00
| | Other estrogens (weak estrogens, primarily estriol 1 mg/d)-N=5945 | Classification based on ICD-9 codes | | | (0.75–0.97) | (0.59–0.86) | (0.33–0.90) | (0.85–1.18)
| | 18,869 <60 yr old at time of first Rx; 4219 >60 yrs. old | | | | SAH 1.19 | 1.24 | 0.83 | 1.03
| | | | | | (0.86–1.61) | (0.85–1.74) | (0.33–1.71) | (0.47–1.96)
| | | | | | ICH 0.68 | 0.57 | 0.20 | 0.84
| | | | | | (0.45–0.99) | (0.30–0.97) | (0.01–1.11) | (0.46–1.41)
| | | | | | TES 0.91 | 0.78 | 0.57 | 1.08
| | | | | | (0.76–1.09) | (0.59–1.01) | (0.26–1.09) | (0.83–1.38)
Grodstein 1996 ^8^ | Women from the Nurses Health Study; age 30–55 y/o. | Hormone use obtained by biennial questionnaire. | NF/F strokes; MI/CABG/Angioplasty, death from CAD. | 16 yr f/u from 1976-1992 (662,891 person-yrs) | Adjusted for age, age at menopause, BMI, smoking, DM, HTN, hypercholesterolemia, FH h/o of MI before age 60; prior use of OCP, type of menopause, sat. fat intake, ETOH use, vit E or MVI use, ASA use, physical activity. | stroke(all)(572) | ischemic | SAH (155) | stroke (285) | Deaths due to stroke not reported. | | RR of stroke + dose | | Good; Comparable groups, all outcomes considered, although stroke deaths not reported. Adjusted for major risk factors. | Relative Risk of hemorrhagic stroke in ERT users 0.53, only 3 cases; no confidence interval, p-value reported.
| 1976-1992. N=59,337 | N=27,034 never users | Positive report in questionnaire resulted in review of medical records; | 59,337 women | | Current | 1.03(0.82–1.31) | 1.40(1.02–1.92) | 0.90(0.57–1.41) | | | Dose | RR of Stroke | F/U not clear in terms of losses to f/u and those completing study.
| | N=12,503 past users | NF strokes verified by med. Record if typical neurologic symptoms lasting at least 24 hours and meeting criteria of the Nat'l Survey of Stroke. Stroke classified as ischemic (thrombotic or embolic), SAH, IPH. If no medical record available, case defined as probable if they required hospitalization and letter of interview corrobaorated event. | Mortality data >98% | | Past | 0.99(0.80–1.22) | 1.01(0.74–1.36) | 0.81(0.52–1.25) | | | 0.3 | 0.64(0.30–1.36)
| | N=7776 current users of estrogen only | Death reported by subjects family and verified by medical records, autopsy records. Non-respondents - searched Nat'l Death Index | | | ERT only | 1.27(0.95–1.69) | 1.63(1.10–2.39) | 1.35(nr) | | | 0.625 | 1.24(0.90–1.70)
| | N=6224 current users of estrogen + progestin | | | | Est+Prog | 1.09(0.66–1.80) | 1.42(0.73–2.75) | | | | 1.25 | 1.44(0.94–2.22)
| | | | | | | | | | | | >1.25 | 1.86(0.59–5.90)
| | | | | | | | | | | | Ptrend = 0.047
| | | | | | | | | | | | Data for RR by duration of HRT not reported in detail, but association found to be unrelated to duration of use. RR for 10+ years of use = 1.01(0.69–1.46).
Schairer 1997 ^75^ | Swedish women from Uppsala Health Care Region (Sweden). | Prescription-based exposure group. | All cause mortality | 8.6 years (199,810 person-years) | Confounders were not adjusted for b/c all data was obtained from pharmacy database. No adjustment for smoking, hypertension, diabetes, etc. | | | | | SMR by HRT regimen: no nonuser group | | SMR by HRT regimen (continued) | | Poor; External controls; Unadjusted F/u appears to be complete | Unable to adjust for confounders
| Cohort of 23,246 women older than 35 years of age, on prescribed estrogen (reported from regional pharmacies). Mean age ~54.4 yrs. | A random-selected subset of cohort (n=753) received questionnaires to evaluate concordance between presription data and those given questionnaire. | Cardiovascular deaths | 3/77–12/86 | Small subset of cohort received questionnaires (n=1034) to evaluate for possible confounding. | | | | | Other: | | Combined | | | no comparison to nonusers.
| Estrogen prescribed for HRT and not contraception. | External controls. Same questionnaire sent to sample of 1324 women from general population of the region and age-matched to distribution of cohort. 1034 respondants (79%). | CVA (SAH, ICH, TES) | | | | | | | CVD | 0.9 (0.7–1.0) | 0.6 (0.3–1.1)
| External controls (“background group“) | Exposure groups: | Outcomes verified by linkage to National Causes of Death Registry, according to ICD-9 code | | | | | | | SAH | 1.7 (0.9–2.9) | 0.5 (0.1–1.4)
| Compared to background group, women on “more potent estrogens” had higher rates of TAH/BSO, less DM, smoked more and were more physically active. | A. Estrogen grp: 1) Combined: {estradiol/valerate (2 mg) + levonorgestrel (250 ug)} | | | | | | | | Stroke | 0.8 (0.6–1.0) | 0.8 (0.3–1.6)
| 4/77-3/80 | 2) More Potent Estrogen {estradiol/conjugated estrogen} | | | | | | | | ICH | 0.9 (0.6–1.3) | 0.6 (0.1–1.7)
| | B. Other: predominantly estriol | | | | | | | | TES | 0.8 (0.5–1.3) | 0.6 (0.1–1.7)
| | | | | | | | | | nos | 0.7 (0.4–1.1) | 1.2 (0.1–4.4)
| | | | | | | | | | More Potent Estrogen:
| | | | | | | | | | CVD | 0.7 (0.6–0.9)
| | | | | | | | | | SAH | 0.9 (0.5–1.5)
| | | | | | | | | | Stroke | 0.8 (0.6–1.1)
| | | | | | | | | | ICH | 0.4 (0.2–0.7)
| | | | | | | | | | TES | 1.1 (0.6–1.8)
| | | | | | | | | | nos | 1.2 (0.7–1.9)
Lafferty FW, Fiske ME. Postmenopausal estrogen replacement: a long-term cohort study. Am J Med. 1994;97(1):66–77. | All postmenopausal women, aged 43–60, who were healthy, white, ambulatory women from the private practice of FWL(author) between 1964-1983, were offered ERT. N=176 (out of 234, after exclusions, cancer, severe HTN, CVD, osteoporosis, DM, etoh, misc. illness;) | ERT prescribed as premarin at 0.625 mg by the study author to each of the 81 patients. No measure of compliance noted. Risk factors collected by history by examiner. | stroke/cardiovascular events (htn, MI, ischemic changes on EKG, CVA). (also BMD, lipids). No measure of how CVA was determined. | min. 3 years (5–14 yr) avg. 8.6 years. | adjusted for HTN, BMI, smoking, cholesterol, age, ETOH, bil. Oophorectomy; | p=0.025; however only 4 cases of CVA in controls and 0 in the ERT group. | | | | | | | | Poor; f/u almost 98%. Study population possibly not generalizable (only from one physician's practice); Documention of CVA, MI scant. Compliance of therapy not known. | Small number of cerebrovascular events (4 in control group, 0 in ERT group);
| N= 81 long term estrogen subjects; | | | 1964-1989 | Diabetics were excluded from study at the beginning. | | | | | | | | | | Standardized useage of premarin.
| Controls, N = 76, women who declined ERT use. | | | 15 of ERT users dc'd estrogen prior to the 3 yr min. obs period. (quit b/c of fear of endom. ca (9), cystic breast dx(2), fear of breast ca, mastalgia, menses, depression (4) | | | | | | | | | | | Outcome classification/documentation not clear.
| | | | At end of study, 67–68% of both groups were under direct f/u of deceased. 26–29% were contacted by questionnaire.
Sourander 1998 ^51^ | 7944 women aged 57–64 participating in mammography screening program in Turku, Finland in 1987-1988. | Initial questionnaire filled out by participants with the help of trained nurses. RF info obtained and former and present use of hormone therapy. Use of hormones verified by nurse and presriptions checked. Interviews occurred q 2 years for three times. | Cardiovascular disease | 53,305 person-yrs. | social class, smoking, age, BMI, DM, HTN, CAD and cardiac failure. | Stroke Morbidity | | | | Former users | RR 1.05 (0.41–2.68) | Cardiovasc. Disease mortality | | Good; F/U 100% ; homogeneous population; appropriate adjustment of confounders. 97% response rate. | Not adjusted for lipids.
| | Estrogen exposure = never, former and current users. Mean oral dose of estradiol was 1.46 mg, mean duration of current use was 8.2 yr. 1707 women had hysterectomies; Non-hysterectomised women, N=514, unopposed current ERT use, and N=139 used opposed ERT. | Coronary artery disease (CAD) | | Not adjusted for lipids, exercise, ETOH and family history. | Former users | RR 1.08(0.88–1.71) | | | Current users | RR 0.16(0.02–1.18) | Former | RR 0.75(0.41–1.37)
| | | Acute myocardial infarction (AMI) | | | Current users | RR 0.86(0.42–1.75) | | | | | Current | RR 0.21(0.08–0.59)
| | | Stroke | | | | | | | | | CAD mortality
| | | National Death Register in Finland/death certificates bu ICD9 codes. National Agency for Welfare and Health kept nat'l register of hospital discharges for cardiovascular disease and stroke. | | | | | | | | | Former | RR 0.64(0.27–1.47)
| | | | | | | | | | | | Current | RR 0.19(0.05–0.77)
Cauley 1995 ^50^ | N=9704 non-African American women, >= 65 yrs old. Recruited for the Study of Osteoporotic Fractures from 4 communities: Portland, OR, Minneapolis, MN; Baltimore County, MD; Monongahela Valley near Pittsburgh, PA. Women recruited from population-based lists (licensed drivers, registered voters and HMOs). | Estrogen +/- progesterone exposure obtained at baseline interview and updated on third clinical visit (1991). | Death due to: | ~6 years | Adjusted for age, clinic, education, h/o surgical menopause, DM, stroke or HTN, ETOH, health status, smoking, exercise, BMI, waist-hip ratio. | | | | | Past users | | Duration of use | | Good; 99% f/u. Good adjustment for confounding. | RR of all CVD and CHD on HRT >= 10 years was significant decrease,
| Analyses restricted to women with known oral HRT use. | 14% currently using oral HRT, 80% ERT, 20% CHRT. ~22% past use of HRT. | Stroke | 99% complete through 10/31/94. | No adjustment for lipids, SES. | | | | | RR 0.85(0.48–1.49) | | 1–9 y | | Internal controls, with external US controls. | RR 0.30(0.16–0.57) and RR 0.25(0.09–0.68), respectively.
| | HRT use = never, never (n=4995) or less than 1 year (n=745); past, past use 1 yr or longer; current, use for >= 1 yr. | All cardiovascular disease | | | | | | | Current users | | RR = 0.66 | | | Current users:
| | | Coronary Heart disease (CHD), (incl. MI and sudden death) | | | | | | | RR 0.47(0.20–1.08) | | (0.20–2.20) | | | all CVD
| | | All cancers | | | | | | | | | >=10 y | | | RR 0.46(0.29–0.73);
| | | All cause mortality | | | | | | | | | RR = 0.38 | | | RR 0.46(0.29–0.73);
| | | Death Certificates | | | | | | | | | (0.13–1.10) | | | CHD
| | | | | | | | | | | | | | | RR 0.49(0.26–0.93);
| | | | | | | | | | | | | | | All cause mortality:
| | | | | | | | | | | | | | | current
| | | | | | | | | | | | | | | RR 0.69(0.54–0.87)
| | | | | | | | | | | | | | | past
| | | | | | | | | | | | | | | RR 0.79(0.66–0.95)
| | | | | | | | | | | | | | | Healthy user effect
| | | | | | | | | | | | | | | Comparison of SMR on internal controls to US population, white women.
| | | | | | | | | | | | | | | Low ERT prevalence and limited power
Singh PN, Lindsted KD, Fraser GE. Body weight and mortality among adults who never smoked. Am J Epidemiol. 1999;150(11):1152–1164. | Adventist Health Study Cohort I | HRT info obtained from census questionnaires, classified as never, current and past use. Duration of use also obtained. | BMI and mortality cerebrovascular mortality | F/U 12 years (1976-1988); F/U 96–97% complete | Age; | RR of Death due to cerebrovasc. dz, HTN and other CV dz: | | | | Control group | | | | Poor Used death certificate data only strokes not classified (ie, SAH, TES, ICH); Not adjusted for HTN, DM. Good F/U. Defined, comparable population. | Comparison/referent group NOT non-users
| N=20,346(13281 women; 7065 men) | | Deaths ascertained by record linkage with California Death Certificate File and National Death Index and church records. | | All were never smokers at baseline; | HRT>5 yrs: | | | | Nonusers Deaths
| Health, SDA's, white, never-smoking, no CAD, stroke or cancer at baseline, aged 25–84. | | | | Not adjusted for DM or HTN. | (Quartile BMI) | 1 | 5 | | n=480
| Younger cohort (25–54 yr) - 29% menopausal | | | | | Baseline BMI | 1.4 | 1.4 | | 1 | 5
| Older cohort (55–84 yr) - 96% menopausal; 47% participated in Adventist mortality study (1960-1985) - subcohort. | | | | | n = 480 | (0.7–2.6) | (0.7–2.6) | | 1.9 (1.3–3.0) | 1.7 (1.1–2.7)
| 1976-1988 | | | | | Stable wt. | 0.4 | 2.0 | | n=149
| | | | | | n = 149 | (0.05–3.4) | (0.5–7.5) | | 1 | 5
| | | | | | HRT <5yrs: | | | | 1.8 (0.4–9.3) | 2.0 (0.9–4.2)
| | | | | | (Quartile BMI) | 1 | 5
| | | | | | Baseline BMI | 0.8 | 1.9
| | | | | | n=480 | (0.3–2.0) | (0.9–3.7)
| | | | | | Stable wt. | 3.11 | 2.0
| | | | | | n=149 | (0.8–11.6) | (0.4–9.3)
Fung, 1995 ^57^ | Cohort of middle to upper class Caucasian women from Rancho Bernado, CA; aged 60 or older; no h/o of stroke. | Info obtained by trained interviewer using standard Rancho Bernardo Study and Rose questionnaires; HRT use validated by examining pills and/or prescriptions by nurse. (92.4% of CU was validated) | Fatal/Nonfatal Strokes | average 8.75 years; Vital status determined for 99% of participants | adjusted for age, current smoking, systolic blood pressure and diabetes. | For TIA or non-fatal stroke, N=20 (8 CU, 9 PU, and 3 NU's) | | | | For fatal stroke | | | | Fair; Outcome was stroke death only; F/U 99% complete; homogeneous population; appropriate adjustment of confounders. | Despite small number of events, statistical power sufficient to detect 40% protection from stroke death (1-B = 0.83). Didn't differentiate thrombotic from hemorrhagic strokes.
| Initial survey 1972-74 | Current use (within the past two weeks). (76% taking CEE; 29% also taking progestin, mainly MPA | Deaths = 263 (25.5% of cohort) | | Not adjusted for ethnicity or SES (restricted at entry by population location) | CU vs NU = 4.43 (0.83–23.58) | | | | CU vs. NU = 0.92(0.34–2.49) | | | | | -Recruitment ends 1987; f/u questionnaire in 1995 given to survivors; 433 responded (?out of how many survivors); nonfatal stroke & TIA's addressed at that time.
| Repeat survey/questionnaires 1984-1987 (80% of surviving cohort) - baseline survey | F/U visit 1995 - 433 participants: | 178 death certificates listed CVD (67.7%) and 37 listed stroke as cause or contributing to cause of death. | | | | | | | PU vs. NU = 0.85(0.40–1.81) | | | | | Current users compared to never users were significantly younger (avg. 70.6 vs. 75; p<0.001); had lower BMI (p<0.001); had lower total cholesterol (~224 mg/dl; p<0.001); Lower LDL (126 mg/dl; p<0.001) and higher HDL (74.1 mg/dl p<0.001) compared to both never & past users; Less DM (p=0.01) compared to never users.
| N=1031 | 32.6% - CU; 45.3% PU; 22.2% NU | Fatal Strokes: | | | | | | | CU vs. PU = 1.14(0.44–2.93) | | | | | High rate of current (32.6%) & past users (45.3%). 76% of CEE, 29% of MPA
| Cohort (84–87 survey) divided into current users(CU) N=278, past users(PU) N=459; and never users(NU) N=294 | | 7 in current users
| | | 16 in former users
| | | 14 in never users
| | | Vital status determined by annual mailers. Deaths verified with death certificates, ICD-9 codes; in random 1/3 of subjects, validation of cause of death attempted by interviews with next of kin, MD and hosp. records. Fatal CVD confirmed by panel of cardiologists in 85% of cases.
Grodstein 2000 ^58^ | Women from the Nurses Health Study; age 30–55 y/o, no prev. h/o CVD. 1976-1996. N=70,533 | 1976 - duration of use obtained | Total (NF/F) strokes, Ischemic stroke, SAH, IPH; MI/CABG/Angioplasty, death from CAD. | up to 20 yr f/u from 1976-1996 (808,825 person-yrs) >90% | Adjusted for age, age at menopause, BMI, smoking, DM, HTN, hypercholesterolemia, FH h/o of MI before age 60 | AS (767) | IS (432) | HS (174) | | Current: | | | | Good; Comparable groups, all outcomes considered. Adjusted for major risk factors. | 73% strokes confirmed;
| | 1978 - type of HRT noted | Positive report in questionnaire resulted in review of medical records; NF strokes verified by med. Record if typical neurologic symptoms lasting at least 24 hours and meeting criteria of the Nat'l Survey of Stroke. Stroke classified as ischemic (thrombotic or embolic), SAH, IPH. If no medical record available, case defined as probable if they required hospitalization and letter of interview corrobaorated event. Death reported by subjects family and verified by medical records, autopsy records. Non-respondents searched Nat'l Death Index | F/U Mortality data >98% | | Current | 1.13(0.94–1.35) | 1.26(1.00–1.61) | 0.93(0.64–1.34) | HRT 0.81(0.54–1.22) | | | | | Major coronary heart dz + stroke:
| | 1980 - dose of oral estrogen obtained. | | | | Past | 1.02(0.85–1.24) | 1.01(0.79–1.30) | 0.95(0.65–1.40) | ERT 0.81(0.49–1.34) | | | | | HRT RR 0.71(0.69–0.87), significant due to a preponderance of CHD end points.
| | Hormone use updated by biennial questionnaire. | | | | Any dose: | | | | CHRT 1.22(0.65–2.28) | | | | | ERT RR 0.75(0.65–0.87)
| | 44.3% never users f/u time | | | | ERT only | 1.18(0.95–1.46) | | | N=119 stroke deaths. | | | | | CHRT RR 0.91(0.75–1.11)
| | 22.9% past users f/u time | | | | CHRT | 1.45(1.10–1.92)
| | 32.8% current users f/u time | | | | 0.625 mg only:
| | | | | | ERT only | 1.24(0.95–1.62)
| | | | | | CHRT | 1.54(1.12–2.11)
| | | | | | Duration of use:
| | | | | | AS | IS | HS
| | | | | | <1 y | 1.32(0.76–2.32) | 1.07(0.44–2.61) | 1.56(0.63–3.90)
| | | | | | 1–1.9 y | 1.04(0.55–1.97) | 1.32(0.58–3.00) | 0.63(0.15–2.59)
| | | | | | 2–4.9 y | 1.14(0.86–1.52) | 1.31(0.90–1.92) | 0.95(0.54–1.67)
| | | | | | 5–9.9 y | 1.05(0.79–1.38) | 1.36(0.96–1.92) | 0.74(0.40–1.36)
| | | | | | >10 y | 1.17(0.91–1.49) | 1.17(0.84–1.63) | 1.03(0.59–1.78)
| | | | | | Dose response:
| | | | | | AS | IS | HS
| | | | | | 0.3 mg | 0.54(0.28–1.06) | 0.43(0.16–1.16) | 0.51(0.13–2.10)
| | | | | | 0.625 mg | 1.35(1.08–1.68) | 1.44(1.07–1.93) | 1.41(0.91–2.19)
| | | | | | >1.25 mg | 1.63(1.18–2.26) | 2.00(1.32–3.05) | 1.18(0.58–2.38)
| | | | | | AS = all stroke
| | | | | | IS = ischemic stroke
| | | | | | HS = hemorrhagic stroke
Luoto R, Manolio T, Meilahn E, et al. Estrogen replacement therapy and MRI-demonstrated cerebral infarcts, white matter changes, and brain atrophy in older women: the Cardiovascular Health Study [see comments]. J Am Geriatr Soc. 2000;48(5):467–472. | Cardiovascular health study cohort | HRT use determined at baseline annual exam by self report and/or prescription check | MRI infarcts cerebral atrophy white matter changes | Not clear | Only age adjusted for MRI infarcts | MRI infarcts (%) | | | | N/A | | Current vs. past vs. never | | Poor | HRT users showed no difference from current, past or never users in terms of prevalence of MRI infarcts
| 2133 women randomly recruited from N. Carolina, California, Maryland & Pennsylvania aged 65–95 y/o between 1992-1994 population-based prospective study | Current, past or never use. | | | Adjusted for age, education, race, BP, smoking, hysterectomy, menopause type, medications, ETOH, BMI, live births for cerebral atrophy and white matter changes | HRT | | | | | | Sulcal warning: | | Only age adjusted data for MRI infarcts | Current users had significantly higher education, lower BMI, higher ETOH use
| | ERT current users (n=272) 12.8% | | | | Current (n=88) 28.6% | | | | | | Ptrend = 0.07 | | 63% response rate: (2133 out of 3393 women eligible had MRI scans) | No significant dose response relationship found. Also for duration of use.
| | ERT past users (n=429) 20.1% | | | | Past (n=142) 29.9% | | | | | | Bifrontal distance | | | No significant association between white matter change and use of ERT.
| | CHRT current users (n=87)2.7% | | | | Never (n=403) 29.9% | | | | | | Ptrend = 0.01
| | CHRT past users (n=54) 2.5% | | | | Ptrend= 0.70* (age adjusted)* | | | | | | Ventricular size
| | Combined ERT/CHRT | | | | total number MRI infarcts = 744 (35%) | | | | | | Ptrend = 0.01
| | HRT current users (n=329) 15% | | | | | | | | | | MMSE score
| | HRT past users (n=483) 23% | | | | | | | | | | HRT use: 89.2 CI (88.3–90.2)
| | | | | | | | | | | | Never use: 87.8 CI (87.3–88.3)
| | | | | | | | | | | | Past use: 89.9 CI (89–90.7)

Evidence Table 4. HRT and stroke - case control studies

Reference | Setting/Study Population/Date | Cases | Controls | Exposure Assessment/Classification | Confounders Adjusted For | HRT & Stroke (MAOR) | HRT Duration (MAOR) | HRT and Time Since Last Use | Other Findings (MAOR) | Quality of Study | Comments
Rosenberg SH, Fausone V, Clark R. The role of estrogens as a risk factor for stroke in postmenopausal women. West J Med. 1980;133(4):292–296. | Case control study involving women 50–80 y/o with Kaiser Foundation Health Plan, from the SF, Redwood City, South SF, Hayward and Santa Clara area. From 1972-1974. | Women >45 yr. Discharged from Northern California Kaiser Foundation Hospital with a diagnosis of stroke from 1972-1974. | 2 matched controls by age with in 5 years and geographic location (same city), randomly selected from Kaiser databank, no history of stroke. | Inpatient and outpatient charts were reviewed by two physician investigators for the use of estrogen. Also for risk factors, cerebral vascular ds., cardiovascular ds., DM, Htn, CAD. Smoking history was unable to obtained reliable b/c of variation in charts. | Adjusted for age only. | Stroke F/NF | nr | nr | | Poor - good ascertainment of cases and controls; important confounders not adjusted for, htn, smoking , lipids, FHx. | 17 cases eliminated b/c no matched controls could be found. Occurred in the 80–90 year old group; none were on ERT.
| | N=198, 20.7% taking estrogen. | N=396, 18.4% taking estrogen; 19.3% on estrogen after diabetics removed from analysis. | Estrogen use defined as subject cases had to be taking ERT at time of stroke and control case had to be using ERT at the time subject case were matched, when they had stroke. | | 1.16(0.75–1.77) unadj
| | After diabetics removed from study, 24% on estrogen | Primarily used CEE 0.625 mg or 1.25 mg. | Mailed questionnaires to patients covering info sought in chart review. 84 out of 215 returned. Of those that responded, showed excellent concordance. | | 1.32(0.84–2.09), after diabetics were eliminated.
| | | Average duration of use on 0.625 mg was 7.6 yr, 1/3 of patients; avg. duration of use for 1.25 mg was 7.15 yr, 2/3 patient. | Stroke data obtained by review of medical records, those with diagnosis of stroke; defined further as occlusive cererovascular disease referable to a specific artery. Excluded intracerebral hematoma and vague diagnosis such as cerebrovascular insufficiency and dizziness. Examined H&P's, labs, xrays and angiograms if available.
Pfeffer 1978 ^64^ | Case control study involving 15,500 women living in a retirement community in Southern California from 3/64–12/74. Ages 44–100, avg 70. | Female residents in community with first stroke resulting in hospitalization or death. N=258 | Drawn from resident populations and matched by age with in 1 year; controls matched to case in 5:1 ratio. | Estrogen exposure defined as ever vs. never use. Estrogen use assessed from a file of 25,300 original and refill prescriptions filled at the medical center pharmacy between 1964 and 1974. (Of note 81% of cases and controls obtained care from the medical center and of those 92% obtained their prescriptions from that pharmacy.) On second survey on 1/76 or 2/76 79.8% of female residents used the medical center pharmacy as the sole source of prescribed medications. | Adjusted for HTN, DM and age. | Stroke F/NF 0.97(0.65–1.44) | nr | nr | | Fair - good ascertainment of cases with nonbiases selection of cases/controls. May have some exposure error given that RX data used and individual info not obtained. Attention to some confounders, but not important ones such as smoking and family history. | There were 6 cases and 22 controls who were identified as ERT users from outpatient charts and not from RX data.
| | | N=1260 | Stroke cases detected by review of discharge diagnostic indices in five hospitals and review of death reports in community medical center. Data of first stroke was abstracted by a neurologist who was blinded to ERT use, BP and glucose tolerance. | Not adjusted for lipids, family history, smoking | nonembolic infarction 1.13(0.71–1.77) | | | | | Primarily used CEE
| | | | | | hemorrhagic stroke 0.86(0.00–9.19×103)
| | | | | | embolic infarction 0.49(0.00–5.38)
| | | | | | TIA 2.79(0.67–11.62)
Thompson 1989 ^59^ | Case-control study; Patients from 83 general practices belonging to the Medical Research Council's General Practice Research Framework. Women from UK, white, ages 45–69; | N=603; white women age 45–69; 244 cases of stroke; 359 cases of MI; | N=1206; controls were white women, matched to case for age (within 2 years) and for general practitioner. Selected from age/sex register; Difficulty finding controls b/c of non-attendance of interviews (79% selection of first trial) | Coordinating centre(Northwick Park) followed up all notifications of suspected stroke, or MI; copies of med. records, clinical, lab testing and autopsy findings. Classification by WHO criteria; Questionnaires obtained from cases and controls. HRT use info obtained from recorded prescriptions and PMHx; HRT use defined as receiving at least two prescriptions. | Adjusted for marital status, smoking, family h/o MI, h/o htn, venous thrombosis, stroke, MI and DM. | CVA & MI in women with confounding factors | Estimated RR of CVA & MI by duration of use | Estimated RR of CVA & MI | RR of CVA & MI by # of Prescriptions: 1 rx = 1.02(0.68–1.53); >1Rx = 1.36 (1.01–1.81); p=0.04. (risk of stroke (RR=1.2) vs. MI(RR=1.48) not statistically sig./ no statistical diff between fatal and nonfatal events). | Fair - Good; asc. Cases ok; selection of controls may have some bias - intial 79% response rate; adj for most conf. Except for SES. | Only 1% current users.
| 9/81–9/82 - retrospective case retrieval (part 1) N=148, (5 fatal) | | | | No adjustment for SES | Any HRT = 1.29 (0.82–2.0) | 1–3 mos = 2.14 | 0–1 yr = 1.06 | *RR by HRT type (>1Rx)
| 9/82–1/86 - part 2 of study N=455 (126 fatal) | | | | | Estrogen only = 1.09 (0.65–1.82) | 4–6 mos = 1.09 | 2–5 yrs = 0.74 | Estrogen only = 1.12 (0.79–1.57)
| | | | | | Progestogen only = 1.02 (0.45–2.32) | 7–12 mos = 1.06 | 6–10 yrs = 1.34 | Progestogen only = 1.90 (1.11–3.25); p=0.02 (corresponding RR for fatal events = 5.27; nonfatal events = 1.46; p=0.08 for difference between F/NF events; no diff. between MI or stroke, p=0.2).
| | | | | | Combined E/P = 1.16 (0.43–3.12) | 13–24 mos = 1.14 | 11–15 yrs = 1.73 | Combined = 0.86 (0.43–1.74)
| | | | | | OR CVA 1.20, p>0.2 | >24 mos = 1.19 | >15 yrs = 2.44
| | | | | | | p-trend = 0.09 | p-trend = 0.009
Adam S, Williams V, Vessey MP. Cardiovascular disease and hormone replacement treatment: a pilot case-control study. British Medical Journal Clinical Research Ed. 1981;282(6272):1277–1278. | Women aged 50–59 from England/Wales. | women aged 50–59 who died in England/Wales during 11/78 due to acute myocardial infarction (AMI) or subarachnoid hemorrhage (SAH) | N=45, randomly selected matched for age from practice list using defined procedure. Unclear where practice list obtained. | Questionnaire was mailed to 190 practitioners who cared for the women who died of AMI and SAH. Data obtained on medical history, smoking, HRT and menopausal status. 97/190 questionnaires received. | Unadjusted. | RR not reported, unable to estimate from data provided. | | | | Poor. Not adjusted for confounding. Poor response rate from physicians.
| 11/78 | N=23 SAH | 7% of controls on ERT | Deaths verified by death certificate. No other data given.
| | 4% of cases on ERT.
Longstreth 1994 ^74^ | Population-based case control study; King County, WA. from 7/87–6/89 | N=103; women 18 yrs. Or older; pre and post-menopausal; Avg. age 57.6 +/- 17.4. Patients recruited from King County, WA from 7/87 - 6/89; invited by PCP; pt. >18 y/o with spontaneous SAH; Primarily white, mean age ~57 +/- 17 yrs. English speaking; Had telephone; | N=206; Identified using random-digit telephone dialing; Two-matched controls per case by age, sex with in 5 yr.; English speaking only; Avg. age 57.4 +/-16.9; | Interview in person, usually at home; info obtained by self-report or proxy. Cases identified by surveillance system relying on physician, hospital and EMS, and King County Medical examiner. Excluded primary intraparenchymal hemorrhage, AVM, trauma and neoplasm. | Controlled for self-reported data vs. proxy derived data. | Age-adjusted OR for risk of SAH in women on HRT. | Age adjusted OR for risk of SAH for duration of use of HRT: | Age adjusted OR for risk of SAH by time since last use: | Menopausal status and risk of SAH (age adjusted): | Fair; possibility of inaccurate ascertainment of cases, as it relies on PCP to invite into study; selection of controls by random digit dialing; comparable; Resp. rate: out of 466 elligible controls, 313 participated (67%) | Did not assess estrogen dose or progestins.
| | | | | | Never user = 1.00 | Never user = 1.00 | Never = 1.00 | Postmenopausal = 1.00 | | Cases represented 69% of total cases (103/149); Cases had less education (12.6+/- 2.4 y vs. 13.5+/-2.5 yr); Index and proxy agreement, kappa = 0.58–0.96
| | | | | | Ever user = 0.47 (0.26–0.86); | <1 year = 0.65 (0.26–1.60) | >15 years = 0.67 (0.21–2.20) | Premenopausal = 0.24(0.09–0.68)
| | | | | | Former user = 0.58 (0.28–1.21); | 1–5 years = 0.24 (0.07–0.85) | 1–15 years = 0.40 (0.11–1.50)
| | | | | | Current user = 0.38 (0.17–0.84) | >=5 years = 0.33 (0.12–0.88) | <1 year = 0.32 (0.15–0.69)
Thrift 1996 ^77^ | Melbourne, Australia; 1990-1992 | Pt. With primary ICH between 1990-1992; Ages 18–80 y/o. N=331(total number of cases); 60% men, 90% white; mean age 63.4 y/o; | Controls recruited by nurse home visits and matched with case by age and sex, in the same neighborhood. Total number of controls N=331 | Structured questionnaire given by trained research nurses; avg. 6–7 mos after event; controls with in 2 mos of case interview; HRT present if used ever in lifetime. ICH classified by sudden onset of symptoms; CT evidence (~95% cases); Autopsy (<5%); MRI (<1%) | Htn, cholesterol, prev. cardiovascular ds, exercise, BMI, smoking, ETOH; Not Adjusted for DM, Fam. History | 0.36 (0.14–0.95) | NR | NR | | Fair; Good asc. of cases; control select. ok; Resp. rate not clear; not adj for DM | HRT may be associated with decrease risk of ICH (but results only borderline significance).
| | | | | | N=11, ever-users of HRT | | | | | Type of estrogen, whether progestin present not assessed.
| | | | | | N=26, never users | | | | | Duration of use, time of last use not evaluated; Small number of cases of women on HRT.
Pedersen 1997 ^72^ | Population-based casecontrol study. | Danish women from Danish Nat'l Pt. Register in Denmark. | N=3171/4370 after exclusions; 2 controls matched to each case by age within 3 mos. Controls identified in the Central National Person Register and selected randomly. | Exposure divided into never, former and current use of unopposed estrogen, and current use of combined estrogen-progestagen therapy. | Adjusted for: h/o thromboembolic disorder (other than CVA); treatment of htn; heart disease, anticoagulant therapy; DM, migraine, former use of oral contraceptives; body weight/ height education, marital status, occupational status; smoking habits, physical activity. | HRT/SAH: Adjusted | nr | nr | | Good; Accurate case asc. Selection of controls ok; exclusion criteria equally applied; exposure measured by questionnaire and supported by picture of pills; appropriate adjustment for confounders. Response rate 84.3% for cases and 86.3% for controls. | Number of deaths not evaluated.
| Denmark, women aged 45–64 1990-1992 | Age 45–64 who had first ever, non-fatal CVA between 1990-1992. | | Information obtained from questionnaires. | | Never use 1.00
| | N=1422/2584 after exclusions; SAH = 160 | | | | Former 0.78(0.46–1.30)
| | ICH = 95 | | | | UE 0.53(0.23–1.25)
| | Thromboembolic infarction (TES)= 846; | | | | combined 1.30(0.84–2.02)
| | TIA = 321 | | | | HRT/ICH:
| | Strokes defined by WHO, ICD-9 codes 430–438; Validity of stroke diagnoses investigated in random sample of 347 case records (15% of cases)- confirmation of stroke diagnoses based on evidence of acute onset, localized brain dysfunction, results of CT, MRI or arteriography; Diagnoses compared in hospital records, ICD-9 codes. | | | | Never use 1.00
| | | | | | Former 1.09(0.58–2.03)
| | | | | | UE 0.18(0.02–1.27)
| | | | | | Combined 1.22(0.66–2.23)
| | | | | | HRT/TES:
| | | | | | Never use 1.00
| | | | | | Former 1.12(0.88–1.42)
| | | | | | UE 1.24(0.91–1.70)
| | | | | | Combined 1.27(1.00–1.62)
| | | | | | HRT & risk of TIA's:
| | | | | | Never use 1.00
| | | | | | Former 1.83(1.33–2.51)
| | | | | | UE 2.13(1.41–3.22)
| | | | | | Combined 1.20(0.81–1.76)
Grodstein 1997 ^53^ | Nested case control study within the Nurses Health cohort | Total deaths = 3637 | 10 controls per case randomly selected | HRT exposure obtained at baseline interview and subsequent biennial questionnaire | Adjusted for age, age at menopause, type of menopause, BMI, DM, BP, cholesterol, smoking, past OCP use, family h/o MI and breast cancer, parity, age at menarche, time period | Never use = 1.00 | | | | Good
| | Total stroke deaths = 167 | Postmenopausal women free of cancer and cardiovascular disease | For each death, HRT status defined by last questionnaire before death or before diagnosis of disease that led to death | | Current HRT use: 0.68 (0.39–1.16)
| | Deaths from stroke from 1976 - 6/1/94 | Matched to case by age (within 1 year) | ICD defined codes 430–438 | | past HRT use: 1.07 (0.68–1.69)
| | Deaths obtained from Natural Death Index | age at menopause (within 1 year) type of menopause period of case patient's death within 2 years
Petitti 1998 ^71^ | Postmenopausal women 45–74 hospitalized for stroke in Northern Calif. Kaiser Facilities (10) 11/91–11/94; | N=349; Initially 885 possible stroke cases, 758 of which confirmed; (550 - ischemic; 201 -hemorrhagic; After exclusions, number of ischemic strokes was 349; no. of hemorrhagic strokes = 83; Detailed data on hemorrhagic stroke not presented in study secondary to small number of cases. | N=349; controls matched on birth year and facility of care for each case subject. 81% white | HRT exposure obtained by interview; proxy responses excluded secondary to underreporting; did not use medical records for analysis of HRT use. Info about confounders determined by history, questionnaire. | Adjusted for smoking, htn, DM, prior CVA or TIA, BMI, ethnicity, education | Never use = 1.00 | Never use = 1.0 | | Risk of Hemorrhagic stroke in current users compared with never users was OR = 0.33 (0.12–0.96), based on 83 case/control sets (after adjusting for smoking, HTN, DM, BMI, ethnicity and education.) | Fair- eliminated fair number of cases due to various reasons; exposure equally ascertained, but by interview only. | No mention of fatal case numbers. ~201/550 cases of IS excluded (pt/md refusal; proxy interview; missing HRT data): 118/201 cases of HS excluded for similar reasons.
| | cases identified from hospital admissions/discharge records, ER logs, payments for out of plan hospitalization; 69% white. | | Outcome: Stroke diagnosis established by records reviewed by 2 physicians with discrepancies adjudicated by project neurologist. Had defined protocol, subclassified into hemorrhagic or ischemic infarctions. Was hemorrhagic if: blood found on CT or MRI; nontraumatic LP with blood or xanthochromia, or if intracerebral blood found at autopsy, cerebral angioography or at surgery. Remaining strokes were classified as ischemic. | | Current HRT/ERT use = 1.03 (0.65–1.65) | < 1 y use = 0.75 (0.23–2.42) | | | | No significant difference in previous/current use of HRT between cases and controls.
| | | | | | Past HRT/ERT use = 0.84 (0.54–1.32) | 1–4 y use = 0.67 (0.26–1.73)
| | | | | | | 5–9 y use = 0.69 (0.28–1.72)
| | | | | | | >10 y use = 1.37 (0.79–2.38)
| | | | | | | Past HRT/ERT use = 0.85 (0.54–1.33)

Evidence Table 5a. Angiography Studies - HRT and Coronary Artery Disease - Secondary Prevention

Author, Journal, Date | Setting, Study Population Date | Measurement of Hormone Exposure, Co-mobidity, Other Risk Factors | Type Controls | Outcomes Evaluated, Documentation | FU Length Loss to FU | Assessment of CVD risk factors | RR CVD Among Users Compared to Non-Users | RR by Duration HRT | RR CVD Associated With Current Use and By Duration | RR CVD Associated With Pass Use and By Duration | CVD Mortality RR Among Users Compared to Non-Users | | Comments
Gruchow, 1988 ^79^ | 993 female patients undergoing angiography ages 50–75 in Milwaukee CVD Data Registry 1972-1985 | Questionnaire | Internal | Degree coronary stenosis | NA | [underlined: Adj. for:] | B= -0.15 | | | | | | Prevalence cases not excluded (38% past MI, 69% unstable ? angina)
| | Lab | | | | age | P< 0.1 | | | | | | Survivors
| | Exam | | | | tos | OR severe CAD [underlined: use/non] | | | | | | Poor classification use (sick may have gone off)
| | Use = at time of angio or in 3 months proceeding | | | | exercise | 0.37(0.46-0.29) | | | | | | ?Generalizability
| | | | | | BMI | OR mod CAD [underlined: use/non] | | | | | | Important covariance with HDL
| | | | | | | 0.59(0.73-0.48) | | | | | | Quality: poor
| | | | | | | After HDL/LDL levels entered estrogen not associated with decreased risk
Sullivan, 1990 ^81^ | Cohort of all women consecutively undergoing angiography at Baptist Memorial, TN 1972-1985 referred from 5 states. | History, exam, labs, questionnaires sent to physicians. Estrogen use not specifically obtained. | Internal | Follow-up questionnaires, not exactly specified | 1985 | [underlined: Adj for:] | | | | | RR death among women > 70% stenosis: use/non (adj) | | No duration/dose data
| 3 Cohorts | | | | | age | | | | | *0.16 (0.04–0.66) | | Fatal CAD/MI excluded - Prevalence/incidence bias
| ≥ 70% stenosis | | | | | smoking | | | | | [underlined: Moderate CAD 10 yr. surv.] (unadj): | | ? if controls representative of populations without CAD.
| < 70% stenosis | | | | | HTN | | | | | use | 96% | Quality: fair
| 0 stenosis | | | | | DM | | | | | non | 85%
| | | | | | Chol | | | | | p = 0.027
| | | | | | Not Adj. | | | | | [underlined: no CAD 10 yr surv.] (unadj):
| | | | | | BMI | | | | | use | 98%
| | | | | | Alcohol | | | | | non | 91%
| | | | | | Family | | | | | p = NS
| | | | | | HDL

Evidence Table 5b. Angiography Studies - HRT and Coronary Artery Disease - Secondary Prevention

Study, Year, Journal | Setting/Study Population Date | Cases | Controls | Exposure Assessment/ Classification | Important Confounders Not adjusted for | Major Findings Multivariable Adjusted Odds Rating (MAOR) 95% CI | | Major Findings by Duration Use HRT (MAOR) | Time Since Last Use | Time Since Starting Estrogen | Findings by Other Sub-group Analyses (MAOR) | Comments
Sullivan, 1988 ^80^ | 6452 consecutive women having coronary angiography at Baptist Memorial, TN 1972-1984 | n=1444 defined as > 70% stenosis in one or more epicardial arteries | N=744 | Medical records Defined as estrogen users if using at time of angiography, risk factors obtained from records. | Family history | Stratified by age (unadj) | | | | | | Symptomatic patients,
| | | No stenosis at angiography | No duration data available | Exercise | <59 | 0.44 (0.26–0.76) | | | | | Quality: fair, medical records likely bias in risk factor assessment.
| | | | | BMI | 60–69 | 0.42 (0.18–0.93)
| | | | | | 70+ | 0.56 (0.11–2.96)
| | | | | | Multivar adjusted-OR of having > 70%
| | | | | | 0.58(0.38–0.97)
McFarland, 1989 ^82^ | 2 hospital cardiology practices in South Carolina | All women ages 35–59 who had undergone angiography and had ≥ 70% stenosis. N=137 | From this group all women with normal coronaries | Use < 6 months = non-use | Only age adjusted | Age adj use/non use | | | | | | Quality: poor
| | | N=208 | | | 0.50(0.3–0.8) | | | | | | no adjustment for confounding
| | | | | | Age adj - natural menopause | | | | | | no response rates reported
| | | | | | 0.7(0.3–1.9)
| | | | | | Hysterectomy
| | | | | | 0.6(0.3–1.2)
| | | | | | Bilateral oopherectomy
| | | | | | 0.3(0.1–0.8)