# Addendum

This evidence review was completed in December 2001, and the meta-analyses evaluating stroke death and incidence were updated in February 2002. A summary of the findings will be published in the Journal of the American Medical Association on August 20, 2002.

On May 31, 2002 after approximately 5.2 years of follow-up, the Women's Health Initiative (WHI) randomized controlled trial was stopped on the recommendation of the data safety and monitoring board because the test statistic for invasive breast cancer exceeded the stopping boundary for this outcome. At the time the study was stopped, the findings for several cardiovascular outcomes, including coronary heart disease (defined as acute MI, silent MI or CHD death) and stroke were reported. Among the 8,506 women randomized to conjugated estrogen 0.625mg per day and medroxyprogesterone acetate 2.5mg per day combined in 1 pill, the annual rate of CHD was 37 per 10,000 compared with 30 per 10,000 among women randomized to placebo (n=8,102). The hazard ratio for CHD was 1.29 (nominal 95% CI; 1.02–1.63). When the confidence interval was adjusted for multiple analyses over time the confidence interval was 0.85–1.97. Rates of CABG and PTCA were similar among the 2 groups. The annualized stroke rates were 29 per 10,000 among women randomized to estrogen and progesterone and 21 per 10,000 among those randomized to placebo. The hazard ratio for stroke was 1.41 (95% nominal CI; 1.07–1.85). After adjustment for multiple analyses over time the confidence interval was 0.86–2.31. The curves showing the cumulative hazards for CHD began to diverge shortly after randomization with little evidence of convergence after 6 years of follow-up. The cumulative hazard for stroke began to diverge between 1 and 2 years after randomization and persists beyond the fifth year. Subgroup analyses among women with prior MI or revasculariztion procedures (conditions that would have made them eligible for the HERS) identified a hazard ratio of 1.28 (95% CI; 0.64–2.56). Among the remaining women (without prior CHD) the hazard ratio was 1.28 (95% CI; 1.00–1.65). An important limitation of the study was a very high rate of discontinuation of study drugs during the trial (42% among CHRT users and 38% for placebo); this should result in dilution of any effect.

Notably, a separate arm of the WHI evaluating whether oral estrogen prevents cardiovascular disease among women with prior hysterectomy (n=10,739) was not terminated so the association between ERT and CVD in this trial remains uncertain, with results expected in 2005.

These findings support the main findings of our review and meta-analyses showing no benefit in preventing CAD events and increased rates of ischemic stroke.