# References

1 Brett K M, Madans J H. Use of postmenopausal hormone replacement therapy: estimates from a nationally representative cohort study. Am J Epidemiol. 1997;145(6):536-545. [pmid: 9063344].
2 National Cholesterol Education Program. Second Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II). Circulation. 1994;89(3):1333-1445. [pmid: 8124825].
3 Bush T L. Evidence for primary and secondary prevention of coronary artery disease in women taking oestrogen replacement therapy. Eur Heart J. 1996;17(Suppl D):9-14. [pmid: 8869876].
4 Kannel W B. Metabolic risk factors for coronary heart disease in women: prespective from the Framingham Study. Am Heart J. 1987;114(2):413-419. [pmid: 3604900].
5 Barrett-Connor E, Bush T L. Estrogen and coronary heart disease in women. JAMA. 1991;265(14):1861-1867. [pmid: 2005736].
6 Bush T L, Barrett-Connor E. Noncontraceptive estrogen use and cardiovascular disease. Epidemiol Rev. 1985;7:80-104.
7 Adams M R, Kaplan J R, Manuck S B, et al. Inhibition of coronary artery atherosclerosis by 17-beta estradiol in ovariectomized monkeys. Lack of an effect of added progesterone. Arteriosclerosis. 1990;10(6):1051-1057. [pmid: 2244855].
8 Grodstein F, Stampfer MJ, Manson JE, et al. Postmenopausal estrogen and progestin use and the risk of cardiovascular disease [published erratum appears in N Engl J Med 1996 Oct 31;335(18):1406]. N Engl J Med. 1996;335(7):453–461.
9 Stampfer M J, Colditz G A, Willett W C, et al. Postmenopausal estrogen therapy and cardiovascular disease. Ten-year follow-up from the nurses' health study. N Engl J Med. 1991;325(11):756-762. [pmid: 1870648].
10 Stampfer M, Colditz G. Estrogen Replacement Therapy and Coronary Heart Disease: A Quantitative Assessment of the Epidemiologic evidence. Prev Med. 1991;20(1):47-63. [pmid: 1826173].
11 Wilson P W, Garrison R J, Castelli W P. Postmenopausal estrogen use, cigarette smoking, and cardiovascular morbidity in women over 50. The Framingham Study. N Engl J Med. 1985;313(17):1038-1043. [pmid: 2995808].
12 Sidney S, Petitti D B, Quesenberry C P Jr. Myocardial infarction and the use of estrogen and estrogen-progestogen in postmenopausal women. Ann Intern Med. 1997;127(7):501-508. [pmid: 9313017].
13 Mendelsohn M E, Karas R H. The protective effects of estrogen on the cardiovascular system. N Engl J Med. 1999;340(23):1801-1811. [pmid: 10362825].
14 Vadlamudi S, MacLean P, Israel R G, et al. Effects of oral combined hormone replacement therapy on plasma lipids and lipoproteins. Metabolism: Clinical & Experimental. 1998;47(10):1222-1226. [pmid: 9781625].
15 Marsh M S, Crook D, Whitcroft S I, Worthington M, Whitehead M I, Stevenson J C. Effect of continuous combined estrogen and desogestrel hormone replacement therapy on serum lipids and lipoproteins. Obstet Gynecol. 1994;83(1):19-23. [pmid: 8272301].
16 Nabulsi A A, Folsom A R, White A, et al. Association of hormone-replacement therapy with various cardiovascular risk factors in postmenopausal women. The Atherosclerosis Risk in Communities Study Investigators. N Engl J Med. 1993;328(15):1069-1075. [pmid: 8384316].
17 Folsom A R, McGovern P G, Nabulsi A A, et al. Changes in plasma lipids and lipoproteins associated with starting or stopping postmenopausal hormone replacement therapy. Atherosclerosis Risk in Communities Study. Am Heart J. 1996;132(5):952-958. [pmid: 8892766].
18 Walsh B W, Schiff I, Rosner B, Greenberg L, Ravnikar V, Sacks F M. Effects of postmenopausal estrogen replacement on the concentrations and metabolism of plasma lipoproteins. N Engl J Med. 1991;325(17):1196-1204. [pmid: 1922206].
19 Kim C J, Min Y K, Ryu W S, Kwak J W, Ryoo U H. Effect of hormone replacement therapy on lipoprotein(a) and lipid levels in postmenopausal women. Influence of various progestogens and duration of therapy. Arch Intern Med. 1996;156(15):1693-1700. [pmid: 8694668].
20 Herrington D M, Werbel B L, Riley W A, Pusser B E, Morgan T M. Individual and combined effects of estrogen/progestin therapy and lovastatin on lipids and flow-mediated vasodilation in postmenopausal women with coronary artery disease. J Am Coll Cardiol. 1999;33(7):2030-2037. [pmid: 10362210].
21 The Writing Group for the PEPI Trial. Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. [published erratum appears in JAMA 1995 Dec 6;274(21):1676]. JAMA. 1995;273(3):199–208.
22 Bush T L, Barrett-Connor E, Cowan L D, et al. Cardiovascular mortality and noncontraceptive use of estrogen in women: results from the Lipid Research Clinics Program Follow-up Study. Circulation. 1987;75(6):1102-1109. [pmid: 3568321].
23 Mijatovic V, Kenemans P, Netelenbos J C, et al. Oral 17 beta-estradiol continuously combined with dydrogesterone lowers serum lipoprotein(a) concentrations in healthy postmenopausal women. J Clin Endocrinol Metab. 1997;82(11):3543-3547. [pmid: 9360504].
24 Sacks F M, McPherson R, Walsh B W. Effect of postmenopausal estrogen replacement on plasma Lp(a) lipoprotein concentrations. Arch Intern Med. 1994;154(10):1106-1110. [pmid: 8185424].
25 Espeland M A, Marcovina S M, Miller V, et al. Effect of postmenopausal hormone therapy on lipoprotein(a) concentration. PEPI Investigators. Postmenopausal Estrogen/Progestin Interventions. Circulation. 1998;97(10):979-986. [pmid: 9529266].
26 Haines C J, Chung T K, Masarei J R, Tomlinson B, Lau J T. An examination of the effect of combined cyclical hormone replacement therapy on lipoprotein(a) and other lipoproteins. Atherosclerosis. 1996;119(2):215-222. [pmid: 8808498].
27 LaRosa J C. Metabolic effects of estrogens and progestins. Fertility & Sterility. 1994;62(6 Suppl 2):140S-146S. [pmid: 7958008].
28 Taskinen M R, Puolakka J, Pyorala T, et al. Hormone replacement therapy lowers plasma Lp(a) concentrations. Comparison of cyclic transdermal and continuous estrogen-progestin regimens. Arteriosclerosis, Thrombosis & Vascular Biology. 1996;16(10):1215-1221.
29 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280(7):605-613. [pmid: 9718051].
30 Herrington M D, Revoussin D M, Brosnihan K B, et al. Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med. 2000;343:522-529. [pmid: 10954759].
31 Gerhard M, Ganz P. How do we explain the clinical benefits of estrogen? From bedside to bench. Circulation. 1995;92(1):5-8. [pmid: 7788916].
32 Lieberman E H, Gerhard M D, Uehata A, et al. Estrogen improves endothelium-dependent, flow-mediated vasodilation in postmenopausal women. Ann Intern Med. 1994;121(12):936-941. [pmid: 7978718].
33 Collins P, Rosano G M, Sarrel P M, et al. 17 beta-Estradiol attenuates acetylcholine-induced coronary arterial constriction in women but not men with coronary heart disease. Circulation. 1995;92(1):24-30. [pmid: 7788912].
34 The ESHRE Capri Workshop Group. Hormones and cardiovascular diseases: oral contraceptives and hormonal replacement therapy: differential effects on coronary heart disease, deep venous thrombosis and stroke. Hum Reprod. 1998;13(8):2325-2333. [pmid: 9756321].
35 Estelles A, Cano A, Falco C, et al. Lipoprotein(a) levels and isoforms and fibrinolytic activity in postmenopause--influence of hormone replacement therapy. Thrombosis & Haemostasis. 1999;81(1):104-110. [pmid: 10348700].
36 Sbarouni E, Melissari E, Kyriakides Z S, Kremastinos D T. Effects of simvastatin or hormone replacement therapy, or both, on fibrinogen, factor VII, and plasminogen activator inhibitor levels in postmenopausal women with proven coronary artery disease. Am J Cardiol. 2000;86(1):80-83. [pmid: 10867097].
37 L'Hermite M. Sex hormones and cardiovascular risk. Acta Cardiol. 1991;46(3):357-372. [pmid: 1927164].
38 Miller J, Chan BKS, Nelson HD. Hormone replacement therapy and risk of venous thromboembolism; system evidence review. Rockville, MD: Agency for Healthcare Research and Quality; in press 2000.
39 Grady D, Wenger N K, Herrington D, et al. Postmenopausal hormone therapy increases risk for venous thromboembolic disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2000;132(9):689-696. [pmid: 10787361].
40 Folsom AR, Kaye SA, Sellers TA, et al. Body fat distribution and 5-year risk of death in older women [published erratum appears in JAMA 1993 Mar 10;269(10):1254]JAMA 1993;269(4):483–487.
41 Ridker P M, Hennekens C H, Buring J E, Rifai N. C-reactive protein and other markers of inflammation in the prediction of cardiovascular disease in women. N Engl J Med. 2000;342(12):836-843. [pmid: 10733371].
42 Ridker P M, Hennekens C H, Rifai N, Buring J E, Manson J E. Hormone replacement therapy and increased plasma concentration of C-reactive protein. Circulation. 1999;100(7):713-716. [pmid: 10449692].
43 Cushman M, Legault C, Barrett-Connor E, et al. Effect of postmenopausal hormones on inflammation-sensitive proteins: the Postmenopausal Estrogen/Progestin Interventions (PEPI) Study. Circulation. 1999;100(7):717-722. [pmid: 10449693].
44 Liehr J G, Roy D. Pro-oxidant and antioxidant effects of estrogens. Methods Mol Biol. 1998;108:425-435. [pmid: 9921549].
45 Sack M N, Rader D J, Cannon R O, 3rd. Oestrogen and inhibition of oxidation of low-density lipoproteins in postmenopausal women. Lancet. 1994;343(8892):269-270. [pmid: 7905101].
46 Matthews K A, Kuller L H, Wing R R, Meilahn E N, Plantinga P. Prior to use of estrogen replacement therapy, are users healthier than nonusers?. Am J Epidemiol. 1996;143(10):971-978. [pmid: 8629615].
47 Harris R, Helfand M, Woolf S, et al. Current Methods of the U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
48 National Heart, Lung & Blood Institute. Statement from Claude Lenfant, MD, NHLBI Director, on preliminary trends in the Women's Health Initiative. Bethesda, Maryland: National Heart, Lung and Blood Institute.; April 3, 2000.
49 Petitti D B, Perlman J A, Sidney S. Noncontraceptive estrogens and mortality: long-term follow-up of women in the Walnut Creek Study. Obstet Gynecol. 1987;70(3 Pt 1):289-293. [pmid: 3627576].
50 Cauley J A, Seeley D G, Browner W S, et al. Estrogen replacement therapy and mortality among older women. The study of osteoporotic fractures. Arch Intern Med. 1997;157(19):2181-2187. [pmid: 9342994].
51 Sourander L, Rajala T, Raiha I, Makinen J, Erkkola R, Helenius H. Cardiovascular and cancer morbidity and mortality and sudden cardiac death in postmenopausal women on oestrogen replacement therapy (ERT) [published erratum appears in Lancet 1999 Jan 23;353(9149):330]. Lancet. 1998;352(9145):1965–1969.
52 Wolf P H, Madans J H, Finucane F F, Higgins M, Kleinman J C. Reduction of cardiovascular disease-related mortality among postmenopausal women who use hormones: evidence from a national cohort. Am J Obstet Gynecol. 1991;164(2):489-494. [pmid: 1992690].
53 Grodstein F, Stampfer M J, Colditz G A, et al. Postmenopausal hormone therapy and mortality. N Engl J Med. 1997;336(25):1769-1775. [pmid: 9187066].
54 Criqui M H, Suarez L, Barrett-Connor E, McPhillips J, Wingard D L, Garland C. Postmenopausal estrogen use and mortality. Results from a prospective study in a defined, homogeneous community. Am J Epidemiol. 1988;128(3):606-614. [pmid: 3414664].
55 Folsom A R, Mink P J, Sellers T A, Hong C P, Zheng W, Potter J D. Hormonal replacement therapy and morbidity and mortality in a prospective study of postmenopausal women. Am J Public Health. 1995;85(8 Pt 1):1128-1132. [pmid: 7625511]. [pmcid: 1615815].
56 Finucane F F, Madans J H, Bush T L, Wolf P H, Kleinman J C. Decreased risk of stroke among postmenopausal hormone users. Results from a national cohort. Arch Intern Med. 1993;153(1):73-79. [pmid: 8422201].
57 Fung M M, Barrett-Connor E, Bettencourt R R. Hormone replacement therapy and stroke risk in older women. J Womens Health. 1999;8(3):359-364. [pmid: 10326990].
58 Grodstein F, Manson J E, Colditz G A, Willett W C, Speizer F E, Stampfer M J. A prospective, observational study of postmenopausal hormone therapy and primary prevention of cardiovascular disease. Ann Intern Med. 2000;133(12):933-941. [pmid: 11119394].
59 Thompson S G, Meade T W, Greenberg G. The use of hormonal replacement therapy and the risk of stroke and myocardial infarction in women. J Epidemiol Community Health. 1989;43(2):173-178. [pmid: 2592907]. [pmcid: 1052821].
60 Hemminki E, McPherson K. Impact of postmenopausal hormone therapy on cardiovascular events and cancer: pooled data from clinical trials. BMJ. 1997;315(7101):149-153. [pmid: 9251544]. [pmcid: 2127109].
61 Nachtigall L E, Nachtigall R H, Nachtigall R D, Beckman E M. Estrogen replacement therapy II: a prospective study in the relationship to carcinoma and cardiovascular and metabolic problems. Obstet Gynecol. 1979;54(1):74-79. [pmid: 221871].
62 Hernandez Avila M, Walker A M, Jick H. Use of replacement estrogens and the risk of myocardial infarction. Epidemiology. 1990;1(2):128-133. [pmid: 2073499].
63 Eaker ED, Castelli WP. Differential risk for coronary heart disease among women in the Framingham Study. New York, NY: Haymarket Doyma; 1987.
64 Pfeffer R I. Estrogen use, hypertension and stroke in postmenopausal women. Journal of Chronic Diseases. 1978;31(67):389-398. [pmid: 711831].
65 Croft P, Hannaford P C. Risk factors for acute myocardial infarction in women: evidence from the Royal College of General Practitioners' oral contraception study. BMJ. 1989;298(6667):165-168. [pmid: 2493841]. [pmcid: 1835478].
66 Beard C M, Kottke T E, Annegers J F, Ballard D J. The Rochester Coronary Heart Disease Project: effect of cigarette smoking, hypertension, diabetes, and steroidal estrogen use on coronary heart disease among 40- to 59-year-old women, 1960 through 1982. Mayo Clin Proc. 1989;64(12):1471-1480. [pmid: 2557493].
67 Rosenberg L, Palmer J R, Shapiro S. A case-control study of myocardial infarction in relation to use of estrogen supplements. Am J Epidemiol. 1993;137(1):54-63. [pmid: 8434573].
68 Mann R D, Lis Y, Chukwujindu J, Chanter D O. A study of the association between hormone replacement therapy, smoking and the occurrence of myocardial infarction in women. J Clin Epidemiol. 1994;47(3):307-312. [pmid: 8138842].
69 Heckbert S R, Weiss N S, Koepsell T D, et al. Duration of estrogen replacement therapy in relation to the risk of incident myocardial infarction in postmenopausal women. Arch Intern Med. 1997;157(12):1330-1336. [pmid: 9201007].
70 Rose G, Marmot M G. Social class and coronary heart disease. British Heart Journal. 1981;45(1):13-19. [pmid: 7459161]. [pmcid: 482483].
71 Petitti D B, Sidney S, Quesenberry C P Jr, Bernstein A. Ischemic stroke and use of estrogen and estrogen/progestogen as hormone replacement therapy. Stroke. 1998;29(1):23-28. [pmid: 9445323].
72 Pedersen A T, Lidegaard O, Kreiner S, Ottesen B. Hormone replacement therapy and risk of non-fatal stroke. Lancet. 1997;350(9087):1277-1283. [pmid: 9357407].
73 Teunissen L L, Rinkel G J, Algra A, van Gijn J. Risk factors for subarachnoid hemorrhage: a systematic review. Stroke. 1996;27(3):544-549. [pmid: 8610327].
74 Longstreth W T, Nelson L M, Koepsell T D, van Belle G. Subarachnoid hemorrhage and hormonal factors in women. A population-based case-control study. Ann Intern Med. 1994;121(3):168-173. [pmid: 8017743].
75 Schairer C, Adami H O, Hoover R, Persson I. Cause-specific mortality in women receiving hormone replacement therapy. Epidemiology. 1997;8(1):59-65. [pmid: 9116097].
76 Falkeborn M, Persson L, Adami H. The risk of acute myocardial infarction after oestrogen and oestrogen-progestogen replacement. Br J Obstet Gynaecol. 1992(99):821–828.
77 Thrift A G, McNeil J J, Forbes A, Donnan G A. Risk factors for cerebral hemorrhage in the era of well-controlled hypertension. Melbourne Risk Factor Study (MERFS) Group. Stroke. 1996;27(11):2020-2025. [pmid: 8898809].
78 Herrington D M, Fong J, Sempos C T, et al. Comparison of the Heart and Estrogen/Progestin Replacement Study (HERS) cohort with women with coronary disease from the National Health and Nutrition Examination Survey III (NHANES III). Am Heart J. 1998;136(1):115-124. [pmid: 9665228].
79 Gruchow H W, Anderson A J, Barboriak J J, Sobocinski K A. Postmenopausal use of estrogen and occlusion of coronary arteries. Am Heart J. 1988;115(5):954-963. [pmid: 3364352].
80 Sullivan J M, Vander Zwaag R, Lemp G F, et al. Postmenopausal estrogen use and coronary atherosclerosis. Ann Intern Med. 1988;108(3):358-363. [pmid: 3341672].
81 Sullivan J M, Vander Zwaag R, Hughes J P, et al. Estrogen replacement and coronary artery disease. Effect on survival in postmenopausal women. Arch Intern Med. 1990;150(12):2557-2562. [pmid: 2244772].
82 McFarland K F, Boniface M E, Hornung C A, Earnhardt W, Humphries J O. Risk factors and noncontraceptive estrogen use in women with and without coronary disease. Am Heart J. 1989;117(6):1209-1214. [pmid: 2729050].
83 Grady D, Rubin S M, Petitti D B, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117(12):1016-1037. [pmid: 1443971].
84 Ettinger B, Friedman G D, Bush T, Quesenberry C P Jr. Reduced mortality associated with long-term postmenopausal estrogen therapy. Obstet Gynecol. 1996;87(1):6-12. [pmid: 8532268].
85 Henderson B E, Paganini-Hill A, Ross R K. Decreased mortality in users of estrogen replacement therapy. Arch Intern Med. 1991;151(1):75-78. [pmid: 1985611].
86 Barrett-Connor E, Grady D. Hormone replacement therapy, heart disease, and other considerations. Annu Rev Public Health. 1998;19:55-72. [pmid: 9611612].
87 Paganini-Hill A. Estrogen replacement therapy and stroke. Prog Cardiovasc Dis. 1995;38(3):223-242. [pmid: 7494884].
88 Persson I, Bergkvist L, Lindgren C, Yuen J. Hormone replacement therapy and major risk factors for reproductive cancers, osteoporosis, and cardiovascular diseases: evidence of confounding by exposure characteristics. J Clin Epidemiol. 1997;50(5):611-618. [pmid: 9180654].
89 Derby C A, Hume A L, McPhillips J B, Barbour M M, Carleton R A. Prior and current health characteristics of postmenopausal estrogen replacement therapy users compared with nonusers. Am J Obstet Gynecol. 1995;173(2):544-550. [pmid: 7645633].
90 Barrett-Connor E. Postmenopausal estrogen and prevention bias. Ann Intern Med. 1991;115(6):455-456. [pmid: 1872493].
91 Vandenbroucke J P. How much of the cardioprotective effect of postmenopausal estrogens is real?. Epidemiology. 1995;6(3):207-208. [pmid: 7619923].
92 Sturgeon S R, Schairer C, Brinton L A, Pearson T, Hoover R N. Evidence of a healthy estrogen user survivor effect. Epidemiology. 1995;6(3):227-231. [pmid: 7619927].
93 Barrett-Connor E. Heart disease in women. Fertility & Sterility. 1994;62(6 Suppl 2):127S-132S. [pmid: 7958006].
94 Gallagher E J, Viscoli C M, Horwitz R I. The relationship of treatment adherence to the risk of death after myocardial infarction in women. JAMA. 1993;270(6):742-744. [pmid: 8336377].
95 Horwitz R I, Viscoli C M, Berkman L, et al. Treatment adherence and risk of death after a myocardial infarction. Lancet. 1990;336(8721):1002-1003.
96 Wenger N K, Knatterud G L, Canner P L. Early risks of hormone therapy in patients with coronary heart disease. JAMA. 2000;284(1):41-43. [pmid: 10872009].
97 Grodstein F, Manson J, Stampfer MJ. Postmenopausal Hormones and recurrence of coronary events in the Nurses' Health Study. Paper presented at: American Heart Association's 72nd Scientific Sessions Final Program; November 2, 1999, 1999; Atlanta, GA.
98 Price D T, Ridker P M. Factor V Leiden mutation and the risks for thromboembolic disease: a clinical perspective. Ann Intern Med. 1997;127(10):895-903. [pmid: 9382368].
99 Vandenbroucke J P, Helmerhorst F M. Risk of venous thrombosis with hormone-replacement therapy. Lancet. 1996;348(9033):972. [pmid: 8855846].
100 Lowe G, Woodward M, Vessey M, Rumley A, Gough P, Daly E. Thrombotic variables and risk of idiopathic venous thromboembolism in women aged 45–64 years. Relationships to hormone replacement therapy. Thrombosis & Haemostasis. 2000;83(4):530-535. [pmid: 10780311].
101 Psaty B M, Smith N L, Lemaitre R N, et al. Hormone replacement therapy: Prothrombotic mutations, and the risk of incident nonfatal myocardial infarction in postmenopausal women. JAMA. 2001;285(7):906-913. [pmid: 11180734].