# Research Priorities

- Investigate whether subgroups of women are at particularly increased risk of CVD or CAD in association with HRT.
- Almost all studies involve Caucasian women; further research should be conducted among non-Caucasian women.
- Homocysteine levels have recently been identified as important risk factors for CVD. Evaluate whether adding homocysteine levels to multivariate models changes the association with HRT. Consider interaction between homocystiene levels and HRT use.
- The most commonly used estrogen compound is conjugated equine estrogen, which is composed of multiple chemicals. Evaluate whether particular components are associated with different physiologic effects.
- Conduct studies to evaluate whether aspirin might modify the early risk of increased MI, stroke, and clotting, as seen in 2 of the randomized controlled trials.
- Further evaluate the role of transdermal estrogen in CVD, as well as other formulations.
- Evaluate childhood and adolescent exposures that might influence the risk of CVD and might be associated with HRT use.
- Investigate the potential interaction with HRT in women with hypercoaguable states.
- Conduct/complete randomized controlled trials evaluating the role of ERT and CHRT in CVD.
- Conduct more research on lower-dose estrogen preparations.