# Discussion

The data on HRT and CVD events, previously fairly consistent in showing benefit to users, have recently become more uncertain because of the publication of new observational studies, the HERS and ERA studies of secondary prevention, and preliminary, though unpublished, data from the Women's Health Initiative. The major points from this review are:

- HRT has been shown in randomized trials to influence a number of biological intermediates that might in turn influence the risk of CVD, CAD, or stroke. HRT raises triglycerides and HDL, and lowers LDL. In addition, it has important effects on endothelial function, fibrinolysis and clotting, and carbohydrate metabolism; may have oxidant (pro- or anti-oxidant) activity; and may be associated with a proinflammatory response. The balance among these biological intermediates in determining CVD, CAD, and stroke risk is uncertain at this time.
- Forty-two observational studies have evaluated the relationship between CVD and HRT. However, only 20 of them are of sufficient quality to allow a valid evaluation of the association and only these were included in our meta-analyses.
- The best evidence from observational studies suggests increased rates of CVD events, but the findings have not been statistically significant in most studies. When combined in meta-analyses, no statistically significant association is shown, although the point estimates are increased for any measure of use.
- The best evidence from observational studies suggests reduced risk of coronary disease events on the order of 20–40%, although many point estimates are not statistically significant and none of the studies that adjust for SES, alcohol use, or exercise show this benefit.
- The findings from the best observational studies are inconsistent in their findings of risk or benefit from longer duration of HRT and any CVD event.
- The vast majority of observational studies and our meta-analysis show no association between HRT and stroke mortality.
- Our meta-analysis estimate for stroke incidence indicates increased risk with a relative risk of 1.12 (95% CI 1.01–1.23)
- Currently, few data suggest that adding progesterone to estrogen influences the risk of any CVD event associated with HRT.
- When women were randomized to HRT or placebo, one clinical trial of secondary prevention convincingly showed no benefit to women in the first 2 years of HRT use, with a non-statistically significant increase in non-fatal MI until year 3 and in CAD death that persists to at least 4 years. Another trial of secondary prevention also showed no benefit in preventing angiographic progression of CAD among HRT users.
- Preliminary evidence from the Women's Health Initiative, the only randomized controlled trial of primary prevention with HRT, has also suggested increased CVD event rates (including stroke and MI) in the first 2 years of the study among women randomized to HRT.
- Observational studies suggest that HRT is associated with reduced relative risks for CVD and CAD death. In our meta-analysis, however, only current use of HRT was associated with significantly reduced risks of death from CVD and CAD. No significant association was identified between past, ever, or any use of HRT and CVD or CAD death.
- Our meta-analysis evaluating CAD incidence and HRT shows no benefit among the studies that adjust for SES and benefit among studies that do not adjust for SES, suggesting confounding.
- Several observational studies suggest increased risk of ischemic stroke among HRT users. Our meta-analysis identified a significant increase in ischemic stroke among ever users of HRT (RR 1.20; 95% CI 1.05–1.40).

We approached this review differently from others who have reviewed this topic. ^10,^ ^83^ First, we evaluated the overall issue of CVD and then the two major components of it, stroke and CAD. Second, we conducted separate analyses of incidence and mortality for each of the outcomes, as well as a global measure of CVD. Separating these analyses by type of CVD outcome, as well as by incidence and mortality, made sense from both a clinical and epidemiological standpoint because, in spite of many shared risk factors, they are quite different outcomes. Our analysis is also different because we limited our detailed review and meta-analyses to only studies of good or fair quality. With few exceptions, all were population-based, had some assessment of important CVD risk factors, and had no evidence of bias in classification of exposures. We paid particular attention to CVD risk factors, given the known use of HRT by women at lower risk for CVD based on behavioral and environmental factors (discussed below). Finally, we evaluated risks in our meta-analyses using different measures of exposure (current, past, ever) as well as a global (any) measure.

One of the difficulties in assessing the literature evaluating the HRT-CVD relationship is the large span of years (1962-mid 1990s) represented in the observational studies, during which there were dramatic changes in clinical practice and knowledge about CVD. There have also been significant secular changes in the use of estrogen, including type, administration, and dose, as well as the relatively recent practice of adding progesterone to estrogen therapy. Complicating this evaluation is that many studies use only measurements of estrogen use at one point in time or asked women if they had “ever” used HRT. Thus, “ever” and “current” use could reflect very short exposure or very long exposure to HRT. These differences are illustrated in Tables 1 and 2. Also shown is that several studies combined past use with non-use, which would dilute any potential association between HRT use and CVD. The importance of how HRT use is characterized is illustrated in the FHS, where a change in how HRT use was assessed changed relative risk estimates significantly.

The findings of our review evaluating CVD and CAD mortality show relatively consistent decreases in relative risk of CAD and CVD death in association with exposure to HRT, particularly current exposure. Our meta-analyses differed, however, in showing benefit only with current use of HRT with pooled relative risk estimates of 0.64 (95% CI 0.44–0.93) and 0.62 (95%CI 0.40–0.91) for CVD and CAD death, respectively. Other measures of exposure, and in particular, any use of HRT, showed no benefit in CVD/CAD death in our meta-analyses. The major exception to the consistency among the studies is the FHS, where the relative risk of CVD death was non-statistically significantly elevated at 1.94. The FHS, though older than many, was an excellent study, and why their mortality findings differ from most other studies is not clear. One possiblity is that women in the study used higher doses of estrogen than in more recent studies. ^9^ Unfortunately, little information is available about the dose of HRT used in this study. Selection of higher risk women for HRT use can be considered, but is not supported by their data, which shows that women using HRT had lower CAD risk than those not choosing HRT. ^11^ Therefore, it is unclear why the mortality rate among women using HRT in the FHS was increased.

Most other studies show mortality benefits, but this may be explained by many of the biases discussed below. This is supported by the finding of reduced all-cause mortality among women using HRT shown in several studies, ^49,^ ^50,^ ^55,^ ^84,^ ^85^ even from causes unlikely to be influenced by HRT. Adjustment or lack of adjustment for important confounders does not explain variable findings among the studies (see Tables 4 and 7). Finally, review of how HRT use is assessed and defined (see Tables 1 and 2) does not explain different findings among studies.

Many studies have evaluated CAD incidence, and many have shown reduced, though non-statistically significant, relative risks (Table 12). The summary relative risk estimate for CAD incidence from our meta-analysis shows a reduced relative risk of CAD of 0.81 (95% CI 0.69–0.96) for current use when no adjustment for SES is made. This is of lower magnitude than prior meta-analyses have found. No benefit was shown in our meta-analyses for any other measure of HRT use in reducing CAD events. This difference between our meta-analysis and others is likely due to our use of fairly rigorous study inclusion criteria, as well as the inclusion of more recent studies, 2 of which show no benefit. ^12,^ ^51^ It is notable that of the 3 cohort studies evaluating CAD incidence, only the NHS shows reduced risk and the 2 others show non-significantly elevated risks. However, because of the size of the NHS, any meta-analytic estimate will be weighted towards its results. An interesting finding among the studies evaluating CAD incidence is that none of the studies that included adjustment for SES or education in their multivariate models showed reduced CAD incidence. ^12,^ ^51,^ ^65,^ ^67^ This is an important finding, since lower SES is an important risk factor for CAD, as well as for most other poor outcomes, ^70^ and women using HRT tend to be of higher SES, and their better outcomes may be explained by higher SES rather than HRT.

To better evaluate this observation, we conducted the meta-analysis stratifying by adjustment for SES. When this was done, the summary risk derived from studies not adjusting for SES showed benefit for current and past use of HRT. However, when SES was accounted for, no benefit was seen for any type of HRT use. These findings suggest confounding of the HRT/CAD relationship by SES.

To the best of our knowledge, no other meta-analyses have rigorously evaluated studies or included this type of sensitivity analysis. In the area of CAD, Stampfer and colleagues ^9^ conducted a meta-analysis in 1991 that included 6 case-control studies, 16 cohort studies, and 3 cross-sectional angiography studies and found a relative risk of 0.56 (95% CI 0.50–0.61) for CAD events (incidence and mortality). In 1992, Grady and colleagues ^83^ conducted a meta-analysis of HRT and CAD and calculated a relative risk for CAD events of 0.65 (95% CI 0.59–0.71) and CAD death 0.63 (95% CI 0.55–0.72) when comparing ever-users to non-users. More recently, Barrett-Connor and Grady ^86^ conducted another meta-analysis and calculated a summary risk estimate for CAD of 0.70 (95% CI 0.65–0.75) for ERT/CHRT use. In each of these meta-analyses, studies were included which we rated of poor quality and excluded from our review. Several of the studies we excluded from our review did not provide risk-adjusted estimates of relative risk or used data from proxies. In addition, angiography studies that involve symptomatic women and are limited by their cross-sectional design were included in the above meta-analyses. These meta-analyses also differ from ours because they combine mortality and incidence relative risks for HRT. Finally, we evaluated current, past, and ever use in several of our meta-analyses and found significant results only among current users, and this approach differs from all of the above. These differences may partially explain why our review suggests less benefit from HRT in preventing CAD.

Our review and meta-analysis suggest increased rates of CVD among women using HRT, with summary estimates of 1.35 for ever use and 1.27 for current use, which are not statistically significant. This finding differs from prior analyses and likely results from our reviewing total CVD separate from CAD, as well as inclusion of new data from the Hemminki analysis ^60^ and the Finnish cohort. ^51^ Our findings of reduced CVD mortality among current HRT users and no association with CVD incidence were also shown in the Sourander ^51^ and Pettiti ^49^ studies.

The relationship between stroke and HRT is very difficult to study for many reasons. These include inconsistencies in defining stroke endpoints, as well as differences in estrogen formulations and dose, length of use, and time since last use. Not surprisingly, therefore, studies that have been conducted on stroke and HRT have conflicting results. One meta-analysis pooled 15 studies (3 case-control, 3 uncontrolled cohort, and 9 cohort) and found a pooled estimate of the relative risk of stroke among estrogen users of 0.96 (95% CI 0.82–1.13), ^83^ indicating no association between HRT and stroke. This review pooled numerous studies that varied in size and quality. The summary relative risk was estimated by assigning a weight for the relative risk from each study, thereby giving more weight to larger studies. No allowance was made for the quality of the study, allowing poor-quality studies to carry weight equal to that of good-quality studies. A review by Paganini-Hill ^87^ in 1995 analyzed 26 studies, representing 19 cohorts, and found mixed results. Our results differ from prior analyses of this relationship in showing a significantly increased risk of stroke (summary RR 1.12) and ischemic stroke (summary RR 1.15) among HRT users and no association with stroke death. Again, these different findings likely reflect our exclusion of poor quality studies and inclusion of recent studies, many of which have elevated point estimates.

Several biases complicate the interpretation of our results, as well as those of others. The first consideration is selection bias. Women who use HRT tend to be more affluent, leaner, more educated, exercise more often, and drink more alcohol, and all of these factors have been shown to be protective against cardiovascular disease. ^88^ This has been shown in several studies, including the FHS, NHS, IWHS, and NHANES. They are also different premenopausally. Longitudinal data among women who are premenopausal and followed into menopause show that prior to menopause, women who take estrogen postmenopausally are different in significant ways from those who do not. ^46,^ ^89^ In one study, ^11^ the premenopausal women who subsequently took HRT were better educated, drank more alcohol, were leaner and exercised more, and had less comorbidity, and all of these lifestyle characteristics are associated with reduced rates of cardiovascular disease in epidemiologic studies. Thus, the role of estrogen in CVD may be confounded by its relationship with these other important known protective factors for cardiovascular disease. Interestingly, none of the studies evaluating CAD that adjusted for alcohol or exercise showed benefit, supporting evidence of confounding by these factors. These protective factors can be adjusted for analytically when measured; what cannot be adjusted for statistically, however, are lifestyle and/or environmental exposures and/or genetic characteristics that are not measured, or may not yet be identified as important etiologically in cardiovascular disease. This is particularly an issue in CVD, where 50% of it is unexplained by traditional risk factors. ^3^

We know that women who take HRT have access to health care, since they are receiving prescriptions, and they are therefore more likely to be treated for comorbid conditions such as high cholesterol or high blood pressure, which would also lower their risk of cardiovascular disease. ^90^ This has been called “prevention bias” by Barrett-Connor and was effectively demonstrated in an upper-middle-class cohort where current HRT users were significantly more likely than non-users to have several preventive health care measures performed. ^90^ Several studies have suggested that even when known cardiovascular disease risk factors are adjusted for, the social class difference in cardiovascular disease remains, suggesting that social class should be included in multivariate models and that there are as yet unmeasured risk factors for cardiovascular disease that are associated with lower socioeconomic class. ^70^ None of the studies evaluating CAD incidence that adjusted for SES showed benefit, and our meta-analysis showed markedly different relative risks depending on the inclusion or exclusion of SES in the studies' multivariate analyses.

Another type of selection bias that is very difficult to quantify or characterize is selection bias among physicians. Do physicians select women at lower risk of cardiovascular disease for HRT use? This is clearly shown when the characteristics of women who take HRT are evaluated. Significant secular trends have been observed in estrogen use, ^91^ and it is notable that many of the studies of estrogen use were conducted at a time when physicians were concerned about the risk of HRT and CVD, based on the Coronary Drug Project findings among men and MI rates in women taking oral contraceptives. ^91^ In addition, for many of the years represented in these studies, hypertension, diabetes and heart disease were considered contraindications to the use of HRT. ^86^ What is more subtle, though likely apparent to practicing physicians, may be a tendency to offer and prescribe HRT to women for whom the physicians' sense of their overall “health” is higher. This type of selection bias is more difficult to measure and could lead to systematic overestimates of the benefit of HRT in cardiovascular disease.

These types of selection bias have been termed “healthy user bias.” Another aspect of healthy user bias is the common finding that women often quit HRT when they become ill. This tendency would bias studies that evaluate recent use, by underestimating use in ill patients, resulting in reduced relative risk estimates associated with exposure suggesting protection by HRT. This is suggested in studies where current or recent users may have a reduced risk of cardiovascular disease compared to non-users or past users of HRT. It is even more strongly suggested in studies where past users have higher rates of cardiovascular disease than nonusers or current users, suggesting that they may have stopped HRT because of illness. ^92^ In our meta-analyses evaluating CVD and CAD mortality, only current use of HRT was associated with decreased risk of death; other measures of use showed no association. In particular, any use, which combined mutually exclusive point estimates by type of use (past, current, ever) showed no association with decreased risk. This measure of use should have had sufficient power to show benefit if benefit existed, given that current use had enough power. One interpretation of these data is that current use reflects healthy user bias. That is, women currently using HRT are healthier, and when data are combined to reflect any use (current, past or ever), the pool of women is less enriched with healthy users, and benefit is therefore not shown. Clinically, it makes sense that HRT is less likely to be used in women who have become ill, and that when HRT use is evaluated using observational methods, current use actually reflects current health. Supporting the concept of healthy use bias among women using HRT is that several studies have shown reduced all-cause mortality, as well as reduced mortality from accidents and homicides, among women who take HRT, possibly reflecting multiple benefits, but more likely indicating systematic differences among users and non-users. ^22,^ ^49^

Another consideration in evaluating the HRT-CVD relationship is the issue of compliance bias. Women who take HRT, especially for long periods of time, are by definition compliant with therapy. Several epidemiologic studies have shown that compliance itself is associated with reduced risk of disease of many types, often of the same magnitude seen with HRT use. ^93^ Women who comply with treatment are different from those who do not in ways that are protective against cardiovascular disease. In randomized controlled trials, good compliance with placebo has been shown to decrease CAD events by 40 to 60%. ^94,^ ^95^ Because the studies of HRT are almost entirely observational, compliance bias itself may explain much of the benefit seen in studies of HRT and CVD.

Another area of potential bias in evaluating the HRT-CVD relationship, possibly leading to an underestimation of benefit from HRT, is that HRT is more often used by women who have undergone hysterectomy and oophorectomy. Women who undergo premenopausal hysterectomy are at increased risk of CVD, possibly because of loss of estrogen, although this is not clearly delineated as causal in the medical literature. ^4^ This could lead to a systematic underestimate of the benefit of HRT if their baseline risk is higher, since they have a higher likelihood of using HRT. Also, estimating age at menopause in women who have had simple hysterectomies may lead to misclassification of a CVD risk factor that would result in estimates of the association between HRT and cardiovascular disease moving closer to the null if it is nonbiased. However, often the oldest potential age for menopause is used as an estimate for age at menopause, and this could result in bias towards a systematic underestimate of the intrinsic risk of CVD in women with surgical menopause. Finally, women undergoing hysterectomy and receiving HRT are selected for health, since they are able to undergo and survive surgery, which is typically elective.

In the last 2 years, important data from 2 randomized controlled trials of HRT in the secondary prevention of CVD ^29,^ ^30^ and one trial of HRT in the primary prevention of CVD ^48^ have been published, or have released information to the public. Results from these studies are very important because randomization is the only way to deal with the above biases and to ensure equal distribution of known and unknown CVD risk factors or confounders. The HERS study of secondary prevention showed no benefit of HRT in the first 2 years of use, and, in fact, showed an increased rate of MI during the first 2 years of use. ^29^ The ERA study of secondary prevention showed no benefit from HRT in reducing angiographic CHD progression. ^30^ In both these studies of secondary prevention, HRT was initiated long after menopause, which likely differs from most observational studies of primary prevention. It is important to consider that the HERS results may not apply to ERT alone, or to other types of estrogen or progesterone, or other progestin dose schedules. Also, whether these secondary prevention results can be extrapolated to the primary prevention of CVD with HRT is unclear in the absence of further data from randomized controlled trials. The WHI released early results to participants in the spring of 2000. ^48^ These results, as yet unpublished, suggest that women randomized to HRT had rates of stroke, ischemic heart disease, and blood clots higher than those of women randomized to placebo. Again, similar to the secondary prevention studies, the excess rate of these events was found to be highest in the first 2 years of the study, with risks decreasing at approximately 2 years.

How can the results of these 3 studies, and especially the WHI study of primary prevention, be explained, given the observational data described above showing benefit? As discussed at length in this report, it is possible, and even likely, that selection and compliance bias play a major role in the findings from the observational studies. What is especially surprising in these 3 studies, however, is not just the lack of benefit among users, but the suggestion of harm in the first 2 years in 2 of the studies. ^29,^ ^48^ For years it has been thought that the most likely biological explanation for some of the observed reduction in cardiovascular disease risk among HRT users was an improvement in lipid profiles. However, the fact that randomized controlled studies have shown that women had higher CVD risks in the first 2 years of the study in the setting of more favorable lipid profiles, suggests that other important biological effects occur in women who take HRT. As discussed above, estrogen has many other biological effects, and one of these is a complex role in clotting and thrombolysis. The role of clotting is a major issue that must be considered, since stroke, MI, and unstable angina are thought to be partially mediated through clotting mechanisms. These biological changes may result in a shift in balance towards increased blood clotting, which may be a more immediate or acute effect of estrogen, and is consistent with the observation of increased risk among women during the early years of estrogen use. Notably, women at high risk for thrombotic disorders were excluded from these trials. Women who are able to stay on estrogen may be able to benefit from the more chronic benefit of reduced lipids or other changes in physiology.

With the publication of the HERS results and the preliminary reporting of increased event rates in the first 2 years of the WHI, one of the most pressing questions facing investigators and clinicians is whether this early increase in events is later offset by a reduction. Among the fair and good quality studies we reviewed and included in our meta-analyses, only a few provide information that is helpful in evaluating this issue. The Hemminki analysis, ^60^ which used only trial data, suggests (though the finding is not statistically significant) an increase in CVD event with HRT use of relatively short duration. The Criqui data ^54^ suggest an increased risk of CAD death among women using HRT for fewer than 8 years. These authors also investigated order of use among women using HRT for fewer than 8 years. Among women on HRT at the beginning of the study who went off it before 8 years follow-up, the relative risk was 1.24 (95% CI 0.55–2.78). However, for women who were not on HRT at the beginning of the study who began estrogen and used it for fewer than 8 years, the relative risk of CAD death was 2.62 (95% CI 0.59–11.61). A similar pattern of early increased risk, though with smaller relative risk, was also observed with CVD mortality in this cohort. Rosenberg and colleagues ^67^ reported a similar pattern in a large US case-control study where the adjusted relative risk of MI was 1.5 in ERT users of less than 1 year, 1.2 for 1–4 years of use, 0.6 for 5–9 years of use, and 0.5 for more than 10 years of use, suggesting early increased risk. Data from 2 other sources evaluating estrogen use in the secondary prevention of CAD also support an increase in early event rates in association with estrogen. Wenger and colleagues ^96^ report a similar pattern of early events among men involved in the Coronary Drug Project, a randomized controlled trial of estrogen and other therapies in the secondary prevention of CAD. Specifically, among men randomized to estrogen (2.5 mg), the relative risk of CAD events was 1.58 (95% CI 1.04–2.40) in months 0–4 compared to placebo and 0.96 for months 13–60. The relative risk of CAD events associated with months 0–4 compared to months 13–60 of estrogen exposure was 1.65 (95% CI 1.04–2.60). In addition, in the group of men randomized to 5.0 mg of estrogen, this trial arm was stopped because of an increase of adverse events in the first 2 years of use. Among 2,245 women in the NHS with prior MI or coronary atherosclerosis the overall risk of recurrent events associated with estrogen use was 0.65 (95% CI 0.45–0.95). ^97^ However, marked differences were observed with duration of use. In the first year of use, the relative risk of recurrent events was 2.10 (95% CI 0.88–4.99). For years 1 to 2 the relative risk was 1.01 (95% CI 0.31–3.27) and for greater than 2 years use it was 0.56 (95% CI 0.37–0.85). Thus, several studies suggest an early increase in CVD risk in association with HRT which diminishes over 1 to 2 years, consistent with both the HERS and WHI study findings.

In recent years, many new hypercoaguable states have been identified, one of which is the Factor V Leiden mutation. This mutation is a relatively common disorder in the US population, with prevalence of 4–6%, and has been shown to increase the risk of primary and recurrent venous thrombolism 3–6 fold. ^98^ A very interesting recent observation has been the marked interaction and increased risk of blood clotting among women with the Factor V Leiden mutation who use oral contraceptive agents. ^99^ There are theoretical reasons that HRT may interact with this deficiency similarly to oral contraceptives, and recent work suggests a 13-fold increase in risk of clot associated with HRT in women with Factor V Leiden mutations. ^100^ Could an excess number of early CVD events in women with this relatively common disorder or other hypercoagulative states explain some of the HRT findings from randomized controlled trials? Supporting this possibility is a recent case-control study among women with first non-fatal MI which suggests an important interaction with current HRT and the presence of a pro-thrombotic genetic variant among women with hypertension, resulting in a markedly elevated risk of recurrent MI. ^101^ No interaction was observed among non-hypertensive women or those with Factor V Leiden. Also, are there subgroups of women where most of the increased risk is conferred, such that those women at lower risk of clot could benefit from the potential long-term benefits of HRT? The answers to these questions are unknown but are important to pursue.

Based on this review, and extrapolating somewhat from the 2 trials of secondary prevention, there is good reason to question the results of observational studies supporting the use of HRT in the primary or secondary prevention of CVD. Randomized controlled trials are the best way to determine whether these biases explain the effects observed in observational studies. We hope that better information will come from randomized trials in the near future.