# Results

## Cardiovascular Disease, Coronary Artery Disease and Stroke Mortality

The literature evaluating total CVD mortality and/or the subsets of CVD, CAD, and stroke mortality includes 8 studies reporting total CVD mortality, 5 reporting CAD mortality, and 8 reporting stroke mortality. In an effort to report all CVD, we first report data from studies evaluating the global outcome of CVD mortality when it was reported either alone or in addition to the subsets of CAD or stroke mortality. All of the studies providing information to this discussion and the meta-analyses are summarized in detail in Evidence Tables 1 through 5.

### 1. What is the Role of Postmenopausal HRT in the Primary Prevention of Cardiovascular Disease Death?

Definitions of CVD were taken directly from studies evaluating this outcome. In general, these outcomes included stroke, CAD, sudden cardiac death, congestive heart failure, peripheral vascular disease, CABG, or PTCA. In some studies, however, CVD is not clearly defined and likely represents death from a variety of etiologies coded as CVD. Alternatively, CVD may really represent only or primarily CAD events, but was used in a less specific manner by the authors. For these reasons we evaluated CVD rates in addition to its components of CAD and stroke when these were reported.

Among the observational studies reviewed, 8 studies of good or fair quality provided information to this analysis ^11,^ ^22,^ ^49–54^ (Table 4, Evidence Tables 1 and 2). Six of the 8 studies ^22,^ ^49–53^ reported lower CVD mortality among women using HRT, but only 4 reported statistically significant findings. ^50–53^

Table 4. Cardiovascular disease mortality and hormone replacement therapy

Study, year | N | Design | Hormone Type | Hormone Exposure Status | RR | 95% Confidence Intervals | Age | BP | DM | Family History | Chol | LDL/ HDL | Smoking | BMI | Alcohol | Educ SES | Exercise | Other
Quality
Wilson, 1985 ^11^ | 1234 | Cohort | HRT | Ever | | NS | X | X | | | | X | X | X | X
Good
Pettiti, 1987 ^49^ | 6093 | Cohort | HRT | Ever | 0.60 | 0.3–1.1 | X | X | | | | | X | X | X | X | | Marital status
Fair
Bush, 1987 ^22^ | 2270 | Cohort | HRT | Current | 0.63 | P=0.29 | X | X | | | | X | X | X
Good
Criqui, 1988 ^54^ | 1868 | Cohort | HRT | Ever | 0.96 | 0.65–1.43 | X | X | X | | X | | X | X | | X | | Glucose
Fair
Wolf, 1991 ^52^ | 1944 | Cohort | HRT | Ever | 0.66 | 0.48–0.90 | X | X | | | X | | X | X | | X | | Previous MI
Fair
Cauley, 1997 ^50^ | 9704 | Cohort | HRT | Current Past | 0.46 | 0.29–0.73 | X | X | X | | | | X | X | X | X | X | Surgical menopause, health status, clinic, stroke
Good | | | | Past | 0.86 | 0.65–1.15
Grodstein, 1999 ^69^ | 3637 | Nested CC | HRT | Current High CVD risk | 0.51 | 0.45–0.57 | X | X | X | X | X | | X | X | | | | Age at menopause, type menopause, OCP use
Good | | | | Current low CVD risk | 0.89 | 0.62–1.28
Sourander, 1998 ^51^ | 7944 | Cohort | HRT | Current | 0.21 | 0.08–0.59 | X | X | X | | | | X | X | | X | | CAD, CHF
Fair | | | | Past | 0.75 | 0.41–1.37

Among the studies suggesting benefit is the Lipid Research Clinic (LRC) study, in which 2,270 women ages 40 to 69 identified in the Lipid Clinics Prevalence Study were followed for an average of 8.5 years. ^22^ Women participated in a clinical exam, laboratory evaluation, and cardiologic evaluation, as well as an interview. Subjects were classified as current users if they were using HRT at the second visit. After age adjustment, the relative risk of CVD death among women using HRT was 0.34 (95% CI 0.12–0.81). However, with the addition of HDL levels to the multivariate model, the protection associated with HRT use was reduced from a relative risk of 0.44 to a relative risk of 0.63, which was not statistically significant (p=0.29). This finding is very important because it suggests that HDL is an important risk factor for CVD mortality in women. It also suggests that HDL levels among HRT users may be a mechanism of the benefit of HRT and/or that women who use HRT have higher HDL levels independent of HRT, and that HDL is an important confounder of the HRT-CVD mortality relationship. As will be discussed, women taking HRT tend to exercise more, drink more alcohol, and be leaner, characteristics that are associated with increased HDL levels. The LRC Study highlights the importance of adding HDL levels to multivariate models evaluating the HRT-CVD relationship.

The NHS evaluated CVD mortality using nested case-control methodology. ^53^ In this study, 3,637 women dying of CVD were divided into groups at high and low risk for CVD and matched to 10 controls. Among high-risk women, the relative risk of CVD death with current HRT use was 0.51 (95% CI 0.45–0.57); among low-risk women it was 0.89 (95% CI 0.62–1.28).

In the Study of Osteoporotic Fractures (SOF), 9,704 women above the age of 60 were followed for CVD death. The risk of CVD death was reduced only among current HRT users (RR 0.46; 95% CI 0.29–0.73). For past HRT use the relative risk of CVD death was 0.86 (0.65–1.15). ^50^

A study by Wolf and colleagues ^52^ involved a national sample of 1,944 white, postmenopausal women age 55 or older from the epidemiologic followup study of National Health and Nutrition Examination Survey I (NHANES I). All women underwent a baseline interview, physical, and laboratory exam, with HRT use evaluated as “ever” or “never,” and were followed for an average of 16 years. There were 631 deaths among the cohort, and the relative risk of CVD death was 0.66 (95% CI 0.48–0.90). The findings were similar for women with natural and surgical menopause.

A cohort of 6,093 postmenopausal women identified between 1968 and 1972 in Walnut Creek, California was followed until 1983 for mortality. ^49^ In this cohort, the adjusted all-cause mortality was 0.80 (95% CI 0.6–1.0) among HRT users. The relative risk of death from CVD was 0.60 (95% CI 0.3–1.1) among estrogen users.

A Southern California cohort study involving 1,868 white, upper-middle class women, aged 50 to 79, residing in a planned community in Southern California, was followed from 1972 to 1984 for CVD. No difference in CVD mortality was shown among ever users of HRT (RR 0.96; 95% CI 0.65–1.43). ^54^

An important exception to the above studies, however, is the Framingham Heart Study (FHS), ^11^ which showed increased mortality among ever HRT users. This is a prospective cohort study involving 1,234 women from Framingham, Massachusetts who were above age 50 and postmenopausal, and who participated in the 12^th^ biennial survey. During the study, women were evaluated biennially and HRT use was considered positive if reported in the 8 years prior to the baseline of the 12^th^ biennial exam. These 1,234 women were followed for an average of 8 years, but HRT use was not re-evaluated during that time period. The overall rate of HRT use in this study was 24%, with fewer than 5% of women using progestins. Cardiovascular disease death was defined broadly and included death from coronary heart disease, sudden cardiac death, congestive heart failure, and stroke. After 8 years of followup, the relative risk of death was 1.94 and not statistically significant.

A cohort of 7,944 Finnish women, ages 57 to 64, participating in a mammography study, was followed an average of 7 years for CVD death. ^51^ Among women currently using HRT, the risk of CVD death was reduced (RR 0.21; 95% CI 0.08–0.59). Former use was associated with a relative risk of 0.75 (95% CI 0.41–1.37).

Two cohort studies evaluated risk of CVD death by duration of HRT use (see Table 5). Criqui ^54^ found elevated relative risk among women using HRT for fewer than 8 years (RR 1.2–1.55) and lower relative risk among women using HRT for more than 8 years (RR 0.40). However, none of the findings were statistically significant. Cauley ^50^ identified reduced risk among women using HRT for 10 or more years (RR 0.36; 95% CI 0.16–0.57).

Table 5. Cardiovascular disease mortality and hormone replacement therapy by duration

Study, year | HRT Status | Duration (years) | RR | 95% Confidence Intervals
Criqui, 1988 ^54^ | Ever | [underlined: <8 (on-off)¶] | 1.20 | 0.62–2.35
| | [underlined: 8 (off-on)¶¶] | 1.55 | 0.32–6.62
| | [underlined: >8] | 0.40 | 0.05–3.19
Cauley, 1997 ^50^ | Current | 1–9 | 0.78 | 0.44–1.38
| | >10 | 0.36 | 0.16–0.57

¶ On HRT at first evaluation, off at second

¶¶ Off HRT at first evaluation, on at second

The reasons for different results among the studies is unclear. As shown in Table 4, each study adjusted for different sets of confounders, but review of the table does not help in understanding the different results. In addition, the differences do not seem to be explained by differences in the studies' quality or methods by which HRT use was assessed. The findings from the FHS differ from many of the other good quality studies and will be discussed below. Many studies of HRT show a number of biases that may influence mortality estimates among women using HRT; this will also be discussed below.

Our meta-analysis (Table 6, Figure 3) estimated summary relative risks for CVD death in association with HRT using several measures of use. Current HRT use was associated with a summary relative risk of 0.64 (95% CI 0.44–0.93), ever use with a summary relative risk of 0.81 (95% CI 0.58–1.13), and past use with a summary relative risk of 0.79 (95% CI 0.52–1.09). Any use was associated with a summary relative risk of 0.75 (95% CI 0.42–1.23).

Table 6. Meta-analysis summary table

| Current | Past | Ever | Any
Mortality - Meta-analysis
Total cardiovascular disease | 0.64 (0.44–0.93) | 0.79 (0.52–1.09) | 0.81 (0.58–1.13) | 0.75 (0.42–1.23)
Coronary artery disease | 0.62 (0.40–0.90) | 0.76 (0.53–1.02) | 0.81 (0.37–1.60) | 0.74 (0.36–1.45)
Stroke | | | | 0.79 (0.60–1.01)
Incidence- Meta-analysis
Total cardiovascular disease | 1.27 (0.80–2.00) | 1.26 (0.79–2.08) | 1.35 (0.92–2.00) | 1.28 (0.86–2.00)
Coronary artery disease | 0.72 (0.61–0.84) | 0.77 (0.65–0.91) | 0.79 (0.59–1.15) | 0.75 (0.56–1.04)
| 0.98 (0.79–1.18) | 1.06 (0.84–1.31) | 1.09 (0.77–1.58) | 1.04 (0.75–1.40)
Stroke | | | 1.12 (1.01–1.23)

¶ Risks similar for current, past and ever use

¶¶ Adjusted for socioeconomic status

Figure 3. Cardiovascular Disease Mortality and Hormone Replacement Therapy

### Summary

- Seven cohort studies and one nested case-control study evaluating the risk of CVD death associated with HRT use were of good or fair quality.
- Six of these studies suggest decreased risk of CVD death, with relative risks ranging from 0.21 to 0.80 among current or ever users. However, only 4 had statistically significant findings.
- One cohort study showed no association between HRT and CVD death (RR 0.96; 95% CI 0.65–1.43).
- The FHS showed an almost 2-fold (RR 1.94) increased risk of CVD death, which was not statistically significant.
- A nested case-control study conducted among the NHS cohort showed decreased risk among women at high risk of CVD (RR 0.51; 95% CI 0.45–0.57) with current HRT use. For women at low risk of CVD, the relative risk associated with current use was 0.89 (95% CI 0.62–1.28).
- Past HRT use was evaluated in 2 studies with relative risks of 0.75–0.86 that were not statistically significant.
- Two studies evaluated risk by duration of use; one study showed significantly reduced risk with use for 10 or more years (RR 0.36; 95% CI 0.16–0.57). The other showed non-statistically significant increased risk in the first 8 years of use, with reduced risk after 8 years.
- When evaluated with meta-analysis, only current HRT use is associated with reduced risk of CVD death (RR 0.64; 95% CI 0.44–0.93). Past, ever, and any use showed no benefit in our meta-analysis.

### 2. What is the Role of Postmenopausal HRT in the Primary Prevention of Coronary Artery Disease Death?

Among the observational studies evaluating the relationship between HRT and CVD, 5 studies of good or fair quality specifically evaluated the risk of CAD death (Table 7). ^50,^ ^51,^ ^53–55^ Four of these reported total CVD mortality in addition to the subset of CAD mortality, and one, the Iowa Women's Health Study (IWHS), ^55^ reported only CAD (not CVD) mortality. For the purposes of this review, the definition of CAD death was taken directly from the studies reviewed and most often included fatal MI and/or sudden cardiac death attributed to CAD.

Table 7. Coronary artery disease mortality and hormone replacement therapy

Study, year | N | Design | Hormone Type | Hormone Exposure Status | RR | 95% Confidence Intervals | Age | BP | DM | Family History | Chol | LDL/HDL | Smoking | BMI | Alcohol | Educ SES | Exercise | Other
Quality
Criqui, 1988 ^54^ | 1868 | Cohort | HRT | Ever | 0.99 | 0.59–1.67 | X | X | X | | X | | X | X | | X | | Glucose
Fair
Folsom, 1995 ^55^ | 41,000 | Cohort | HRT | Current | 0.82 | 0.47–1.43 | X | X | X | | | | | X | X | | X | Waist/hip, marital status
Good | | | | Past | 0.57 | 0.38–0.85
Grodstein, 1996 ^8^ | 3637 cases | Nested CC | HRT | Current | 0.47 | 0.32–0.69 | X | X | X | X | X | | X | X
Good | | | | Past | 0.99 | 0.75–1.30
Cauley, 1997 ^50^ | 9704 | Cohort | HRT | Current | 0.49 | 0.26–0.93 | X | X | X | | | | X | X | X | X | X | Surgical menopause, clinic, stroke, health
Good | | | | Past | 0.82 | 0.55–1.23
Sourander, 1998 ^51^ | 7944 | Cohort | HRT | Current | 0.19 | 0.05–0.77 | X | X | X | | | | X | X | | X | | CAD, CHF
Fair | | | | Past | 0.64 | 0.27–1.47

The two largest studies are the Nurse's Health Study and the IWHS, both from the United States. The IWHS ^55^ involved 41,070 Iowa women aged 55 to 69, who were evaluated at baseline using a mailed questionnaire and followed for coronary mortality for 6 years. Hormone use was characterized as “ever,” “never,” or “former,” and duration was evaluated. Overall coronary mortality was decreased significantly in former users, and decreased but not statistically significant among current users, with relative risks of 0.57 (95% CI 0.38–0.85) and 0.82 (95% CI 0.47–1.43), respectively. Women using HRT for 5 or fewer years also had reduced CAD mortality (RR 0.57), although this was not statistically significant. Use over 5 years was associated with a relative risk of 0.90 (95% CI 0.47–1.72).

The NHS published data in 1997 evaluating CAD mortality using nested case-control methodology. ^53^ The study evaluated 3,637 deaths among women in the cohort between 1976 and 1994. Each case was matched to 10 controls and after adjustment for most coronary disease risk factors, mortality was reduced among current users (RR 0.47; 95% CI 0.32–0.69) but not among past users (RR 0.99; 95% CI 0.75–1.30).

Coronary disease mortality was evaluated in 9,704 women above age 65 in the SOF study. ^50^ Among women in the cohort with current HRT use, the relative risk of CAD death was 0.49 (95% CI 0.26–0.93). Women using HRT from 1 to 9 years had no reduction in CAD mortality (RR 0.97), but women using HRT for 10 or more years had a significantly decreased rate of CAD death (RR 0.25; 95% CI 0.09–0.68). Notably, women currently using HRT had reduced all-cause mortality (RR 0.69; 95% CI 0.54–0.87), as did past HRT users (RR 0.79; 95% CI 0.66–0.95).

A cohort of 7,944 women ages 57 to 64 from Finland participating in a mammography study was followed for an average of 7 years for CAD death. ^51^ Among current HRT users, the relative risk of CAD mortality was 0.19 (95% CI 0.05–0.77). One difference between this study and others is that the mean dose of estrogen was 1.46 mg, higher than the usual doses found in other studies.

A cohort of 1,868 white, upper-middle-class women, ages 50 to 79, residing in a planned community in Southern California was followed for 12 years from 1972 on for CAD. ^54^ Among women using HRT, the CAD mortality was unchanged after multivariate adjustment for most CAD risk factors (RR 0.99; 95% CI 0.59–1.67).

Among the 3 studies evaluating CAD mortality by duration of HRT, ^50,^ ^54,^ ^55^ the findings are inconsistent (Table 8). The Criqui study ^54^ observed decreased risk of CAD among those using HRT for more than 8 years, with a relative risk of CAD mortality of 0.36 (95% CI 0.04–3.02). However, among women using HRT for fewer than 8 years, CAD mortality was increased, with relative risks ranging from 1.24 to 2.62, depending on the order of HRT use in the 8 years of follow-up (off then on, or on then off). Neither finding was statistically significant. Another study shows decreased risk for use of fewer than 5 years (RR 0.57), ^55^ and one shows no difference in risk (RR 0.97). ^50^ None of these findings was statistically significant. Two studies suggest decreased risk for very long-term use. In the SOF study, more than 10 years of HRT use was associated with a relative risk of 0.25 (95% CI 0.09–0.68). ^50^ Use for 8 or more years was also associated with decreased risk of CAD mortality in the Southern California cohort (RR 0.36), but was not statistically significant. The relative risk of CAD death was 0.90 and not significant in the IWHS among women using HRT longer than 5 years. ^55^

Table 8. Coronary heart disease mortality and hormone replacement therapy by duration

Study, year | Design | Duration (years) | RR | 95% Confidence Intervals
Criqui, 1988 ^54^ | Cohort | [underlined: <8 (on-off)¶] | 1.24 | 0.55–2.78
| | [underlined: 8 (off-on)¶¶] | 2.62 | 0.59–11.61
| | [underlined: >8] | 0.36 | 0.04–3.02
Folsom, 1995 ^55^ | Cohort | [underlined: <5] | 0.57 | 0.18–1.75
| | [underlined: >5] | 0.90 | 0.47–1.72
Cauley, 1997 ^50^ | Cohort | 1–9 | 0.97 | 0.46–2.05
| | >10 | 0.25 | 0.09–0.68

¶ On HRT at first evaluation, off at second

¶¶ Off HRT at first evaluation, on at second

Many of these studies differentiated past HRT use from current use (as opposed to “ever” use), as shown in Table 7. Among them, the SOF, Finnish, and NHS cohorts showed statistically reduced risk of CAD mortality with current HRT use (RR 0.19–0.49). The IWHS had a non-statistically significant relative risk of 0.82 for current use. For past use, the IWHS had a statistically significant relative risk of 0.57 (95% CI 0.38–0.85); the other 3 studies had relative risks ranging from 0.64 to 0.99, and were not statistically significant. ^50,^ ^51,^ ^54^ None of the fair or good quality studies evaluated CAD mortality by type of HRT used.

In our meta-analysis of HRT and CAD mortality (Table 6, Figure 4), current HRT use was associated with a summary relative risk of 0.62 (95% CI 0.40–0.91), ever use was associated with a summary relative risk of 0.81 (95% CI 0.37–1.60) and past use with a summary relative risk of 0.76 (95% CI 0.53–1.02). “Any use,” the global measure of use, had a summary relative risk of 0.74 (95% CI 0.36–1.45).

Figure 4. Coronary Artery Disease Mortality and Hormone Replacement Therapy

### Summary

- Five studies of good or fair quality evaluated CAD death among women using HRT. No studies evaluated CAD mortality by type or dose of HRT.
- Four of the 5 showed reduced risk of CAD death associated with current use of HRT, with relative risks ranging from 0.19 to 0.82, although only 3 were statistically significant.
- Past use was associated with relative risks ranging from 0.57 to 0.99, with only one result statistically significant.
- The 3 studies evaluating risk of CAD death by duration of use had inconsistent findings, with relative risks ranging from 0.57 to 2.62 for fewer than 5–10 years of use, and 0.25 to 0.90 for more than 5 to 10 years of use.
- Only current HRT use was associated with reduced CAD mortality in our meta-analysis; no association was shown with past, ever, or any use.

### 3. Does Postmenopausal HRT Alter the Risk of Stroke Death?

Eight cohort studies ^22,^ ^49–51,^ ^55–58^ of good or fair quality addressed the issue of HRT and stroke death (Table 9, see also Evidence Tables 3 and 4). Most of these studies found reduced relative risk point estimates, though none was statistically significant. The Rancho Bernardo study found no significant association between stroke death among current HRT users (RR 0.92; 95% CI 0.34–2.49). ^57^ The Finnish cohort ^51^ also found no significant risk of stroke death in former users (RR 1.05; 95% CI 0.41–2.68) or current users (RR 0.16; 95% CI 0.02–1.18). The SOF study ^50^ identified no significant risk of stroke death in current users (RR 0.47; 95% CI 0.20–1.08) or past users of HRT (RR 0.85; 95% CI 0.48–1.49). The IWHS ^55^ also found no significant association between HRT use and stroke death; the relative risk was 0.95 for current use (95% CI 0.37–2.43) and 0.88 for past use (95% CI 0.48–1.61). The NHANES I cohort study ^56^ identified a significant decreased risk of stroke death (RR 0.86; 95% CI 0.14–0.92) when proxy responses were included; when proxy responses were eliminated, however, there was no reduction in stroke death (RR 0.86; 95% CI 0.28–2.66). The NHS cohort identified no association between current HRT use and stroke mortality (RR 0.81; 95% CI 0.54–1.22). ^58^ Finally, the Lipid Research Clinics study ^22^ , a well-designed cohort study, found no significant association between HRT and stroke death (RR 0.40; 95% CI 0.01–3.07) after adjustment for many CVD risk factors. Although none of these studies adjusted for lipids or socioeconomic status (SES), variable adjustment for confounders does not seem to explain different findings among the studies (see Table 9).

Table 9. Stroke mortality and hormone replacement therapy

Study, year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI | Age | BP | DM | Family History | Chol | LDL/HDL | Smoking | BMI | Alcohol | Educ SES | Exercise | Other
Quality
Bush, 1987 ^22^ | 2270 | cohort | ERT | Ever | 0.4 | 0.01–3.07 | X | X | | | | X | X | X | | X
Good
Petitti, 1987 ^49^ | 16,638 | cohort | ERT | Ever | 0.6 | 0.2–2.2 | X | X | | | | | X | X | X | X | | Marital status
Fair
Finucane, 1993 ^56^ | 1910 | cohort | HRT | Ever | 0.86 | 0.28–2.66 | X | X | X | | | | X | X | | X
Good
Folsom, 1995 ^55^ | 41,070 | cohort | HRT | Current | 0.95 | 0.37–2.43 | X | X | X | | | | X | X | X | | X
Good | | | | Past | 0.88 | 0.48–1.61
Cauley, 1997 ^50^ | 9,704 | cohort | HRT | Current | 0.47 | 0.20–1.08 | X | X | X | | | | X | X | X | X | X | Surgical menopause, health status, clinic, stroke
Good | | | | Past | 0.85 | 0.48–1.49
| | | HRT | Current | all stroke 1.03 | 0.82–1.31
Grodstein, 2000 ^58^ | 70,533 | cohort | HRT | Current | 0.81 | 0.54–1.22 | X | X | X | X | X | | X | X
Good | | | ERT | Current | 0.81 | 0.49–1.34
| | | CHRT | Current | 1.22 | 0.65–2.28
Sourander, 1998 ^51^ | 7944 | cohort | HRT | Current | 0.16 | 0.02–1.18 | X | X | X | | | | X | X | | X | | CAD
Fair | | | | Past | 1.05 | 0.41–2.68 | | | | | | | | X | | X | | CHF
Fung, 1999 ^57^ | 1031 | cohort | HRT | Current | 0.92 | 0.34–2.49 | X | X | X | | | | X | | | X
Fair

Two good-quality cohort studies evaluated long-term use of estrogen and risk of stroke death (Table 10). The SOF study ^50^ identified no significant risk of stroke death for use for 10 or more years (RR 0.38; 95% CI 0.13–1.10), or for use from 1 to 9 years (RR 0.66; 95% CI 0.20–2.20). Similarly, after 6 years of followup, the IWHS, ^55^ identified no significant change in stroke death with HRT use of more than 5 years (RR 1.05; 95% CI 0.41–2.64) or 5 or fewer years (RR 2.08; 95% CI 0.74–5.82).

Table 10. Summary of stroke and hormone replacement therapy by duration

Study, year | Design Type | HRT Duration (years) | Outcome | RR/OR | 95% CI
Folsom, 1995 ^55^ | Cohort | ≤ 5 | Stroke mortality | 2.08 | 0.74–5.82
| | > 5 | | 1.05 | 0.41–2.64
Cauley, 1997 ^50^ | Cohort | 1–9 | Stroke mortality | 0.66 | 0.20–2.20
| | ≥10 | | 0.38 | 0.13–1.10
Petitti, 1998 ^71^ | CC | < 1 | Stroke incidence | 0.75 | 0.23–2.42
| | 1–4 | | 0.67 | 0.26–1.73
| | 5–9 | | 0.69 | 0.28–1.72
| | ≥10 | | 1.37 | 0.79–2.38
Grodstein, 2000 ^58^ | Cohort | < 1 | Stroke incidence | 1.32 | 0.76–2.32
| | 1–1.9 | | 1.04 | 0.55–1.97
| | 2–4.9 | | 1.14 | 0.86–1.52
| | 5–9.9 | | 1.05 | 0.79–1.38
| | ≥ 10 | | 1.17 | 0.91–1.49

We performed a meta-analysis of data from the 8 cohort studies that reported data on HRT and stroke mortality (Table 6, Figure 5). The summary relative risk for stroke death was 0.79 (95% CI 0.60–1.01). No differences were found for ever, past, or current use, and, therefore, only one summary relative risk is reported.

Figure 5. Stroke Mortality and Hormone Replacement Therapy

### Summary

- No significant association between HRT and risk of stroke death was identified in the observational studies of good to fair quality, although most point estimates showed reduced risk.
- Two good-quality cohort studies evaluated long-term use of estrogen and did not show any significant association between long-term HRT use and stroke death.
- Meta-analysis of 8 studies showed no significant association between HRT and stroke mortality.

## Cardiovascular Disease, Coronary Artery Disease and Stroke Incidence

### 4. What is the Role of Postmenopausal HRT in the Primary Prevention of Cardiovascular Disease?

Three observational studies of fair or good quality have evaluated the overall risk of CVD ^11,^ ^51,^ ^59^ (Table 11). The FHS ^11^ defined CVD broadly and included coronary heart disease (angina, MI, coronary death, sudden cardiac death), cerebrovascular disease (stroke and transient ischemic attack [TIA]), claudication, and congestive heart failure. After 8 years of followup, the total CVD rate was increased among HRT users by 76% (RR 1.76; p<0.01). CVD events in this study were ascertained by physician review of clinic notes, hospital and physician records, and death certificates on a biennial basis. This process is unique to this study and involved evaluating unrecognized MI with electrocardiograms and including angina and TIAs, each more difficult endpoints to define. In addition, the multivariate model used in this study included the cholesterol:HDL ratio, which also may have influenced the findings, since adding the HDL level to multivariable models has been shown to significantly change results towards less benefit from HRT. ^22^ The FHS also differs in its assessment of HRT use. In this study, nearly two-thirds of the cohort reported use of HRT at 2 or more of the biennial examinations, suggesting that the findings are most relevant to longer-term use of HRT. Interestingly, the authors reanalyzed their data, categorizing women as users or nonusers at the 11^th^ biennial exam, and repeated similar analyses. When estrogen use was characterized in this manner (at a single point in time), the findings suggested an inverse relation between HRT and CVD mortality in women ages 50–59. Also, when total CVD was evaluated in this way, there was no association between HRT and CVD in the youngest women, but a strong positive relation (increase in risk) among women over age 60. These findings indicate that how HRT use is measured or characterized can significantly affect the findings of a study.

Table 11. Cardiovascular disease incidence and hormone replacement therapy

Study (Year) | N | Design | Hormone Type | Hormone Exposure Status | RR | 95% Confidence Intervals | Age | BP | DM | Family History | Chol | LDL/HDL | Smoking | BMI | Alcohol | Educ SES | Exercise | Other
Quality
Wilson, 1985 ^11^ | 1234 | Cohort | HRT | Ever | 1.76 | P<.01 | X | X | | | X | X | X | X | X
Fair
Thompson, 1989 ^59^ | 603 | CC | HRT | Ever | 1.29 | 0.82–2.00 | X | X | X | X | | | X | | | | | Marital status, MI, stroke, DVT
Good | | | ERT | Ever | 1.09 | 0.65–1.82
| | | CHRT | Ever | 1.16 | 0.43–3.12
Hemminki, 1997 ^60^ | | Meta-analysis | HRT | Short-term | 1.39 | 0.48–3.95
Good
Sourander, 1998 ^51^ | 7944 | Cohort | HRT | Current | 1.07 | 0.86–1.32 | X | X | X | | | | X | X | | X | | Glucose
Fair | | | | Past | 1.11 | 0.89–1.39

A case-control study conducted in the United Kingdom evaluated CVD incidence and involved 603 women ages 45 to 69 with MI or stroke. ^59^ Two controls per case were matched by age, race, and general practitioner, and all were evaluated with a questionnaire completed by a nurse, as well as a review of all medical records. After adjustment for several important confounding variables (though not including lipids), the relative risk of CVD events was 1.29 (95% CI 0.82–2.00) for any HRT use, 1.09 (95% CI 0.65–1.82) for ERT use, and 1.16 (95% CI 0.43–3.12) for CHRT use. ^59^

In the Finnish cohort ^51^ described above, the relative risk of CVD events was 1.07 (95% CI 0.86–1.32) among current HRT users and 1.11 (95% CI 0.89–1.39) among past users.

A 1997 meta-analysis combined data from 22 randomized controlled trials of short-term HRT use for several outcomes other than CVD, such as bone density or lipids. ^60^ In these studies, cardiovascular events were reported as complications or side effects of therapy, not as primary outcomes of interest. Of approximately 1,700 women randomized to placebo or HRT (of varying composition), there were 12 cardiovascular events in the HRT group and 5 in the control subjects, with a relative risk of 1.39 (95% CI 0.48–3.95). The authors also calculated probabilities for finding this result if 0.7 or 0.5 was the true odds ratio, and these probabilities were 0.10 and 0.03, respectively. This suggests that it is highly unlikely that a short-term benefit of HRT was missed by chance alone in this study.

The WHI is a randomized controlled trial of hormone replacement therapy in the primary prevention of CVD involving 27,348 postmenopausal US women. The study began several years ago and was to report findings initially in the year 2005. However, in the spring of 2000, the data and safety monitoring board identified an increased rate of MI, stroke, and “blood clots” among the women randomized to hormone therapy (HRT or CHRT) occurring in the first 2 years of the study. To date, no information on the number of events is available, although the April 3, 2000 press release from the National Heart, Lung and Blood Institute (NHLBI) ^48^ stated that the number was less than 1% among women using HRT. The increased rates did not meet statistical criteria for stopping the trial. Over time, the trends may diminish and, as the press release states, “may even go away.” This information was considered preliminary and did not address the issue of long-term benefits. Therefore, the authors did not recommend that the findings influence current medical practice.

We performed a meta-analysis of the studies of HRT and CVD incidence (Table 6, Figure 6), and found summary relative risk estimates of 1.35 (95% CI 0.92–2.00) for ever use and 1.26 (95% CI 0.79–2.08) for past use. Current use of HRT was associated with a summary relative risk of 1.27 (95% CI 0.80–2.00). Any use of HRT, the overall measure of use, was associated with a summary relative risk of 1.28 (95% CI 0.86–2.00).

Figure 6. Cardiovascular Disease Incidence and Hormone Replacement Therapy

### Summary

- All observational studies evaluating CVD incidence, which includes stroke and coronary disease, show elevated relative risks among women using HRT on the order of 10% to 75%. In only one study, however, was this finding statistically significant, and this study has been criticized for including “angina” as a CVD outcome.
- An important analysis of the FHS showed that how HRT use is assessed and defined can significantly influence calculated rates of CVD events.
- None of the studies evaluating CVD incidence and HRT evaluated risk by duration of HRT use.
- Meta-analysis involving evaluation of only women involved in randomized controlled trials of relatively short-term HRT suggests increased risk of CVD events among women randomized to HRT.
- Preliminary findings from the large Women's Health Initiative randomized controlled trial of HRT and primary prevention released to the public in the spring of 2000 indicate increased rates of stroke, MI, and “blood clots” among women using HRT within the first 2 years of the study. These rates have diminished with increased followup.
- In our meta-analysis, all measures of HRT use were associated with increased risk of CVD events, with relative risks ranging from 1.26 to 1.35.

### 5. What is the Role of Postmenopausal HRT in the Primary Prevention of Coronary Artery Disease?

Evaluating CAD events is difficult, and each study has used different methods to determine or identify events, as well as different definitions of CAD. For this review, we classified all MIs as coronary events, recognizing that many occur outside the hospital and are not included in this category. This is especially a problem in case-control studies that evaluate the relationship, since most define their cases as women hospitalized with MI while others include only non-fatal MI as cases. As discussed above, some investigators included outcomes of angina and sudden cardiac death in their overall definition of CAD. Typically, if sudden cardiac death was considered in the measurement of CAD, the investigators did so after excluding other causes. Finally, the FHS ^11^ included clinically unrecognized MI in its definition of CAD, which is important because approximately one-third of MIs in women are clinically unrecognized or “silent.” The data from the studies evaluating CAD incidence and HRT are displayed in Table 12.

Table 12. Coronary disease incidence and hormone replacement therapy

Study, year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI | Age | BP | DM | Family History | Chol. | LDL/HDL | Smoking | BMI | Alcohol | Educ. SES | Exercise | Other
Pfeffer, 1978 ^64^ | 274 | CC | HRT | Ever | 0.86 | 0.54–1.37 | X | X
| | | HRT | Current | 0.68 | 0.32–1.42 | X | X
Nachtigall, 1979 ^61^ | 168 | RCT | CHRT | 10 years | 0.33 | NS | X
Wilson, 1985 ^11^ | 1234 | Cohort | HRT | Ever | 1.9 | P<.01 | X | X | | | X | X | X | X | X
Croft, 1989 ^65^ | 158 | CC | HRT | Ever | 0.8 | 0.3–1.8 | X | | | | | | X | | | X | | OCP use, hysterectomy
| | | | | | | X
Beard, 1989 ^66^ | 133 | CC | HRT | Ever | 0.55 | 0.24–1.30 | X | X | X | | | | X | | | | | Menopausal status,type,year
Hernandez-Avila, 1990 ^62^ | 120 | Nested case control from cohort study | HRT | Current | 0.7 | 0.4–1.4 | X | X | X | | | | | | | | | Drug treated anti-arhythmic therapy
Rosenberg, 1993 ^67^ | 858 | CC | ERT | Ever | 0.9 | 0.7–1.2 | X | X | X | | X | | X | X | X | X | X | Coffee, angina, MI<60, age/type menopause, physician visits
| | | CHRT | Ever | 1.2 | 0.6–2.4 | X | X | X | | X | | X | X | X | X | X
| | | ERT | Past | 0.9 | 0.7–1.3 | X | X | X | | X | | X | X | X | X | X
| | | ERT | Recent | 0.8 | 0.4–1.3 | X | X | X | | X | | X | X | X | X | X
Mann, 1994 ^68^ | 1521 | CC | HRT | Recent | 0.83 | 0.66–1.03 | X | X | X | | X | | | | | | | Hysterectomy, surgical menopause
| | | CHRT | | 0.68 | 0.47–0.97 | X | X | X | | X
| | | ERT | | 0.93 | 0.47–1.86 | X | X | X | | X
Grodstein, 1996 ^8^ | 59,337 | Cohort | ERT | Current | 0.6 | 0.43–0.83 | X | X | X | X | X | | X | X | | | | OCP use, parity, menarche
| | | CHRT | Current | 0.39 | 0.19–0.78 | X | X | X | X | X | | X | X
| | | HRT | Current | 0.6 | 0.47–0.76 | X | X | X | X | X | | X | X
| | | HRT | Past | 0.85 | 0.71–1.01 | X | X | X | X | X | | X | X
Heckbert, 1997 ^69^ | 850 | CC | HRT | Ever | 0.72 | 0.59–0.88 | X | | X | | | | X | | | | | Year, angina
| | | HRT | Current | 0.7 | 0.55–0.89 | X | | X | | | | X
| | | HRT | Past | 0.74 | 0.57–0.96 | X | | X | | | | X
Sidney, 1997 ^12^ | 438 | CC | HRT | Current | 0.96 | 0.66–1.40 | X | X | X | | | | X | | X | X | X | HO, CAD, race, facility
| | | HRT | Past | 1.07 | 0.72–1.58 | X | X | X | | | | X | | X | X | X
Sourander, 1998 ^51^ | 7944 | Cohort | HRT | Current | 1.05 | 0.76–1.46 | X | X | X | | | | X | | | X | X
| | | | Past | 1.21 | 0.88–1.71 | X | X | X | | | | X | | | X | X
Eaker¶ | 1234 | Cohort | HRT | Ever | 50–59:0.4 | P>0.05 | X | X | X | | X | X | X | X | | | X | CAD, CHF
| | | | | 60–69:2.2 | P>0.05 | X | X | X | | X | X | X | X | | | X

¶ Reanalysis of Framingham data excluding angina adapted by Stampfer (Stampfer 19919)

The only published randomized controlled trial of the primary prevention of CAD with HRT was conducted among 168 postmenopausal women institutionalized in New York City and followed for 10 years while in the hospital. ^61^ After 10 years, there were 3 MIs in the control group treated with placebo, and 1 MI in the CHRT treated group (RR 0.33; 95% CI non-significant). This study contributes little to this evaluation however, because of its small size and unique population, and because the dose of estrogen used (2.5 mg) is rarely used in clinical practice.

The association between HRT and CAD incidence was evaluated in 4 cohort studies (1 analyzed as a nested case-control study) of good or fair quality. ^8,^ ^11,^ ^51,^ ^62^ The FHS identified a relative risk of 1.90 (p<0.01) for CAD events associated with HRT use. ^11^ When this study was reanalyzed by Eaker, ^63^ excluding the endpoint of angina, the relative risk among women reporting HRT use at exams 11 or 12 was 0.40 (p > 0.05) among women ages 50 to 59. ^10^ Among women ages 60 to 69, the relative risk of those reporting HRT use at exam 11 or 12 was 2.20 (p > 0.05). ^10,^ ^63^ It can be argued that angina is such a poorly defined or difficult-to-define entity, particularly among women, that it is appropriate to exclude angina from the relative risk calculations for CAD. However, the FHS was a very carefully conducted study. Also, it is difficult to know how to interpret or compare the relative risk findings of the studies by Eaker and Wilson without an overall estimate involving the entire cohort, since the number of CAD events would have been larger in the older women in whom the relative risk was elevated. In addition, women in the FHS tended to use higher doses of estrogen. ^9^

The Finnish cohort study ^51^ identified elevated relative risks of CAD associated with current and past HRT use, although these were not statistically significant. Among current users of HRT, the risk of CAD was 1.05 (95% CI 0.76–1.46). Past users had a relative risk of 1.23 (95% CI 0.88–1.71). Women in this study also used higher doses of estrogen.

The NHS ^8^ reported a relative risk of CAD of 0.60 (95% CI 0.47–0.76) among women currently using HRT and a relative risk among past users of 0.85 (95% CI 0.71–1.01). These data were also analyzed by type of HRT use. Among current users of CHRT, the relative risk of CAD was 0.39 (95% CI 0.19–0.78); women currently using ERT had a relative risk of 0.60 (95% CI 0.43–0.83), suggesting reduced risk with both types of HRT, consistent with the overall risk identified.

A cohort study involving women ages 50 to 64 from the GroupHealth Cooperative in Seattle, who were identified between 1978 and 1984, included a nested case-control analysis among 120 women with first MI. ^62^ After adjustment for drug treatment of hypertension and diabetes, as well as age, the relative risk for current HRT use was 0.70 (95% CI 0.40–1.40) and for past use was 0.60 (95% CI 0.10–2.10). These results should be interpreted cautiously because they are not statistically significant and adjustment for confounding by CAD risk factors was limited.

Among the 8 case-control studies evaluating CAD incidence that were of fair or good quality, ^12,^ ^62,^ ^64–69^ 2 of good quality investigated the relationship between HRT and incident coronary disease. ^12,^ ^67^ The best of these studies was a population-based study conducted by Rosenberg and involved 858 cases with first, non-fatal MI. ^67^ Each case was geographically and age matched (within 5 years) to one control. Estrogen use was considered present with any use more than one month in duration, and its use, as well as CAD risk factors, was evaluated by questionnaire. The odds ratio for ever use of ERT was 0.90 (95% CI 0.70–1.20) and for CHRT was 1.2 (95% CI 0.60–2.40). Overall, recent use of any HRT was associated with a non-statistically significant decrease in first MI of 20%. Past use was associated with an odds ratio of 0.9 (95% CI 0.7–1.3). All relative confounders were included in the analyses except for the cholesterol: HDL ratio, which has been identified as an important explanatory variable in multivariate models. ^4,^ ^22^ When ERT use was evaluated by duration, relative risks were elevated in the first 4 years of use, and after 4 years were below 1.0 with positive trend (p =0.08) for reduced risk of first MI with increasing ERT duration, though none of the strata of years was statistically significant. CHRT use of 5 or fewer years was associated with an odds ratio of 0.50 (95% CI 0.20–1.50) and more than 5 years with an odds ratio of 2.60 (95% CI 0.80–8.40). It is important to note that this study evaluated only survivors of first MI.

Another good-quality population-based case-control study ^12^ was conducted in a Northern California HMO population and involved 438 postmenopausal women with first MI. An equal number of controls were matched by age and medical center. Medical records were reviewed for estrogen exposure, and some major risk factors for CAD were identified and adjusted for (family history, lipids, and BMI were not adjusted for). The adjusted odds ratio for current ERT or CHRT use was 0.96 (95% CI 0.66–1.40) and for past use was 1.07 (0.72–1.58). For CHRT, there was an increased, though non-statistically significant, risk in the first year of use (OR 1.27; 95% CI 0.40–4.02). There was no trend associated with increasing duration of either CHRT or ERT.

Only one case-control study evaluating CAD incidence showed statistically significant reduced risk of CAD among HRT users. ^69^ This study was conducted in the Seattle GroupHealth Cooperative and involved 850 postmenopausal women ages 30 to 79 with incident fatal or non-fatal MI. Controls were frequency matched, and record review, pharmacy review, and telephone interviews were conducted to measure exposure and CAD risk factors. The odds ratios for ever use, current use, and past use of HRT were 0.72 (95% CI 0.59–0.88), 0.70 (95% CI 0.55–0.89), and 0.74 (95% CI 0.57–0.96), respectively. This study had relatively little adjustment for CAD risk factors, however.

Four other population-based case-control studies of fair quality identified odds ratios ranging from 0.55 to 0.93 for current, recent, or ever use of HRT, though none was statistically significant. ^62,^ ^65,^ ^66,^ ^68^

Past use of HRT was evaluated in 6 studies of CAD incidence. The risks were elevated in 2 studies (RR 1.07–1.23), ^12,^ ^51^ but were not statistically significant. The risks were reduced in 3 studies (RR 0.60–0.90), ^8,^ ^62,^ ^67^ but again were not statistically significant. The GroupHealth Study ^69^ did show significantly reduced risk with past use (OR 0.74; 95% CI 0.57–0.96), though it is limited by lack of adjustment for many CAD risk factors.

The use of combined therapy (CHRT) was evaluated in 3 observational studies. In the NHS, ^8^ the relative risk of current CHRT use was 0.39 (95% CI 0.19–0.78). In the Rosenberg case-control study, ^67^ ever use of CHRT was associated with an odds ratio of 1.2 (95% CI 0.60–2.4). Finally, in the UK study, ^59^ recent CHRT use was associated with an odds ratio of 0.68 (95% 0.47–0.97).

Although review of Table 10 indicates that many studies had point estimates below 1.0, suggesting benefit, only 3 of these were statistically significant. The most notable finding is that, with the exception of the NHS, ^11^ the good quality studies were consistent in showing no benefit or an increased risk of CAD events among HRT users. The reason(s) for disparity among the best studies is uncertain. There were great differences among the studies in their adjustment for confounders. What is striking in reviewing the table however, is that none of the studies that included adjustment for SES or education in their models found HRT use beneficial. This is an important finding and suggests that SES may confound the relationship between HRT and CAD incidence. Similarly, none of the studies with adjustment for alcohol use or exercise, both known to be more common in women who use HRT and to be protective against CAD, showed benefit with HRT use. As Tables 1 and 2 indicate, all studies included in this systematic review assessed and defined HRT use differently. As Wilson very effectively showed, ^11^ how this is done can significantly influence relative risk estimates. Unfortunately, however, no clear pattern emerges from Tables 1 and 2 that helps further explain disparate findings among studies evaluating CAD incidence.

Results of our meta-analysis evaluating the association between CAD incidence and HRT use varied by exposure status (Table 6, Figure 7). Current use of HRT was associated with a summary relative risk of 0.80 (95% CI 0.68–0.95). Ever use of HRT was associated with a relative risk of 0.91 (95% CI 0.67–1.33), and past use with a summary relative risk of 0.87 (95% CI 0.75–1.05). We also conducted the meta-analyses and compared the summary relative risks among the studies that adjusted for SES and those that did not adjust. Among the studies that adjusted for SES, there was no association between any measure of HRT use and CAD events, with relative risks ranging from 0.98–1.07. However, the summary relative risks among studies that did not adjust for SES were reduced with current exposure (RR 0.72; 95% CI 0.61–0.84) and past exposure (RR 0.77; 95% CI 0.65–0.91). This finding suggests that SES status may significantly confound observations of reduced CAD among women using HRT. This is a very important issue as SES is powerfully and inversely linked with CVD. ^70^ Our finding of no association between any measure of HRT use and coronary incidence was similar when the meta-analyses were stratified by alcohol consumption and exercise, in addition to other major coronary disease risk factors, suggesting confounding by these factors as well.

Figure 7. Coronary Artery Disease Incidence and Hormone Replacement Therapy

### Summary

- Among 3 cohort studies of good or fair quality, 2 suggest increased risk of CAD in association with HRT, although only the FHS findings were statistically significant (RR 1.05–1.90). Reanalysis of FHS data without angina as an endpoint showed a trend towards reduced risk among women aged 50 to 59 (RR 0.40) and increased risk among women aged 60–69 (RR 2.20). The NHS showed reduced risk among current users of any type of hormone therapy.
- Eight case-control studies (1 nested case control study) evaluated HRT use and CAD incidence. Among them only one showed statistically significant reduced risk of approximately 30% with HRT use. ^11,^ ^51,^ ^56–58,^ ^69^ The two best studies suggested elevated risks (RR 0.96–1.20) among women using HRT, but the findings were not statistically significant. The others showed relative risks ranging from 0.55 to 0.93 and were not statistically significant.
- The findings among the 6 studies evaluating past use of HRT were inconsistent, showing both increased and decreased risks.
- With the exception of the NHS, none of the good quality studies showed reduced coronary events among women using HRT.
- None of the studies including adjustment for SES, education, exercise, or alcohol use in their models showed a benefit of HRT in reducing CAD events.
- Two of 3 observational studies evaluating CHRT use showed statistically significant reduced risk among current, recent, or ever users.
- In our meta-analysis, there was no association between HRT use and CAD events in studies that adjusted for SES, but summary relative risks for studies that did not adjust for SES were reduced. These results suggest that SES may significantly confound observations of reduced CAD among women using HRT.

### 6. Does Postmenopausal HRT Alter the Risk of Stroke?

#### 6a. Total stroke

Among the 24 cohort studies reviewed (representing 15 cohorts), 5 cohort studies ^11,^ ^51,^ ^56–58^ and 4 case-control studies ^59,^ ^64,^ ^71,^ ^72^ of good or fair quality were analyzed in depth (Table 13a, Evidence Table 3 and 4).

Table 13a. Summary of total stroke incidence and hormone replacement therapy

Study, Year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI | Age | BP | DM | Family History | Cholesterol | LDL/HDL | Smoking | BMI | Alcohol | Education SES | Exercise | Other
Quality
Pfeffer 1978 ^64^ | 258 cases | CC | HRT | Ever | 0.97 | 0.65–1.44 | X | X | X
Fair | | | | | TIA 2.79 | 0.67–11.62
Wilson 1985 ^11^ | 1234 | cohort | HRT | Ever | 2.27 | p<0.01 | X | X | | | X | X | X | X | X
Good
Thompson 1989 ^59^ | 244 cases | CC | HRT | Ever | 1.2 | p>0.02 | X | X | X | X | X | | | | | | | Marital status, clot, stroke, MI
Good
Finucane 1993 ^56^ | 1910 | cohort | HRT | Ever | 0.82 | 0.46–1.47 | X | X | X | | | | X | X | | X | | MI
Good
Grodstein 2000 ^58^ | 70,533 | cohort | ERT | Current | 1.24 | 0.95–1.46 | X | X | X | X | X | X | X | X | X | | | OCP use, parity, menarche
Good | | | CHRT | Current | 1.54 | 1.12–2.11
| | | HRT | Current | 1.13 | 0.94–1.35
| | | | Past | 1.02 | 0.85–1.24
Pedersen 1997 ^72^ | 1422 cases | CC | ERT | Current | 1.24 | 0.91–1.70 | X | X | X | | | | X | X | | X | X | CAD, CHF
Good | | | | Past | 1.12 | 0.88–1.42
| | | CHRT | Current | 1.27 | 1.00–1.62
| | | ERT | Current | TIA 2.13 | 1.41–3.22
| | | | Past | TIA 1.83 | 1.33–2.51
| | | CHRT | Current | TIA 1.20 | 0.81–1.76
Petitti 1998 ^71^ | 349 cases | CC | HRT | Current | 1.03 | 0.65–1.65 | X | X | X | | | | X | X | | X | | Stroke
Fair | | | | Past | 0.84 | 0.54–1.32
Sourander 1998 ^51^ | 7944 | cohort | HRT | Current | 0.86 | 0.42–1.75 | X | X | X | | | | X | X | | X | | CAD, CHF
Fair | | | | Past | 1.08 | 0.55–2.10
Fung, 1999 ^57^ | 1031 | cohort | HRT | Ever | stroke/TIA | 0.83–23.58 | X | X | X | | | | X | X | | X
Fair | | | | | 4.43

TIA - Transient Ischemic Attack

Four of the 5 cohort studies found no association between stroke and postmenopausal estrogen. ^51,^ ^56–58^ Only the FHS ^11^ found an increase in stroke rates in women using HRT.

The Rancho Bernado cohort ^57^ consisted primarily of white, middle- to upper-class women from California, aged 60 or older, with no history of stroke. In this study 1,031 women, of which 278 (27%) were current HRT users, were followed for approximately 8.75 years. After controlling for age, smoking, systolic blood pressure and diabetes, no significant association between stroke or TIA and HRT use was identified (RR 4.43; 95% CI 0.83–23.58).

A population-based study included 7,944 women ages 57 to 64 from Finland participating in mammography screening in 1987 to 1988 who were followed every 2 years for stroke. ^51^ After approximately 6 years of followup, there was no significant association ^11,^ ^51,^ ^56–58^ between non-fatal stroke and the use of HRT, with a relative risk of 0.86 (95% CI 0.42–1.75) in current users and 1.08 (95% CI 0.55–2.10) in former users.

A cohort of 1,910 women without a history of stroke, ages 55–74, was evaluated in the NHANES I followup study from 1971 to 1975. ^56^ No significant decrease in risk of non-fatal stroke (RR 0.69; 95% CI 0.47–1.00) was identified. Although most major confounders were adjusted for, family history of CVD and lipids were not.

The NHS evaluated stroke incidence after 20 years of followup. ^58^ Non-fatal strokes were verified by medical record review, and required typical neurological symptoms of stroke lasting more than 24 hours and meeting the criteria of the National Survey of Stroke. Strokes were classified into ischemic stroke (IS), (thrombotic or embolic), SAH, and intraparenchymal hemorrhage (IPH). Deaths were verified by family, medical, and autopsy records, and by the National Death Index. No association between the risk of total stroke and current (RR 1.13; 95% CI 0.94–1.35) or past (RR 1.02; 95% CI 0.85–1.24) use of HRT was shown; ^58^ however, an increased risk of total stroke (RR 1.54; 95% CI 1.12–2.11) was observed in women currently using CHRT. No association was identified in women taking 0.625 mg of oral CEE compared to non-users (RR 1.24; 95% CI 0.95–1.62). This good-quality study adjusted for major confounders, including age, smoking, cholesterol, history of hypertension and myocardial infarction, diabetes, lipids, alcohol use, BMI, and family history of cardiovascular disease (see Table 13a). In addition, a significant dose-response relationship was shown for stroke with graded risks of 0.54, 1.35, and 1.63 for conjugated estrogen doses of 0.3 mg, 0.625 mg and 1.25 mg or more per day. ^58^

The FHS found a significant increase in stroke rates among women using HRT. ^11^ On average, women took estrogen for approximately 3 years, and primarily used CEE; fewer than 5% used CHRT. After 8 years of followup, 45 cases of fatal and non-fatal cerebrovascular disease events (total stroke), including 21 cases of atherothrombotic brain infarction had occured. Women taking HRT had greater than a 2-fold risk of total stroke (RR 2.27, p<0.01). A limitation of this study is that diabetes, a known major risk factor for stroke, was not assessed or adjusted for.

Four case-control studies have evaluated the association between short-term estrogen use and risk of stroke. ^59,^ ^64,^ ^71,^ ^72^ Though several have elevated point estimates, none of the studies has shown a significantly increased risk of stroke. All the studies were of fair quality, limited primarily by lack of control for confounding factors (refer to Evidence Table 4).

The results of the studies evaluating stroke incidence are relatively consistent in showing elevated, though non-statistically significant, relative risks of stroke in association with HRT. The major outlier is the FHS, which found significantly increased rates of stroke and brain infarction among women using HRT. The reason for the disparity between the FHS and other studies is not clear. However, since most women in the FHS were on estrogen alone, this result is consistent with the increase in risk of ischemic stroke shown among women using estrogen alone in the NHS (discussed below). ^58^ Because event ascertainment in the FHS was similar among women using and not using HRT, differential ascertainment is unlikely to explain the results. Two other issues with the FHS should be considered. These include the use of higher doses of estrogen among women in the study, ^9^ and the lack of adjustment for diabetes in their analysis, an important stroke risk factor. However, the FHS evaluated risk profiles among women using HRT, and these women were at lower CVD risk than women not using HRT based on traditional risk factors. Thus, the data somewhat compellingly suggest increased stroke risk among HRT users.

Long-term use of HRT has not clearly been defined. Many of the cohort studies do not address duration of use, and among those that do, the definition of “long-term” often varies from a few months to more than 15 years. Also, duration of use has been evaluated in past users by time since last use as well as time since the first use. The NHS ^58^ evaluated the effect of long-term use of HRT on the risk of stroke, and it showed no association, with relative risks ranging from 1.04 to 1.32 for less than one year to 10 or more years of use (see Table 10).

Of the 4 case-control studies reviewed, only one study of fair quality, the Northern California Kaiser Permanente study, ^71^ addressed the duration of estrogen use and risk of stroke. This study identified no significant association between stroke and HRT use by duration. HRT use of less than one year had an odds ratio of 0.75 (95% CI 0.23–2.42); for use of more than 10 years, the odds ratio of stroke was 1.37 (95% CI 0.79–2.38). There was also no association between HRT and stroke with past use (OR 0.84; 95% CI 0.54–1.32).

Evaluating exposure from estrogen and progesterone therapy is difficult. Most studies that include combination therapy rarely present these data independently. Often they report that a certain percentage of women was on combination therapy, but do not differentiate further. The majority of studies had fewer than 20% of subjects on combination therapy. The NHS evaluated the risk of stroke and CHRT use in 70,533 women. ^58^ A significant increase in total stroke (RR 1.54; 95% CI 1.12–2.11) was identified in association with CHRT. Two case-control studies evaluated CHRT and stroke risk. The first study ^72^ (previously discussed in detail) involved a cohort of 1,422 Danish women. Among women on CHRT, odds ratios of stroke ranged from 1.20 to 1.30 for various types of stroke (SAH, ICH, thromboembolic stroke, TIA), and none were significant. A study from the UK ^59^ found no increase in stroke in women on CHRT (OR 0.86; 95% CI 0.43–1.74) (see Evidence Table 4.)

Although there are no randomized trials of HRT and the primary prevention of stroke, the WHI is a CVD primary prevention trial involving 27,348 postmenopausal women randomized to either CHRT, ERT, or placebo. In the spring of 2000, women in the trial were notified that there were increased rates of stroke occurring among women randomized to HRT. ^48^

For the reasons discussed above and because there are no randomized controlled trials of HRT for the primary prevention of stroke, valuable information may come from the HERS trial, a secondary prevention study involving 2,763 women with known CAD randomized to either placebo (n=1383) or Prempro (CEE 0.625 mg and medroxyprogesterone acetate 2.5 mg) (n=1380). Stroke and TIA were secondary cardiovascular outcomes. Details of stroke diagnosis and classification were not reported. After 4 years of followup, 108 strokes or TIAs had occurred in the CHRT group, and the risk hazard was 1.13 (95% CI 0.85–1.48).

In our meta-analysis of total stroke incidence and HRT (Table 6, Figure 8), 5 cohort studies ^11,^ ^51,^ ^56–58^ and 4 case-control studies ^59,^ ^64,^ ^71,^ ^72^ were included in the analysis. The summary relative risk was 1.12 (95% CI 1.01–1.23), identifying a slightly significant increase in stroke incidence, consistent with the early results from the WHI.

Figure 8. Stroke Incidence and Hormone Replacement Therapy

### Summary

- One meta-analysis showed no association between HRT and stroke.
- Twenty-five cohort studies representing 15 cohorts have evaluated the use of HRT. Five of these were of fair or good quality, and 4 of the 5 found no association between stroke HRT use.
- Of the 4 good to fair case-control studies, none showed a significant association between HRT and stroke, though several had elevated point estimates.
- Although no randomized trials have evaluated HRT and primary prevention of stroke, preliminary findings of the Women's Health Initiative, as reported by the lay press, found an increased risk of stroke in women treated with HRT.
- The NHS found no association with long-term use of HRT and stroke incidence. One fair-quality case-control study evaluated the effect of long-term use of HRT on the risk of stroke, and found no significant association.
- The majority of the studies do not analyze risk associated with CHRT independently. The NHS found an increased risk of stroke in current users of CHRT compared to never-users, but no increased risk in women on ERT compared to never-users. Other studies to date have not found a significant association between stroke and CHRT, though some have suggested increased risk. The HERS trial of secondary prevention identified no increase risk of stroke or TIA in association with CHRT. However, this was a secondary prevention trial and may not be generalizable to a healthy population.
- Data from the NHS found an increasing risk of stroke with increasing doses of estrogen.
- Our meta-analysis identified a significant increased risk of stroke associated with ever use of HRT (RR 1.12; 95% CI 1.01–1.23).

#### 6b. Ischemic stroke

Ischemic, or thromboembolic, strokes are the most common type of stroke. HRT is a known thromboembolic agent and thus may be important etiologically in ischemic stroke. The majority of studies report their results as total stroke, and epidemiologically, ischemic stroke is the major contributor to total stroke. However, 4 studies of good or fair quality specifically report ischemic stroke separately. ^11,^ ^58,^ ^64,^ ^72^ (Table 13b, Evidence Tables 3 and 4)

Table 13b. Summary of ischemic stroke incidence and hormone replacement therapy

Study, Year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI | Age | BP | DM | Family History | Cholesterol | LDL/HDL | Smoking | BMI | Alcohol | Educ SES | Exercise | Other
Quality
Pfeffer 1978 ^64^ | 258 cases | CC | HRT | Ever | NES 1.13 | 0.71–1.77 | X | X | X
Fair | | | | | ES 0.49 | 0.00–5.38
Wilson 1985 ^11^ | 1234 | cohort | HRT | Ever | 2.6 | p<0.01 | X | X | | | X | X | X | X | X
Good
Grodstein 2000 ^58^ | 70,533 | cohort | HRT | Current | 1.26 | 1.00–1.61 | X | X | X | X | X | X | X | X | X | | | OCP use, parity, menarche
Good | | | HRT | Past | 1.01 | 0.79–1.30
Pedersen 1997 ^72^ | 1422 cases | CC | ERT | Current | 1.24 | 0.91–1.70 | X | X | X | | | | X | X | | X | X | CAD, CHF
Good | | | | Past | 1.12 | 0.88–1.42
| | | CHRT | Current | 1.27 | 1.00–1.62

Ischemic Stroke includes: nonembolic and embolic stroke (NES/ES), thromboembolic stroke and atherothrombotic stroke

Two cohort studies specifically evaluate ischemic stroke in their analyses. ^11,^ ^58^ The FHS, discussed previously, found that women with ever-use of HRT had an increased risk of ischemic stroke (RR 2.60; p<0.01). ^11^ The NHS ^58^ found that women who currently use HRT had an increased risk of ischemic stroke (RR 1.26; 95% CI 1.00–1.61); past use of HRT was not associated with ischemic stroke (RR 1.01; 95% CI 0.79–1.30). ^58^

Two case-control studies have evaluated the risk of ischemic stroke. ^64,^ ^72^ An older study of primarily white women from a Southern California retirement community found no significant increase in risk (OR 1.13; 95% CI 0.71–1.77) associated with ever use. ^64^ In the Denmark study, ^72^ previously described, there was no significant increased risk of ischemic stroke among current (OR 1.24 95% CI 0.91–1.70) or past ERT users (OR 1.12 95% CI 0.88–1.42), or current CHRT users (OR 1.27 95% CI 1.00–1.62), though all had elevated point estimates suggesting increased risk.

In our meta-analysis (Figure 9), the results of these 4 studies ^11,^ ^58,^ ^64,^ ^72^ were pooled to estimate risk of ischemic stroke. Because there were no apparent differences between study type, type of hormone use, or ever-use, past use or current use, these results were pooled. The summary relative risk was 1.20 (95% CI 1.05–1.40), indicating a significant increased risk of ischemic stroke in women with HRT exposure.

Figure 9. Atherothrombotic Brain Infarction Incidence and Hormone Replacement Therapy

### Summary

- The NHS and FHS identified statistically significant increased risk of ischemic stroke.
- 2 case-control studies of fair to good quality evaluated the risk of ischemic stroke and found no association.
- Our meta-analysis of these studies found increased risk of ischemic stroke with HRT use (RR 1.20; 95% CI 1.05–1.40).

#### 6c. Subarachnoid hemorrhage

Risk factors for SAH are different from those of ischemic and hemorrhagic stroke. In a systematic review of risk factors for SAH, the significant risk factors included smoking, hypertension, and drinking 150 grams or more of alcohol per week. ^73^ Use of oral contraceptives, use of HRT, hypercholesterolemia, and physical activity were not shown to be significantly related to the risk of SAH. With this in mind, only a few studies have evaluated the association between HRT and SAH independently. These studies are summarized in Table 13c and Evidence Table 3 and 4.

Table 13c. Subarachnoid hemorrhage and hormone replacement therapy

Study, Year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI
Quality
Longstreth 1994 ^74^ | 103 cases | CC | HRT | Ever | 0.47 | 0.26–0.86
Fair | | | | Current | 0.38 | 0.17–0.84
| | | | Past | 0.58 | 0.28–1.21
Grodstein 1999 ^69^ | 59,337 | cohort | ERT | Current | 1.35 | nr
Good | | | HRT | Current | 0.90 | 0.57–1.41
| | | HRT | Past | 0.81 | 0.52–1.25
Pedersen 1997 ^72^ | 1422 cases | CC | ERT | Current | 0.53 | 0.23–1.25
Good | | | ERT | Past | 0.78 | 0.46–1.30
| | | CHRT | Current | 1.30 | 0.84–2.02

nr - not reported

Of the 10 observational studies of fair or good quality that evaluated stroke, only one cohort study specifically evaluated SAH. ^8^ After 16 years of followup in the NHS, no clear association between SAH and current (RR 0.90; 95% CI 0.57–1.41) or past (RR 0.81; 95% CI 0.52–1.25) use of HRT was identified. ^8^ There was an increased risk of SAH observed in subjects using ERT only (RR 1.35), but no confidence interval or p-value was reported.

Only two case-control studies ^72,^ ^74^ of fair quality evaluated the relationship between HRT and SAH (see Table 13c and Evidence Table 4). One population-based case-control study from Denmark ^72^ included 1,422 women aged 45 to 64 who had a first-ever, non-fatal stroke between 1990 and 1992. Cases were identified from the Danish National Patient Register. Randomly selected from the Central National Person Register were 3,171 age-matched controls. There was no significant association between SAH and current use of ERT (OR 0.53; 95% CI 0.23–1.25), current use of CHRT (RR 1.30; 95% CI 0.84–2.02), or former use of HRT (RR 0.78; 95% CI 0.46–1.30).

The other study ^74^ was a population-based case-control study from King County, Washington. This study included 103 women with spontaneous SAH invited into the study by a treating physician in the King County area. There were 206 age- and sex-matched controls identified through random-digit dialing. A significant decrease in risk of SAH in women who ever (RR 0.47; 95% CI 0.26–0.86) or currently (RR 0.38; 95% CI 0.17–0.84) used HRT in comparison to never-users was identified. No association was found with former use of HRT and SAH (RR 0.58; 95% CI 0.28–1.21).

In our meta-analysis, these 3 studies ^8,^ ^72,^ ^74^ were pooled to estimate the risk of SAH associated with HRT use (Figure 10). No association was identified, with a summary relative risk of 0.80 (95% CI 0.57–1.05).

Figure 10. Subarachnoid Hemorrhage Incidence and Hormone Replacement Therapy

### Summary

- The NHS found no clear association between SAH and current or past use of HRT.
- Of the 2 case-control studies that evaluated SAH and HRT use, one identified no significant association, and the other found a significant decrease in risk of SAH in current and ever users compared to never users.
- Our meta-analysis estimated a pooled relative risk of 0.80 (95% CI 0.57–1.05).

#### 6d. Intracerebral hemorrhage

Three cohort studies, among 2 cohorts, evaluated the risk of intracerebral hemorrhage (ICH) specifically. ^8,^ ^75,^ ^76^ The NHS reported a decreased risk of ICH in ERT users (RR 0.53), but there were only 3 cases, and confidence intervals or p-value were not reported. ^8^ The other studies, involving a Swedish cohort, are of poor quality. ^75,^ ^76^ These studies based exposure on pharmacy databases, used external controls from the general Swedish population, and presented data as standard mortality ratios with no adjustment for confounding. However, a small, but significant decrease in risk of ICH was observed in the estrogen-treated group.

Four case-control studies of good or fair quality evaluated ICH (Table 13d, Evidence Table 4). ^64,^ ^71,^ ^72,^ ^77^ A population-based case-control study from Denmark ^72^ analyzed the association between ICH and HRT use. There were 95 cases of ICH, and no significant association between ICH and estrogen use was identified with either former or current use of ERT (OR 0.18; 95% CI 0.02–1.27) or CHRT (OR 1.22; 95% CI 0.66–2.23).

Table 13d. Intracerebral hemorrhage and hormone replacement therapy

Study, Year | N | Design Type | Hormone Type | Hormone Exposure Status | RR/OR | 95% CI
Quality
Pfeffer 1978 ^64^ | 258 cases | CC | HRT | Ever | 0.86 | 0.00–9.19 × 103
Fair
Grodstein 1996 ^8^ | 59,337 | cohort | CHRT | Current | 0.53 | nr
Good
Thrift 1996 ^77^ | 331 cases | CC | HRT | Ever | 0.36 | 0.14–0.95
Fair
Pedersen 1997 ^72^ | 1422 cases | CC | ERT | Current | 0.18 | 0.02–1.27
Good | | | ERT | Past | 1.09 | 0.58–2.03
| | | CHRT | Current | 1.22 | 0.66–2.23
Petitti 1998 ^71^ | 349 cases | CC | HRT | Ever | 0.33 | 0.12–0.96
Fair

nr - not reported

The Northern California study, ^71^ involving women hospitalized for stroke, identified a total of 83 cases of hemorrhagic stroke. Each case was matched to a control by birth year and facility of care. HRT exposure history was obtained by interview or by proxy. Smoking, hypertension, diabetes, prior stroke or TIA, BMI, ethnicity, and education were assessed and included in their multivariate models. This study found a significant decrease in risk of hemorrhagic stroke in current users of HRT (OR 0.33; 95% CI 0.12–0.96).

A study conducted in Australia evaluated 105 cases of ICH occurring between 1990 and 1992 among women ages 18–80 years old, with a mean age of 63.4 years. ^77^ Each case was matched to a control by age, sex, and neighborhood and was recruited and interviewed by the nurse who interviewed the corresponding patient. ICH was verified by CT scan (94.9%), autopsy (4.8%), and MRI (0.3%). Estrogen exposure was considered present if ever used. Among women with ICH, there was a significantly decreased risk of ICH in ever users of HRT (OR 0.36; 95% CI 0.14–0.95).

The population-based case-control study from a Southern California retirement community also assessed the risk of hemorrhagic stroke and HRT use. ^64^ This study, reviewed in detail above, involved 258 women with first stroke resulting in hospitalization or death. A total of 1,260 controls were drawn from the resident population and matched to each case by age. Estrogen exposure was defined as “ever” or “never” use, and was assessed from a prescription database. Results were adjusted for hypertension, diabetes, and age, but not for smoking, family history of CAD, or lipids. No association between hemorrhagic stroke and estrogen use (OR 0.49; 95% CI 0.00–9.19×10^3^) was identified.

Four studies ^64,^ ^71,^ ^72,^ ^77^ were pooled to estimate the risk of ICH associated with HRT in our meta-analysis (Figure 11). No significant decrease in risk of ICH was found (RR 0.71; 95% CI 0.25–1.29). Of note, the most recent NHS ^58^ combined both SAH and ICH (due to small numbers of cases) and found no association in current or past users of HRT compared to never users (RR 0.93–0.95).

Figure 11. Intracerebral Hemorrhage Incidence and Hormone Replacement Therapy

### Summary

- The recent NHS found no association between HRT and ICH. Among 4 case-control studies, 2 observed no association between HRT and hemorrhagic stroke, ^64,^ ^72^ and the other 2 identified a significant decrease in risk. ^71,^ ^77^
- Meta-analysis identified no association between HRT and ICH.

### 7. Does HRT Reduce Cardiovascular Events and Death in Women with Known Coronary Artery Disease?

Although this report concerns the prevention of CVD in healthy postmenopausal women, CVD is present in nearly one-third of women over age 65. ^3^ Because CVD is such a prevalent disorder, it can be argued that evaluation of some of the literature about secondary prevention of CVD is useful in developing prevention guidelines. In addition, because almost all of the studies evaluating HRT and CVD incidence and mortality are observational, it is useful to review the best evidence to date on secondary prevention, since it might lend important insight to understanding the primary prevention literature. Furthermore, because the role of HRT in reducing CVD has been promoted to women and physicians by some health care leaders as well as by the media, based largely on observational studies suggesting benefit, and because this promotion may have been more directed towards women at high risk for CVD or with known CVD, it is useful to review the best evidence on secondary prevention. Observational studies of HRT and CVD are often limited by lack of control for known confounders and inability to control for unknown confounders. Therefore, we focus this discussion on randomized controlled trials of HRT in the secondary prevention of CVD.

The most important randomized controlled trial of HRT in the secondary prevention of CAD is the HERS trial, ^29^ a randomized, placebo-controlled trial of HRT conducted at 20 clinical centers in the United States between January 1993 and September 1994. In the trial, 2,763 postmenopausal women ages 44 to 79 (mean age 66.7) with known CVD were randomized to either HRT or placebo. CAD was defined as evidence of at least one of the following: MI, CABG, PCTA, or angiographic evidence of at least 50% occlusion of one or more major coronary arteries. There were a number of exclusions, but most important to this topic were a CAD event within 6 months of randomization, triglycerides over 300 mg/dL, history of pulmonary embolism or deep venous thrombosis, history of recent hormone use, history of breast or endometrial cancer, endometrial hyperplasia, and/or presence of a disease likely to be fatal in 4 years. Study participants were randomized to CEE 0.625 mg per day and MPA 2.5 mg per day in one pill, or placebo. The primary outcomes evaluated were fatal and non-fatal MI (symptomatic or silent), sudden cardiac death in the absence of known cause, death due to a coronary revascularization procedure, or congestive heart failure. Secondary cardiovascular events included CABG, PTCA, hospitalization for unstable angina, congestive heart failure, resuscitated cardiac arrest, stroke, TIA, or peripheral vascular disease.

There were no significant differences between the women randomized to placebo or intervention. After 4.1 years there were 172 primary CAD events in the intervention group (33.1/1,000 women per year) and 176 in the placebo group (33.6/1,000 women per year) (RR 0.99; 95% CI 0.80–1.22). The relative risk for CAD death was 1.24 (95% CI 0.87–1.75). Although the findings were not statistically significant, the survival curves for CAD death diverged during year 2 with survival lower in the hormone-treated group. Also, the incidence curves for non-fatal MI diverged in the first year, with more events occurring in the CHRT group, and then converged and crossed during the third year of the study. Calculating non-fatal MI events by months of treatment, the relative risk was 2.30 for the first 4 months, 1.46 for the second 4 months, and 1.18 for the third 4 months of CHRT. For primary coronary heart disease events, the incidence curves diverged early in year one, with a greater number of events in the CHRT group, and converged at approximately year 3. Overall, the relative risk of primary CAD outcome was 0.95 (95% CI, 0.76–1.17) in those randomized to HRT.

An important finding in this study was that LDL cholesterol decreased 14% in the hormone treated group and 3% in the placebo group, and that HDL increased 8% in the hormone group and decreased 2% in the placebo group. Overall, the relative risk of primary CAD outcome after adjustment for lipid levels and use of statin drugs was 0.94 (95% CI, 0.76–1.17). These findings are important because they are consistent with multiple other studies showing that HRT decreases LDL and increases HDL, ^21^ yet in this study these changes occur in the absence of improved CAD outcomes, suggesting that other biological mechanisms are important in the CAD and HRT relationship. A recent analysis comparing women in the HERS study to women with presumed CAD in the NHANES III survey highlighted the issue that women in the general population have more CAD risk factors than those in the HERS study, and that secondary prevention strategies should also be tested in populations more representative of the general population. ^78^

Another important finding in this study was that deep venous thrombosis and pulmonary embolism occurred in 34 women in the hormone group (6.3/1,000 women-years) and in 12 women in the placebo group (2.2/1,000 women-years). This finding is an important one, both for its intrinsic risk and because it suggests a pathway by which HRT might increase CAD events in the setting of reduced lipid levels, since thrombosis is part of the pathophysiology of several CVD events. It was suggested by Hulley and others that the early increase in CAD events in the HERS study might be explained by an immediate prothrombotic, proischemic, or proarrhythmic effect of CHRT that is gradually outweighed by a reduction in atherosclerosis progression.

The ERA study ^30^ involved randomization of 309 women with angiographically-confirmed CAD to either placebo, CEE 0.625 mg per day, or CEE 0.625 mg per day plus MPA 2.5 mg per day. All women received a baseline coronary angiogram, were followed for a mean of 3.2 years, and had a followup angiogram. Each of the estrogen arms of the study produced significant decreases in LDL cholesterol when compared to placebo. However, neither active treatment regimen changed the progression of atherosclerosis when evaluated with repeat angiogram. In addition, coronary disease event rates did not differ among the treatment groups. Whether lack of angiographic disease progression correlates with no difference in event rates over time is unclear. This lack of benefit of estrogen with or without progestin among women with established coronary disease is consistent with the HERS study, but differs in not finding higher early event rates in the treatment groups. One of the questions raised with the HERS study was whether the addition of progestins contributed to a lack of benefit in the study; the ERA study helps dispel that concern.

We reviewed 4 studies involving women undergoing angiography (Evidence Table 5). ^79–82^ We considered these as studies of secondary prevention since women undergoing angiography represent a select group of women, and the results are not generalizable to the general population. In addition, they are effectively cross-sectional studies in which estrogen use was evaluated at the time of angiography, and these types of studies provide little insight into causal relationships.

### Summary

- There is currently no evidence that HRT reduces either progression of CAD or CAD events among women with known CAD.