# Introduction

Postmenopausal hormone replacement therapy (HRT) is one of the most commonly prescribed drug regimens in the United States. This use largely reflects the significant number of postmenopausal women in the United States, many of whom are choosing to take HRT to treat symptoms of menopause. A recent survey showed that 40% to 55% of postmenopausal women have used hormone replacement therapy at some time in their lives, with higher rates of use in women who have undergone hysterectomy. ^1^ Also contributing to the high prevalence of use has been significant publicity to physicians and women regarding HRT's effect on bone density and its potential effect in decreasing cardiovascular disease (CVD) morbidity and mortality, as well as potentially reducing several other serious diseases, such as Alzheimer's Disease and colon cancer. Finally, because estrogen replacement therapy has been shown to favorably alter lipids, estrogen use is recommended as part of the National Cholesterol Education Program Guidelines for managing cholesterol, and this too has contributed to its frequent use. ^2^

Of all the potential benefits of HRT, the one with the greatest potential public health impact is its possible role in preventing CVD, the leading cause of death among women in the United States. CVD includes coronary artery disease (CAD) and stroke. Unfortunately, despite many observational studies of HRT and CVD, a valid answer to the question of whether HRT is protective against CVD has not yet been provided in the medical literature, due to limitations of observational studies. However, evidence from 3 randomized controlled trials has recently been published and aids in evaluating this relationship. This systematic evidence review will summarize all epidemiologic studies evaluating the role of HRT in the primary prevention of CVD. Two important recent studies of the secondary prevention of CAD in postmenopausal women will also be reviewed because they are the only published randomized controlled trials of HRT in CVD and may provide insight to the primary prevention discussion.

## Background

CVD, which includes CAD and stroke, is the leading cause of death in women in the United States. At every age, women have less CAD than men, even with adjustment for risk factors. ^3^ The one risk factor exception is diabetes, where women and men have equal rates of CAD. ^4^ To explain this gender difference, it has been suggested that women have less CAD than men because of exposure to female hormones, specifically estrogen. Animal studies showing that estrogen is protective against heart disease and vascular disease have suggested an important role for estrogen in atherosclerosis. ^5–7^ The relationship between estrogen and CVD has also been considered because of epidemiologic studies showing low rates of CVD in premenopausal women, with significant increases in incidence occurring after menopause, ^4^ although other physiologic parameters, such as progesterone and pituitary hormones, also change with menopause.

Adding to the hypothesis that estrogen mediates the reduced risk of CVD observed among women are multiple epidemiologic studies showing reduced rates of CVD, particularly CAD, among women using HRT. ^8^ Evidence of a relationship between female reproductive hormones and CVD also comes from studies evaluating CVD in women who undergo premature menopause. In the Nurses' Health Study (NHS), early menopause increased the risk of CVD when compared to later menopause, suggesting an important role of estrogen or other reproductive hormones. ^9^ This change in risk of CVD was reversed or normalized with HRT, ^9,^ ^10^ suggesting that estrogen with or without progesterone was important etiologically. However, other explanations may also be important, such as confounding by factors associated with early menopause and CVD (e.g., smoking and body weight). Other physiologic parameters that change with menopause may also be important etiologically. In addition, the fact that women in different countries have dramatically different rates of CVD suggests that genetic, environmental, and lifestyle characteristics are much more important than exposure to estrogens in determining CVD risk among women.

Multiple observational epidemiologic studies evaluating the relationship between HRT (usually estrogen) and CVD have been conducted, and many suggest that HRT is associated with lower risk of CVD. ^8^ Some, however, have suggested increased risk ^11^ or no difference in risk. ^12^ Critical in evaluating this relationship has been the issue of confounding, and the fact that women who use estrogen are systematically different from women who do not in ways that influence their risk of CAD. ^11^ However, because of the many studies suggesting benefit, multiple studies have been conducted in attempts to understand the potential mechanisms of benefit from HRT. These biological mechanisms will be briefly discussed.

## Cardiovascular Disease: Proposed Biological Actions of Estrogen and Progesterone

This section briefly summarizes proposed mechanisms by which estrogen might influence CVD risk. For excellent, in-depth reviews, see papers by Bush and Barrett-Connor ^6^ and Mendelsohn. ^13^ Because recent randomized controlled trials have evaluated HRT and lipids, and because estrogen has been proposed as a potential therapy for hyperlipidemia, ^2^ the review of lipids is more detailed than other topics in this section.

Lipids. In general, observational studies ^14–17^ and clinical trials of estrogen use ^18–20^ have shown that estrogen alone decreases low-density lipoprotein (LDL) and apoprotein B, and increases high-density lipoprotein (HDL) and triglycerides. ^21^ These findings have been shown in diverse population groups, among healthy and non-healthy women, and among those with natural and surgical menopause. Adding progesterone has been shown to diminish, though not reverse, the improvement in HDL that occurs among women taking estrogen, and the magnitude varies with the type of progestin used. Because women who use HRT often have health characteristics associated with better lipid profiles, the most important data in this area come from randomized controlled trials of HRT and lipids.

The best data may come from the Postmenopausal Estrogen/Progestin Inverventions (PEPI) trial, ^21^ in which 875 healthy postmenopausal women were randomized to placebo, conjugated equine estrogen (CEE) alone, CEE plus cyclic medroxyprogesterone acetate (MPA), CEE plus continuous daily MPA, or CEE plus cyclic micronized progesterone (MP). All active therapies decreased mean LDL-cholesterol and increased mean triglyceride levels when compared to placebo. All estrogen therapies also increased HDL-cholesterol, with the greatest increase among women taking CEE alone (5.6 mg/dl) or CEE plus MP (4.1 mg/dl). Combination therapy with CEE and cyclic MPA, or CEE with continuous MPA, was associated with increased HDL levels of 1.6 and 1.2 mg/dl, respectively. Women taking placebo experienced a decrease in HDL of 1.2 mg/dl. The effect of estrogen and progestins on HDL is an important one because HDL has been shown to be an important predictor of major CAD among women. ^4,^ ^22^ Transdermal estrogen has less effect on lipids than oral administration of estrogen and no effect on HDL cholesterol. ^13^

Another important independent risk factor for atherosclerosis is lipoprotein(a). Randomized trials of CEE and 17 B estradiol have shown that estrogen also reduces lipoprotein (a). ^23–25^ However, some studies have shown that this benefit may be modified ^26^ or attenuated ^19^ by adding progestins.

Adding progestins to estrogen may reduce the decrease in LDL and increase in HDL ^27^ among women taking estrogen (as discussed above in the PEPI trial), although usually not to pre-estrogen or placebo levels. The PEPI trial was important in showing that the action of progestins on lipids varies between MPA and MP. ^21^ Adding progestins to estrogen also may reduce the increase in triglycerides observed when estrogen is used alone. ^27^ Also, the effects of progestins on cholesterol levels vary significantly by dose and type of progestin, particularly their androgenicity. ^19,^ ^27,^ ^28^

The Heart and Estrogen/Progestin Replacement (HERS) trial, ^29^ a randomized controlled trial of combined hormone replacement therapy (CHRT) in the secondary prevention of CAD, contributed important findings to the evaluation of lipid changes associated with CHRT. The study involved 2,763 postmenopausal women younger than age 80 with known CAD randomized to either placebo or CEE (0.625 mg per day) and MPA (2.5 mg per day) and followed for 4.1 years for non-fatal myocardial infarction (MI) or coronary death. During the first year of the study, LDL cholesterol decreased 14% in those randomized to CHRT and 3% in the placebo group. Among those women randomized to hormones, HDL cholesterol increased by 8% and triglycerides by 10%. In the placebo group, HDL decreased by 2% and triglycerides increased by 2%. ^29^

In another recently reported randomized controlled trial of secondary prevention ^30^ involving 309 women with coronary disease, women randomized to CEE (0.625 mg per day) had a decrease in LDL of 9.4%, an increase in HDL of 18.8%, and an increase in triglycerides of 6.1%. Women randomized to CEE (0.625 mg per day) plus MPA (2.5 mg per day) had an LDL decrease of 16.5%, an HDL increase of 14.2%, and an increase in triglycerides of 10.1%. Among the women randomized to placebo, LDL decreased by 1.3%, HDL increased by 6.8%, and triglycerides increased by 2.2%. ^30^

Endothelial wall function. Studies of postmenopausal women with atherosclerosis have shown that sustained estrogen enhances endothelium-dependent vasodilation. ^31,^ ^32^ One study showed that estrogen restored coronary vasodilation in response to acetylcholine among women but not men with coronary disease, suggesting a gender-specific effect. ^33^ Estrogen-associated vasodilation occurs within minutes after estrogen administration and is not dependent on changes in gene expression; in addition, estrogen inhibits the response of blood vessels to vascular injury, a response occurring over hours to days and dependent on changes in gene expression. ^13^

Carbohydrate metabolism. The role of estrogens in carbohydrate metabolism is complex. Some studies have suggested that estrogens may predispose women to impaired glucose tolerance; others have suggested favorable effects on glucose and insulin that may depend on the type of estrogen and progestin used. ^34^ Another important finding from the PEPI trial was that mean changes in 2-hour insulin levels did not differ significantly among treatment groups. ^21^ However, 2-hour glucose levels increased significantly in women on active treatment compared to placebo. Fasting insulin levels slightly, though not significantly, decreased among women assigned to active treatment. Also, fasting glucose levels decreased slightly in all treatment arms compared with placebo (p = 0.03). The overall clinical significance of these changes is uncertain at this time.

Hypertension. The induction of hypertension among women taking estrogen has been a concern because estrogen regulates vascular tone, both through long-term and short-term effects. ^13^ Long-term administration of estrogen is associated with decreases in renin, angiotensin-converting enzyme inhibitor, and endothelin I, as well as other vascular changes, with a net vasodilatory effect. ^13^ However, studies evaluating this relationship have been contradictory, with some showing elevations and some showing decreases in blood pressure among women using estrogen. These studies, though, have had methodologic weaknesses. ^21^ The addition of progesterone to estrogen and the effect on blood pressure has been less well studied. In the PEPI trial, systolic and diastolic blood pressure did not differ significantly among treatment groups. ^21^

Coagulation factors. The role of coagulation factors in atherosclerotic vascular disease is complex. Estrogen has been shown to regulate the hepatic synthesis of several coagulation factors and fibrinolytic proteins, ^13^ resulting in reduced levels of fibrinogen, ^21^ antithrombin III, ^34^ and plasminogen-activator inhibitor type 1. ^35,^ ^36^ The effect of estrogen on coagulation varies with type and dose of estrogen, as well as with duration of use. ^13^ Some studies have shown that estrogen alone increases plasminogen, protein C, and factor VII. ^16^ Estrogen may also favor vasodilation and anti-aggregation by increasing prostacyclin production and thromboboxane A2 platelet aggregation. ^37^ The net effect of these changes on CVD incidence is uncertain, although the data on HRT from both observational and randomized controlled trials are consistent and strong in showing an increase in deep venous thrombosis and pulmonary emboli among women using HRT. ^38,^ ^39^ Given the known importance of plaque formation and rupture with associated thrombosis in myocardial infarction and stroke, the balance among these factors and their association with CVD is critically important.

Weight. Obesity and/or increased abdominal adiposity are associated with increased risk of CAD in women. ^40^ The PEPI study showed that women in all treatment groups gained weight over the 3 years of the study, but weight gain was greater among women assigned to placebo (2.1 kg) and least among women using CEE (0.7 kg) over 36 months. ^21^ The mean waist-to-hip ratio increased slightly over time among all groups, unrelated to treatment.

Inflammation. C-reactive protein, a marker of inflammation, was recently shown to be an independent predictor of CVD in women. ^41^ Two recent studies have shown that women taking estrogen, or estrogen with progesterone, had higher levels of C-reactive protein than women not taking HRT. ^42,^ ^43^

Antioxidant Effects. The role of estrogen as an antioxidant or pro-oxidant has been suggested in some studies. ^44^ Estrogen also has been found to inhibit LDL oxidation in vitro. ^45^

In aggregate, the changes in intermediate biological outcomes have potentially favorable results, including lower LDL, lower lipoprotein (a), and increased HDL, and potentially unfavorable results, such as increased triglycerides, factor VII and c-reactive protein, and decreased plasminogen and antithrombin III. ^16,^ ^21,^ ^34^ These physiologic changes may explain a biological relationship between HRT and CVD. However, whether the favorable changes in these biological intermediates translate into improved CVD outcomes is uncertain. Given the mix of intermediate biological outcomes and limitations of the observational data, it is imperative that the relationship be critically examined prior to speculation of benefit. Several important questions regarding HRT and CVD among postmenopausal women have not yet been answered in the medical literature. These questions primarily relate to the cardiovascular risks/benefits associated with short-term and long-term hormone use, as well as risks/benefits associated with combination therapy involving estrogen and progesterone. These questions are outlined in detail below.

This report reviews the epidemiologic literature evaluating these benefits and risks in association with CVD. In some studies, CVD was explicitly described as a global outcome involving any cardiovascular event, such as stroke, transient ischemic attack, sudden cardiac death attributed to ischemic heart disease, myocardial infarction, peripheral vascular disease, coronary artery surgery (CABG), percutaneous transluminal coronary angioplasty (PTCA), or congestive heart failure (CHF). In other studies, the components of cardiovascular disease were not described but presumably comprised CAD and stroke. In an effort to include the breadth of available information, for the purposes of this review, CVD is considered as a global outcome when described, or as a measure of CAD and stroke when not described. CAD includes MI, PTCA, CABG, sudden cardiac death attributed to CAD, CHF, and occasionally, angina. Stroke includes different types of stroke, such as subarachnoid hemorrhage (SAH), intracerebral hemorrhage (ICH), thromboembolic infarction, and transient ischemic attack.

## Analytic Framework and Key Questions

The analytic frameworks in Figures 1 and 2 show the target populations, interventions, and health outcome measures we examined for the overall question of the benefits and risks of postmenopausal HRT.

Figure 1. Analytic Framework 1: Benefits of Hormone Replacement Therapy

Figure 2. Analytic Framework 2: Adverse Effects of Hormone Replacement Therapy

The key questions to consider when evaluating the research describing the role of exogenous estrogen or estrogen/progesterone in CVD incidence and mortality include:

1. What is the role of postmenopausal HRT in the primary prevention of CVD death?
2. What is the role of postmenopausal HRT in the primary prevention of CAD death?
3. Does postmenopausal HRT alter the risk of stroke death?
4. What is the role of postmenopausal HRT in the primary prevention of CVD?
5. What is the role of postmenopausal HRT in the primary prevention of CAD?
6. Does postmenopausal HRT alter the risk of stroke as well as subtypes of stroke?
7. Does postmenopausal HRT reduce cardiovascular events or progression of disease in women with known CAD?

Because we were concerned with HRT as chemoprophylaxis against chronic conditions, not as treatment of menopausal symptoms, we focused on the use of either estrogen alone or estrogen combined with progesterone in healthy, postmenopausal women. However, because there are important recent data from secondary prevention studies of HRT in women with known CVD and these are the only clinical trials with published information to date, we have also included information on 2 randomized controlled trials of secondary prevention of CVD with HRT, since they may provide insight to the issue of primary prevention. This evaluation will be part of an overall chapter reviewing the risks and potential benefits of HRT. Shared decision making and patient preferences will also be discussed in that chapter.