# Appendix 4. Statistical analysis report for postmenopausal hormone replacement therapy and cardiovascular disease

Benjamin K. S. Chan, M.S.^*^

* Evidence-based Practice Center, Division of Medical Informatics and Outcomes Research, Oregon Health and Science University, Mail Code: BICC, 3181 SW Sam Jackson Park Road, Portland, Oregon 97201-3098, tel: 503 494 1607, fax: 503 494 4551, e-mail: chanb@ohsu.edu

August 20, 2002

## Cardiovascular disease

Four outcomes were analyzed separately: the incidence and mortality of cardiovascular disease and coronary artery disease. Studies contributed multiple data points if they reported separate results for current and past hormone replacement therapy (HRT) users. Such studies almost always did not report results for the combined group of ever HRT users. The results from studies that did not distinguish current users from past users were categorized under ever users. All studies reported relative risk (RR) estimates using either odds ratios or hazard ratios. Adjusted relative risks were used because they represent the original authors' best estimate of the relative risk. The logarithm of the relative risk (logRR) is used as the effect size data point since it is assumed to be Normally distributed. Standard errors for logRR were calculated from reported confidence intervals or pvalues.

## 1 Hierarchical model

Because of the nature of how the studies reported their results we wanted to preserve the stratification by exposure status but also allow for the estimation of a global measure of relative risk under any HRT exposure while allowing for variation between status categories. The linear predictor for study i is defined as μ_i_.

μ_i_ = β_current_x_i_,_current_ + β_past_x_i_,_past_ + β_ever_x_i_,_ever_ (1)

where x_i_,_current_, x_i_,_past_, and x_i_,_ever_ are indicator variables for whether data point i corresponds to the exposure category. The relative risk of each exposure status is a sample from a hyperdistribution of relative risks for any HRT exposure and are distributed as

β_current_, β_past_, β_ever_ ~ Normal (μ_any HRT_, σ^2^ _any HRT_)

The global effect of any exposure is represented by μ_any HRT_. Variance between exposure categories is represented by σ^2^ _any HRT_. The model allows for further stratification by adding terms to μ_i_, such as β_j_x_ij_

The logarithm of the relative risk is assumed to have the following distribution:

log(RR_i_ ~ Normal (μ_i_ + z_i_pr ^2^, s^2^ _i_)

where z_i_ ~ Normal(0, 1) and s_i_ is the standard error calculated from reported confidence intervals or p-values. r^2^ represents between-study variance and z_i_ represents the deviation between the log(RR_i_) of the individual study or data point and the population. Under a fixed effects model r^2^ = 0 while under a random effects model r^2^ > 0.

Fitting the model with Markov Chain Monte Carlo The model was estimated using a Bayesian data analytic framework. The data were analyzed using WinBUGS, which uses Gibbs sampling to simulate posterior probability distributions. Noninformative, proper, prior probability distributions were used unless otherwise specified. The prior probability distributions used were:

β_j_ , β_current_, β_past_, β_ever_, μ_any HRT_ ~ Normal(0, 10^6^)

r^2^, σ^2^ _any HRT_ ~ Inv-gamma(0.001, 0.001)

Five separate Markov Chain Monte Carlo chains were used, with overdispersed initial values, to generate draws from posterior distributions. Point estimates (mean) and 95% credible intervals (2.5 and 97.5 percentiles) were derived from the subsequent 5 × 2, 000 draws after reasonable convergence of the five chains was attained. Iterations that result in very large or very small values were trimmed when calculating means. Kernal density estimation were used to generate smoothed densities.

## 2 Results

### 2.1 Cardiovascular disease mortality

The results from the hierarchical random-effects meta-analysis models are shown in Table 1. Figure 1 shows kernal density estimates for the relative risks of each exposure status and for any HRT exposure estimated from the model.

### 2.2 Coronary disease mortality

The results from the hierarchical random-effects meta-analysis models are shown in Table 2. Figure 2 shows kernal density estimates for the relative risks of each exposure status and for any HRT exposure estimated from the model.

Note that the density for ever HRT exposure is pulled toward the any HRT exposure density and is not similar to the relative risk and confidence interval given for the single study of ever HRT exposure.

### 2.3 Cardiovascular disease incidence

The results from the hierarchical random-effects meta-analysis model are shown in Table 3. Figure 3 shows kernal density estimates for the relative risks of each exposure status and for any HRT exposure estimated from the model.

Note that the densities for each of the exposure status types closely resemble the density for any HRT exposure.

Since there was a previous meta-analysis done on cardiovascular disease incidence, in addition to a noninformative prior, its results are used as the hyperprior in the M2 model fit

μany HRT ~ Normal(0.33, 0.54^2^)

The Hemminki, 1997 prior did not significantly affect the results from the model fit using a noninformative prior. This is likely due to the large variability in the Hemminki, 1997 results.

### 2.4 Coronary disease incidence

An important modification is made to the model for this outcome. It was thought that studies that adjusted for socioeconomic status (SES) in their relative risk models have different estimates than studies that did not adjust for SES. So, an additional term is included in the linear predictor shown in 1. The linear predictor is

μ_i_ = β_current_x_i_,_current_ + β_past_x_i_,_past_ + β_ever_x_i_,_ever_ + β_SES_x_i_,_SES_ (2)

where x_i_,_SES_ is an indicator variable for whether the study adjusted for SES.

The results from the model are shown in Table 4. Figure 4 and 5 show kernal density estimates for the relative risks of each exposure status and for any HRT exposure estimated from the model above.

Stratification by other factors Coronary disease incidence was the only outcome where it was thought that it would be worthwhile to explore stratification by other study-level factors as well.

Such factors included study design (cohort, case-control, and randomized controlled trial); HRT exposure type (unopposed estrogen (ERT), combined estrogen plus progesterone (CHRT), and unspecified HRT); study quality (fair and good); HRT exposure status (current, past, and ever use); and whether the study adjusted for socioeconomic status (SES), alcohol use, exercise, or cholesterol level.

Table 1. Meta-analysis results for cardiovascular disease mortality

| Relative risk | | 95% CI
Exposure | Mean | Median | Lower | Upper
Current | 0.6401 | 0.6195 | 0.4359 | 0.9311
Ever | 0.8104 | 0.7980 | 0.5820 | 1.1250
Past | 0.7861 | 0.7740 | 0.5235 | 1.0920
Any* | 0.7501 | 0.7302 | 0.4159 | 1.2260

* Trimmed mean; lowest and highest 0.5% are trimmed from each tail.

Figure 1. Relative risk densities of cardiovascular disease mortality

Table 2. Meta-analysis results for coronary disease mortality

| Relative risk | | 95% CI
Exposure | Mean | Median | Lower | Upper
Current | 0.6166 | 0.6023 | 0.3989 | 0.9137
Ever* | 0.8070 | 0.7549 | 0.3663 | 1.5980
Past | 0.7578 | 0.7538 | 0.5295 | 1.0220
Any* | 0.7388 | 0.6997 | 0.3551 | 1.4460

* Trimmed mean; lowest and highest 0.5% are trimmed from each tail.

Figure 3. Relative risk densities of cardiovascular disease mortality

Table 3. Meta-analysis results for cardiovascular disease incidence

| | Relative risk | | 95% CI
Prior | Exposure | Mean | Median | Lower | Upper
Non-informative prior | Current | 1.229 | 1.167 | 0.7436 | 2.222
| Ever* | 1.352 | 1.302 | 0.8882 | 2.065
| Past* | 1.241 | 1.181 | 0.7089 | 2.271
| Any* | 1.306 | 1.216 | 0.6899 | 2.422
Hemminki, 1997 prior | Current | 1.273 | 1.177 | 0.8015 | 1.997
| Ever | 1.348 | 1.307 | 0.9177 | 1.997
| Past | 1.258 | 1.188 | 0.7908 | 2.082
| Any | 1.281 | 1.232 | 0.8560 | 2.004

* Trimmed mean; lowest and highest 0.5% are trimmed from each tail.

Figure 4. Relative risk densities of cardiovascular disease incidence

Table 4. Meta-analysis results for coronary disease incidence

| | Relative risk | | 95% CI
Model | Exposure | Mean | Median | Lower | Upper
Model 1 | Current | 0.8057 | 0.8010 | 0.6853 | 0.9555
| Ever | 0.9178 | 0.8871 | 0.6706 | 1.3310
| Past | 0.8862 | 0.8795 | 0.7534 | 1.0510
| Any | 0.8787 | 0.8551 | 0.6372 | 1.2140
Model 2, SES adjusted | Current | 0.9743 | 0.9700 | 0.8164 | 1.1570
| Ever | 1.1070 | 1.0820 | 0.8420 | 1.5250
| Past | 1.0700 | 1.0660 | 0.9023 | 1.2670
| Any* | 1.0510 | 1.0360 | 0.7862 | 1.4410
Model 2, not SES adjusted | Current | 0.7064 | 0.7052 | 0.6379 | 0.7815
| Ever | 0.8022 | 0.7791 | 0.6289 | 1.1030
| Past | 0.7751 | 0.7744 | 0.6897 | 0.8654
| Any | 0.7747 | 0.7517 | 0.5971 | 1.0180

* Trimmed mean; lowest and highest 0.5% are trimmed from each tail.

Pr(βSES > 0) = 0.9998

Results exclude Eaker, 1987 (this study is a reanalysis of the Framingham data reported by Wilson, 1985)and Pfeffer, 1978, ever HRT users (it is assumed that the subjects used in this are a superset of subjects reported as current HRT users). Results including Eaker, 1987 (and excluding Wilson, 1985)and using Pfeffer, 1978, ever HRT users (and not current HRT users) did not produce significantly different results.

Figure 4. Coronary disease incidence pooled relative risk densities from studies that did not adjust for socioeconomic status

Figure 5. Coronary disease incidence pooled relative risk densities from studies that adjusted for socioeconomic status

## Stroke

Six outcomes were analyzed separately: the mortality from stroke; the incidence from stroke; the incidence from atherothrombotic brain infarction, ischemic stroke, and thromboembolic stroke (ABI, IS, and TES); the incidence from subarachnoid hemorrhage (SAH); the incidence from intracerebral hemorrhage (ICH); and the incidence from hemorrhagic stroke (SAH and ICH combined).

Studies contributed multiple data points if they reported separate results for current and past hormone replacement therapy (HRT) users. Such studies almost always did not report results for the combined group of ever HRT users. The results from studies that did not distinguish current users from past users were categorized under ever users. All studies reported relative risk (RR) estimates using either odds ratios or hazard ratios. Adjusted relative risks were used because they represent the original authors' best estimate of the relative risk. The logarithm of the relative risk (logRR) is used as the effect size data point since it is assumed to be Normally distributed.

Standard errors for logRR were calculated from reported confidence intervals or p-values.

## 3 Random effects model

No differences were found in the results stratified between the three factors of study design (casecontrol versus cohort design), exposure type (hormone replacement therapy versus estrogen replacement therapy versus combined hormone replacement therapy), and exposure status (current versus past versus ever user). Therefore, the final results presented use an unstratified, interceptonly model, μ.

The logarithm of the relative risk is assumed to have the following distribution:

log(RR_i_) ~ Normal (μ + z_i_pr^2^, s^2^ _i_)

where z_i_ ~ Normal(0, 1) and si is the standard error calculated from reported confidence intervals or p-values. r^2^ represents between-study variance and z_i_ represents the deviation between the log(RR_i_) of the individual study or data point and the population. Under a fixed effects model r^2^ = 0 while under a random effects model r^2^ > 0.

Fitting the model with Markov Chain Monte Carlo The model was estimated using a Bayesian data analytic framework. The data were analyzed using WinBUGS, which uses Gibbs sampling to simulate posterior probability distributions. Noninformative, proper, prior probability distributions were used unless otherwise specified. The prior probability distributions used were:

μ ~ Normal(0, 10^6^)

r^2^, σ^2^ _any HRT_ ~ Inv-gamma(0.001, 0.001)

Five separate Markov Chain Monte Carlo chains were used, with overdispersed initial values, to generate draws from posterior distributions. Point estimates (mean) and 95% credible intervals (2.5 and 97.5 percentiles) were derived from the subsequent 5 × 2, 000 draws after reasonable convergence of the five chains was attained. Iterations that result in very large or very small values were trimmed when calculating means. Kernal density estimation were used to generate smoothed densities.

## 4 Results

Results from the meta-analysis are shown in Table 5. Figures 6–11 show kernal density estimates for the relative risks of each outcome.

Table 5. Meta-analysis results from random effects models for stroke

| Relative risk | | 95% CI
Outcome | Mean | Median | Lower | Upper
Stroke mortality | 0.7900 | 0.7844 | 0.5982 | 1.014
Stroke incidence | 1.118 | 1.117 | 1.009 | 1.233
ABI, IS, and TES incidence | 1.202 | 1.196 | 1.046 | 1.404
Subarachnoid hemorrhage (SAH) incidence | 0.7997 | 0.7961 | 0.5722 | 1.047
Intracerebral hemorrhage (ICH) incidence | 0.7113 | 0.6877 | 0.2501 | 1.287
Hemorrhagic stroke (SAH or ICH) incidence | 0.8091 | 0.8099 | 0.5931 | 1.008

Figure 6. Relative risk density of stroke mortality

Figure 7. Relative risk density of stroke incidence

Figure 8. Relative risk density of ABI, IS, and TES incidence

Figure 9. Relative risk density of SAH incidence

Figure 10. Relative risk density of ICH incidence

Figure 11. Relative risk density of hemorrhagic stroke (SAH or ICH) incidence