# Appendix 3. Criteria for Grading Individual Studies and Linkages in the Analytic Framework

Largely during 1999, the Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the quality of individual studies could be evaluated in terms of both internal validity and external validity and a related set of criteria relating to the linkages within the analytic framework for the topic of a given systematic evidence review (SER). The USPSTF provisionally accepted these approaches and criteria, and the associated definitions of quality categories, at two quarterly meetings in mid-1999.

The first part of this Appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments. The overall evaluation for each study is recorded in the Evidence Tables typically provided in Appendix D of any SER. The second part of this Appendix provides similar information relating to aggregate internal validity, aggregate external validity (generalizability), and consistency of the results from related sets of articles (also referred to as coherence).

## Criteria for Grading the Internal Validity of Individual Studies

### Introduction

All topic teams will use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technologies or technologies that are not feasible for primary care practice may be screened out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams will justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

### Design-Specific Criteria and Quality Category Definitions

Presented below are categories of criteria for which to judge internal validity; they are given for several major study designs (systematic reviews, case-control studies, randomized trials and cohort studies). With these are given general definitions of three ratings — “good,” “fair,” and “poor” — relating to those criteria. These specifications are not meant to be rigid rules. Rather, they are intended to be general guidelines, and topic teams can make individual exceptions when those are cexplicitly explained and justified.

In general, a “good” study is one that meets all criteria well. A “fair” study is one that meets all but one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### Systematic Reviews

Four categories of criteria apply to systematic reviews. They are:

1. Comprehensiveness of sources considered/search strategy used;
2. Standard appraisal of included studies;
3. Validity of conclusions; and
4. Recency and relevance of the included studies.

The definitions of the three rating categories for these types of studies are as follows:

Good: Recent, relevant review that has comprehensive sources and systematic search strategies; explicit and relevant selection criteria; standard appraisal of studies; and valid conclusions.

Fair: Recent, relevant review that lacks comprehensive sources and systematic search strategies but is not clearly biased and meets the other criteria for a rating of “good.”

Poor: Outdated, irrelevant, or biased review that lacks comprehensive sources and/or systematic search strategies, explicit and relevant selection criteria, and/or standard appraisal of studies or that draws invalid conclusions.

### Case-Control Studies

Six categories of criteria apply to case-control studies. They include:

1. Accurate ascertainment of cases.
2. Nonbiased selection of cases and controls with exclusion criteria applied equally to both.
3. Response rate.
4. Diagnostic testing procedures applied equally to each group.
5. Measurement of exposure accurate and applied equally to each group.
6. Appropriate attention to potential confounding variables.

The definitions of the three rating categories for these types of studies are as follows:

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Appropriate ascertainment of cases and controls and exclusion criteria applied equally to cases and controls, and without major apparent selection or diagnostic work-up bias; response rate less than 80 percent; or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases; response rates less than 50 percent; or inattention to confounding variables.

### Randomized Controlled Trials and Cohort Studies

Seven categories of criteria apply to RCTs and cohort studies. They include:

1. Initial assembly of comparable groups.
  a. For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  b. For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
2. Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
3. Levels of follow-up: differential loss between groups; overall loss to follow-up.
4. Measurements: equal, reliable, and valid, and including masking of outcome assessment.
5. Clear definition of interventions.
6. All important outcomes considered.
7. Analysis:
  a. For RCTs: intention-to-treat analysis.
  b. For cohort studies: adjustment for potential confounders.

The definitions of the three rating categories for these types of studies are as follows:

Good: Comparable groups assembled initially and maintained throughout the study; follow-up at least 80 percent; reliable and valid measurement instruments applied equally to the groups; outcome assessment masked; interventions defined clearly; all important outcomes considered; appropriate attention to confounders in analysis; for RCTs, intention-to-treat analysis.

Fair: Generally comparable groups assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments acceptable (although not the best) and generally applied equally; outcome assessment masked; some, but not all important, outcomes considered; appropriate attention to some, but not all, potential confounders; for RCTs, intention-to-treat analysis.

Poor: Groups assembled initially not close to being comparable or not maintained throughout the study; measurement instruments unreliable or invalid or not applied at all equally among groups; outcome assessment not masked; key confounders given little or no attention; for RCTs, no intention-to-treat analysis.

### Diagnostic Accuracy Studies

Seven categories of criteria apply to diagnostic accuracy studies. They include:

1. Screening test relevant, available for primary care, adequately described.
2. Study uses a credible reference standard, performed regardless of test results.
3. Reference standard interpreted independently of screening test.
4. Handles indeterminate results in a reasonable manner.
5. Spectrum of patients included in study.
6. Sample size.
7. Administration of reliable screening test

The definitions of the three rating categories for these types of studies are as follows:

Good: Relevant, available screening test; credible reference standard; interpretation of reference standard independent of interpretation of screening test; reliability of test assessed; few indeterminate results, or indeterminate results handled in a reasonable manner; large same size (more than 100 subjects) and a broad spectrum of patients with and without disease.

Fair: Relevant, available screening test; reasonable although not best reference standard; interpretation of reference standard independent of interpretation of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow spectrum of patients.

## Criteria for Grading Linkages in the Analytic Framework

### Introduction

As documented just above, the USPSTF Methods Work Group developed a set of criteria by which the quality of individual studies could be evaluated in terms of both internal validity. The Methods Work Group also developed definitions and criteria for judging the strength or quality of evidence for key questions — i.e., linkages in the analytic frameworks — for the topics of SERs. These quality criteria were discussed at the May 1999 quarterly meeting and were essentially adopted for use by the Evidence-based Practice Centers in developing their first set of SERs. This document describes the criteria relating specifically to linkages in the analytic framework.^*^

* The USPSTF is developing a separate set of criteria for rating its recommendations about an entire preventive service, including policies for appropriate extrapolation to populations or settings not reflected in the reviewed literature. These criteria are expected to be put into final form in early 2000. However, because the SERs do not contain USPSTF recommendations, those ways of grading recommendations are not dealt with here.

### Linkage Category Definitions

The rating scheme for grading the evidence for a linkage in the analytic framework rests on three classes of criteria: aggregate internal validity, aggregate external validity, and consistency or coherence. The Methods Work Group did not establish set formulae for arriving at any linkage score for these criteria sets. As with the criteria for quality of individual articles, they are intended to be applied as general guidelines, and the judgments are made implicitly. Judgments can be made about evidence of benefits and evidence of harms. In addition, a summative grade — i.e., an overall rating — combining the evaluations of the three categories defined below can be given.

Also as with the criteria for individual studies, these three categories can be labeled as “good,” “fair,” or “poor.” That is, the linkages can be understood to be supported by good evidence, fair evidence, or poor evidence. The summative, overall rating can also range from good to poor.

#### Aggregate Internal Validity

This category refers to the overall extent to which data are valid for conditions addressed within studies. It would be rated according to quality grading information about individual studies.

#### Aggregate External Validity

This category concerns the generalizability of evidence to questions addressed by the linkage. This would include the concordance between populations, interventions, and outcomes in the studies reviewed (on the one hand) and those to which the linkage pertains (on the other). In short, this category reflects the applicability of the evidence to real-world conditions.

The Methods Work Group expects that differences between conditions examined in studies and those addressed by the linkages should be considered if they could potentially influence outcomes. These might include (but not necessarily be limited to): (a) biologic or pathologic characteristics; (b) incidence and prevalence of clinical conditions; (c) distribution of comorbid conditions that might affect outcomes; and (d) likelihood of acceptability and adherence on the part of patients or providers (or both).

#### Consistency

This category relates to the overall “coherence” of the body of evidence relating to the linkage. Specifically, it includes the number of studies, the homogeneity of those studies (in terms of clinical conditions, populations, settings, and the like), the level of precision of findings in the studies, and the direction of results. In addition, it can include dose-response relationships.