# Appendix 2.Hormone Replacement Therapy and Cardiovascular Disease

## Hormone Replacement Therapy and Cardiovascular Disease

[image]