# Appendix 1. Search Strategies

[underlined: Hormone Replacement Therapy and Cardiovascular Disease]

1. exp hormone replacement therapy/
2. hormone replacement.tw.
3. estrogen replacement.tw.
4. exp estrogens/ad,tu
5. exp estrogens, synthetic/ad,tu
6. 1 or 2 or 3 or 4 or 5
7. exp cardiovascular diseases/
8. exp myocardial infarction/
9. heart disease$.tw.
10. cardiovascular disease$.tw.
11. (heart attack or myocardial infarct$).tw. [tw=abstract, title]
12. 7 or 8 or 9 or 10 or 11
13. 6 and 12
14. limit 13 to human
15. limit 14 to english language
16. 14 not 15
17. limit 16 to abstracts
18. 15 or 17

[underlined: HRT and Stroke Search]

1. exp hormone replacement therapy/
2. hormone replacement.tw.
3. estrogen replacement.tw.
4. exp estrogens/ad,tu
5. exp estrogens, synthetic/ad,tu
6. 1 or 2 or 3 or 4 or 5
7. exp cerebrovascular disorders/ or “stroke”.mp.
8. 6 and 7
9. limit 8 to human