# References

1 Amsel R, Totten PA, Spiegel CA, Chen KC, Eschenbach D, Holmes KK. Nonspecific vaginitis. Diagnostic criteria and microbial and epidemiologic associations. Am J Med. 1983;74:14-22. [pmid: 6600371].
2 Gravett MG, Nelson HP, DeRouen T, Critchlow C, Eschenbach DA, Holmes KK. Independent associations of bacterial vaginosis and chlamydia trachomatis infection with adverse pregnancy outcome. JAMA. 1986;256:1899-1903. [pmid: 3761496].
3 Gravett MG, Hummel D, Eschenbach DA, Holmes KK. Preterm labor associated with subclinical amniotic fluid infection and with bacterial vaginosis. Obstet Gynecol. 1986;67:229-237. [pmid: 3003634].
4 Goldenberg RL, Iams JD, Mercer BM, et al. The preterm prediction study: the value of new vs. standard risk factors in predicting early and all spontaneous preterm births. National Institute of Child Health Development Maternal-Fetal Medicine Units Network. Am J Pub Health. 1998;88:233-238. [pmid: 9491013]. [pmcid: 1508185].
5 Hillier SL, Nugent RP, Eschenbach DA, et al. Association between bacterial vaginosis and preterm delivery of a low-birth-weight infant. The Vaginal Infections and Prematurity Study Group. N Engl J Med. 1995;333:1737-1742. [pmid: 7491137].
6 Meis PJ, Goldenberg RL, Mercer B, et al. The preterm prediction study: significance of vaginal infections. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. 1995;173:1231-1235. [pmid: 7485327].
7 Hillier SL, Krohn MA, Nugent RP, Gibbs RS. Characteristics of three vaginal flora patterns assessed by gram stain among pregnant women. Vaginal Infections and Prematurity Study Group. Am J Obstet Gynecol. 1992;166:938-944. [pmid: 1372474].
8 Pastore LM, Royce RA, Jackson TPJ, Savitz DA, Kreaden US. Association between bacterial vaginosis and fetal fibronectin at 24-29 weeks' gestation. Obstet Gynecol. 1999;93:117-123. [pmid: 9916968].
9 Goldenberg RL, Klebanoff MA, Nugent R, Krohn MA, Hillier S, Andrews WW. Bacterial colonization of the vagina during pregnancy in four ethnic groups. Vaginal Infections and Prematurity Study Group. Am J Obstet Gynecol. 1996;174:1618-1621. [pmid: 9065140].
10 Kurki T, Sivonen A, Renkonen OV, Savia E, Ylikorkala O. Bacterial vaginosis in early pregnancy and pregnancy outcome. Obstet Gynecol. 1992;80:173-177. [pmid: 1635726].
11 Cristiano L, Rampello S, Noris C, Valota V. Bacterial vaginosis: prevalence in an Italian population of asymptomatic pregnant women and diagnostic aspects. Eur J Epidemiol. 1996;12:383-390. [pmid: 8891543].
12 Hillier SL, Martius J, Krohn M, Kiviat N, Holmes KK, Eschenbach DA. A case-control study of chorioamnionic infection and histologic chorioamnionitis in prematurity. New Eng J Med. 1988;319:972-978. [pmid: 3262199].
13 Carey JC, Yaffe SJ, Catz C. The Vaginal Infections and Prematurity Study: an overview. Clin Obstet Gynecol. 1993;36:809-820. [pmid: 8293583].
14 Minkoff H, Grunebaum AN, Schwarz RH, et al. Risk factors for prematurity and premature rupture of membranes: a prospective study of the vaginal flora in pregnancy. Am J Obstet Gynecol. 1984;150:965-972. [pmid: 6391179].
15 McGregor JA, French JI, Jones W, Parker R, Patterson E, Draper D. Association of cervicovaginal infections with increased vaginal fluid phospholipase A2 activity. Am J Obstet Gynecol. 1992;167:1588-1594. [pmid: 1471671].
16 Ralph SG, Rutherford AJ, Wilson JD. Influence of bacterial vaginosis on conception and miscarriage in the first trimester: cohort study. BMJ. 1999;319:220-223. [pmid: 10417083]. [pmcid: 28171].
17 Krohn MA, Hillier SL, Nugent RP, et al. The genital flora of women with intraamniotic infection. Vaginal Infection and Prematurity Study Group. J Infect Dis. 1995;171:1475-1480. [pmid: 7769281].
18 Goldenberg RL, Thom E, Moawad AH, Johnson F, Roberts J, Caritis SN. The preterm prediction study: fetal fibronectin, bacterial vaginosis, and peripartum infection. NICHD Maternal Fetal Medicine Units Network. Obstet Gynecol. 1996;87:656-660. [pmid: 8677062].
19 Gravett MG, Eschenbach DA. Possible role of Ureaplasma urealyticum in preterm premature rupture of the fetal membranes. Pediatr Infect Dis. 1986;5:S253-S257. [pmid: 3540897].
20 Watts DH, Krohn MA, Hillier SL, Eschenbach DA. Bacterial vaginosis as a risk factor for post-cesarean endometritis. Obstet Gynecol. 1990;75:52-58. [pmid: 2296423].
21 Schroder R. Zur Pathogenese und Klinik des vaginalen Fluors. Zentrabl Gynaekol. 1921;45:1350-1361.
22 Gardner HL, Dukes CD. Haemophilus vaginalis vaginitis: A newly defined specific infection previously classified “nonspecific” vaginitis. Am J Obstet Gynecol. 1955;69:962-976. [pmid: 14361525].
23 Krohn MA, Hillier SL, Eschenbach DA. Comparison of methods for diagnosing bacterial vaginosis among pregnant women. J Clin Microbiol. 1989;27:1266-1271. [pmid: 2473992]. [pmcid: 267539].
24 Spiegel CA, Amsel R, Eschenbach D, Schoenknecht F, Holmes KK. Anaerobic bacteria in nonspecific vaginitis. N Engl J Med. 1980;303:601-607. [pmid: 6967562].
25 Westrom L, Mardh PA. Definitions of infectious and infectious-like conditions in the lower genital tract of the female. Scand J Infect Dis Suppl. 1983;40:65-70. [pmid: 6582589].
26 Thomason JL, Gelbart SM, Anderson RJ, Walt AK, Osypowski PJ, Broekhuizen FF. Statistical evaluation of diagnostic criteria for bacterial vaginosis. Am J Obstet Gynecol. 1990;162:155-160. [pmid: 1689107].
27 Eschenbach DA. Bacterial vaginosis: emphasis on upper genital tract complications. Obstet Gynecol Clin North Am. 1989;16:593-610. [pmid: 2687747].
28 Spiegel CA, Amsel R, Holmes KK. Diagnosis of bacterial vaginosis by direct Gram stain of vaginal fluid. J Clin Microbiol. 1983;18:170-177. [pmid: 6193137]. [pmcid: 270763].
29 Nugent RP, Krohn MA, Hillier SL. Reliability of diagnosing bacterial vaginosis is improved by a standardized method of gram stain interpretation. J Clin Microbiol. 1991;29:297-301. [pmid: 1706728]. [pmcid: 269757].
30 Schwebke JR, Hillier SL, Sobel JD, McGregor JA, Sweet RL. Validity of the vaginal Gram stain for the diagnosis of bacterial vaginosis. Obstet Gynecol. 1996;88:573-576. [pmid: 8841221].
31 Centers for Disease Control and Prevention. 1998 guidelines for treatment of sexually transmitted diseases. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep. 1998;47:1-111. [pmid: 9450721].
32 McGregor JA, French JI, Jones W, et al. Bacterial vaginosis is associated with prematurity and vaginal fluid mucinase and sialidase: results of a controlled trial of topical clindamycin cream. Am J Obstet Gynecol. 1994;170:1048-1059. discussion 1059-1060. [pmid: 8166188].
33 Joesoef MR, Hillier SL, Wiknjosastro G, et al. Intravaginal clindamycin treatment for bacterial vaginosis: effects on preterm delivery and low birth weight. Am J Obstet Gynecol. 1995;173:1527-1531. [pmid: 7503196].
34 Platz-Christensen JJ, Pernevi P, Hagmar B, Andersson E, Brandberg A, Wiqvist N. A longitudinal follow-up of bacterial vaginosis during pregnancy. Acta Obstet Gynecol Scand. 1993;72:99-102. [pmid: 8383416].
35 McDonald HM, O'Loughlin JA, Jolley PT, Vigneswaran R, McDonald PJ. Changes in vaginal flora during pregnancy and association with preterm birth. J Infect Dis. 1994;170:724-728. [pmid: 8077737].
36 Lugo-Miro VI, Green M, Mazur L. Comparison of different metronidazole therapeutic regimens for bacterial vaginosis. A meta-analysis. JAMA. 1992;268:92-95. [pmid: 1535108].
37 Brocklehurst P, Hannah M, McDonald H. The management of bacterial vaginosis in pregnancy. Cochrane Database of Systematic Reviews. 1998.
38 Burtin P, Taddio A, Ariburnu O, Einarson TR, Koren G. Safety of metronidazole in pregnancy: a meta-analysis. Am J Obst Gynecol. 1995;172:525-529. [pmid: 7856680].
39 Caro-Paton T, Carvajal A, Martin de Diego I, Martin-Arias LH, Alvarez Requejo A, Rodriguez Pinilla E. Is metronidazole teratogenic? A meta-analysis. Br J Clin Pharmacol. 1997;44:179-182. [pmid: 9278206]. [pmcid: 2042833].
40 Committee on Obstetric Practice. American College of Obstetricians and Gynecologists (ACOG). ACOG committee opinion. Bacterial vaginosis screening for prevention of preterm delivery. Number 198. Int J Gynaecol Obstet. 1998;61:311-312. [pmid: 9688497].
41 US. Preventive Services Task Force. In: DiGuiseppi C, Atkins D, Woolf SH, Kamerow DB, eds. Guide to Clinical Preventive Services, 2nd Edition. Baltimore: Williams & Wilkins; 1996.
42 Meis PJ, Goldenberg RL, Mercer BM, et al. The preterm prediction study: risk factors for indicated preterm births. Maternal-Fetal Medicine Units Network of the National Institute of Child Health and Human Development. Am J Obstet Gynecol. 1998;178:562-567. [pmid: 9539527].
43 Vermeulen GM, Bruinse HW. Prophylactic administration of clindamycin 2% vaginal cream to reduce the incidence of spontaneous preterm birth in women with an increased recurrence risk: a randomised placebo-controlled double-blind trial. Br J Obstet Gynaecol. 1999;106:652-657. [pmid: 10428520].
44 Kekki M, Kurki T, Pelkonen J, Kurkinen-Raty M, Cacciatore B, Paavonen J. Bacterial vaginosis in pregnancy is associated with increased infectious morbidity: a randomized placebo-controlled intervention trial with vaginal clindamycin (abstract). Acta Obstet Gynecol Scand. 1997;76:(Suppl).
45 Alvi SA, Lamont RF. Pregnancy outcome following the use of clindamycin intravaginal cream. J Soc Gynecol Invest. 1999;6.
46 Hauth JC, Goldenberg RL, Andrews WW, DuBard MB, Copper RL. Reduced incidence of preterm delivery with metronidazole and erythromycin in women with bacterial vaginosis. N Eng J Med. 1995;333:1732-1736. [pmid: 7491136].
47 McDonald HM, O'Loughlin JA, Vigneswaran R, et al. Impact of metronidazole therapy on preterm birth in women with bacterial vaginosis flora (Gardnerella vaginalis): a randomised, placebo controlled trial. Br J Obstet Gynaecol. 1997;104:1391-1397. [pmid: 9422018].
48 Morales WJ, Schorr S, Albritton J. Effect of metronidazole in patients with preterm birth in preceding pregnancy and bacterial vaginosis: a placebo-controlled, double-blind study. Am J Obstet Gynecol. 1994;171:345-347. discussion 348-349. [pmid: 8059811].
49 Klebanoff M, Carey JC. Metronidazole did not prevent preterm birth in asymptomatic women with bacterial vaginosis. Am J Obstet Gynecol. 1999;180. [pmid: 10203666].
50 Carey JC, Klebanoff MA, Hauth JC, et al. Metronidazole to prevent preterm delivery in pregnant women with asymptomatic bacterial vaginosis. National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. New Eng J Med. 2000;342:534-540. [pmid: 10684911].
51 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
52 Cook RJ, Sackett DL. The number needed to treat: a clinically useful measure of treatment effect [published erratum appears in BMJ. 1995;310(6986). BMJ. 1995. 310. 452. 454. [pmid: 7873954].
53 STATA. 5 ed. College Station, TX: STATA Corporation.
54 Edwards AWF. Likelihood. Cambridge, UK: Cambridge University Press; 1972.
55 Clayton D, Hills M. Statistical Methods in Epidemiology. Oxford, UK: Oxford University Press; 1993.
56 Royal R. Statistical Evidence: A Likelihood Paradigm. London, UK: Chapman & Hall; 1997.
57 Berger JO, Lisea B, Wolpert RL. Integrated likelihood methods for eliminating nuisance parameters. Stat Sci. 1999;14:1-28.
58 Yusuf S, Peto R, Lewis J, Collins R, Sleight P. Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis. 1985;27:335-371. [pmid: 2858114].
59 Update Software. Review Manager. 3.1 ed. Oxford, UK: Update Software.
60 Rembold CM. Number needed to screen: development of a statistic for disease screening. BMJ. 1998;317:307-312. [pmid: 9685274]. [pmcid: 28622].