# Discussion

This meta-analysis found no benefit to screening and treating for BV in women at average risk for PTD. The findings for average-risk women are consistent with those of a recent Cochrane review of treatment of BV during pregnancy.^ 37 ^ We similarly found no benefit to screening all women at high risk for PTD (women who had a previous PTD) for the clinically important outcomes of PTD before 34 weeks or PPROM. The finding of benefit in some high-risk studies suggests that there may be a subgroup of high-risk women for which there is significant benefit to screening for BV during pregnancy. However, there also appears to be a subgroup of women for whom BV treatment is associated with increased rates of PTD. Although we could not define exactly which population characteristics predicted benefit from screening for BV, important considerations may be multiple previous spontaneous PTDs and timing of screening and treatment.

As noted above, timing of treatment before 16 weeks is theorized to be important to the mechanism of BV in PTD. In 3 studies,^33,45,50^ 100% of the participants were treated before 20 weeks gestation. Joesoeff et al^ 33 ^ treated 50% of the participants before 20 weeks, and Carey et al^ 50 ^ treated 33% of the participants before 18 weeks. Alvi and Lamont^ 45 ^ examined the effect of treatment timing and found a threefold reduction in overall PTD before 37 weeks when treatment was administered before 16 weeks gestation. This may also be important in defining the population of pregnant women who are likely to benefit from screening for BV.

Study intent, size, setting, population demographics, parity, screening method, or choice of antibiotic did not explain the variation in results. The discrepancies in results for high-risk studies highlight the heterogeneity even within this selected group and emphasize the need for further research into factors that predict the effect of BV on pregnancy outcomes.

## Summary of Benefits and Harms

Table 3 summarizes our estimates of the consequences of screening for BV in 1,000 patients at high risk for PTD from the general high-risk population and in 1,000 patients at more-selected high risk for PTD. The first group represents untreated women who have BV, a history of previous preterm birth, and a 23% risk of PTD before 37 weeks versus a 14% risk in untreated women who did not have BV. This base case for the general high-risk population incorporates the mean and the 90% confidence limits of the effect sizes from the NICHD study for the listed outcomes.^ 50 ^ The second group represents a more-selected high-risk group of untreated women who have BV, a history of previous preterm birth, and a 50% risk of PTD before 37 weeks versus a 31% risk in untreated women who did not have BV. This group simulates the samples in the 3 high-risk studies in which the rate of PTD before 37 weeks in the placebo group with BV was known.^46-48^

Table 3. Summary of Benefits and Harms of Screening 1,000 High-Risk Pregnant Women for BV

Benefit and Relevant Factors | General High-Risk Group* | More-Selected High-Risk Group ^†^
Assumptions
Proportion of pregnant women who meet screening criteria | 0.10 | 0.03
Prevalence of BV in population | 0.25 | 0.25
Relative risk of PTD in BV patients | 1.60 | 1.60
Sensitivity of screening test | 0.95 | 0.95
Specificity of screening test | 0.95 | 0.95
Adherence to treatment | 0.80 | 0.80
Effect sizes, patients (probability: control vs treated group [CI])^‡^
PTD <37 wk | −0.075 (−0.19 to 0.04) | 0.22 (0.13 to 0.31)
PPROM | −0.04 (−0.101 to 0.03) | 0.29 (0.15 to 0.43)
PTD <34 wk | 0.012 (−0.06 to 0.08) | 0.06 (0.01 to 0.15)
Effect sizes, patients without BV (probability: control versus treated group)^‡^
PTD <37 wk | 0 | 0
PPROM | 0 | 0
PTD <34 wk | −0.02 | −0.06
Results (n)
Patients who have unsuspected BV | 250 | 250
Patients correctly diagnosed as having BV | 238 | 238
BV patients who complete therapy | 190 | 190
BV patients with missed diagnosis | 13 | 13
Patients incorrectly diagnosed as having BV | 38 | 38
Outcomes^‡^
Decrease or increase in PTD <37 wk (CI) | −14 (−36 to 7) | 42 (25 to 59)
Decrease or increase in PPROM | −8 (−19 to 4) | 49 (28 to 70)
Decrease or increase in PTD <34 wk | 2 (−11 to 14) | 9 (−2 to 19)

BV indicates bacterial vaginosis; PTD, preterm delivery; CI, confidence interval; PPROM, preterm premature rupture of membranes.

*Screen all women who have at least 1 previous PTD.

†Screen if there is more than 1 previous PTD or other risk factors.

‡Minus sign indicates a net increase, plus indicates a net decrease, in adverse effects.

In the base case, we assumed that treatment of BV reduces the risk of adverse pregnancy outcomes of high-risk women to that of BV-negative women (ie, the maximum plausible effect) as well as that a worst-case situation in which the lower 90% confidence limit of the pooled estimate of the effect size was used. In both situations we also assumed that metronidazole therapy might be associated with a higher rate of PTD before 34 weeks in high-risk patients who do not have BV, because results from the only trial that examined this effect revealed a clinically and statistically significant harmful effect.^ 46 ^ We also assumed that the screening test has a sensitivity of 95% and a specificity of 95%, that the prevalence of unsuspected BV is 25%, and that adherence to treatment is 80%.

In the general high-risk population of 1,000 women screened, 238 are correctly diagnosed to have BV, and 190 of these completed therapy. With screening and treatment there would be 14 additional PTDs before 37 weeks (90% CI, 7 fewer to 36 additional cases), 8 additional cases of PPROM (90% CI, 4 fewer to 19 additional cases), and 2 fewer PTDs before 34 weeks (90% CI, 14 fewer to 11 additional cases).

In the second, more-selected high-risk group, screening and treatment results in 42 fewer PTDs before 37 weeks (90% CI, 25 to 59), 49 fewer cases of PPROM (90% CI, 28 to 70), and 9 fewer cases of PTD before 34 weeks (90% CI, 19 fewer to 2 more cases) per 1,000 women screened. For every 111 patients screened, 1 case of PTD before 34 weeks would be prevented; likewise, 1 case of PTD at less than 37 weeks would be prevented for every 24 (90% CI, 17 to 40) patients screened. Because we assumed that there is a potential increase in PTD before 34 weeks in BV-negative patients, the effect of screening on PTD before 34 weeks is moderately sensitive to changes in the accuracy of the screening test. In the more-selected high-risk group, for example, screening and treatment result in an increase in PTD before 34 weeks if the specificity of the screening test for BV is less than 80% (not shown).

## Literature Limitations

There are several issues of generalizability to consider in determining whether screening and treating for BV may be useful for one's patients. First, all U.S. studies were conducted in tertiary referral centers or public health clinics and may not be generalizable to community-based practices. Second, screening methods used in research studies may not reflect those employed in everyday practice. One technique frequently used in clinical practice is screening by identification of clue cells alone. No studies of BV treatment have looked at the effectiveness of treatment in women who have been identified as having BV by this criterion alone. Third, we defined patients as asymptomatic if they were most likely identified through routine prenatal care and were not presenting for evaluation of BV symptoms. However, the details for identification of patients were not explicitly stated in 2 studies.^46,48^ Consequently, it is possible that women presenting for evaluation of BV symptoms were also included. The women who had symptomatic BV may represent a different risk category for adverse pregnancy outcomes and therefore may be an important consideration.

## Future Research Needs

### Timing

The studies included in this review varied in their approaches to screening and treatment, which may have contributed to variation in results. Because BV has both a high rate of spontaneous resolution and a high recurrence rate after treatment, studies are needed to clarify the optimum timing of screening and treatment of BV during pregnancy and to determine how different treatment regimens affect pregnancy outcomes. Information is needed on when to screen during pregnancy, how often to screen, and the duration and the frequency of treatment.

### Treatment Regimen and Length

Treatment regimens varied across the studies in this review. More research is needed on the most effective combination and length of treatments of BV and their differential effects on pregnancy outcomes. Although all the trials showed effectiveness in curing BV, these results apply only to eradication of BV from the lower genital tract. Systemic treatments that affect the upper genital tract should be studied further for their effects on adverse pregnancy outcomes.

### Identifying Subgroups of High-Risk Patients Who May Benefit From Treatment

Randomized trials show no benefit of treatment in average-risk women and are unclear as to the benefit in high-risk women. Further characterization of the population most likely to benefit, if any, is needed. In addition, the optimum timing of screening and treatment to determine the effect of treatment regimens on pregnancy outcomes needs investigation. Particular attention should be paid to the potential adverse effects of treatment of BV during pregnancy.