# Results

Table 1 summarizes design features of the 7 RCTs included in this review.^32,33,43,46-48,50^ The studies varied in diagnostic methods, setting, populations, route, duration, timing, and vehicle of antibiotic therapy. Of the 7 studies, 3 were conducted outside the United States.^33,43,47^ The NICHD study,^ 50 ^ a multicenter trial of several university centers (University of Alabama at Birmingham, University of Pittsburgh, University of Tennessee at Memphis, University of Chicago, Bowman Gray School of Medicine at Wake Forest University, University of Miami, University of Texas at San Antonio, University of Texas Southwestern Medical Center, University of Utah, Thomas Jefferson University, Ohio State University, University of Cincinnati, Wayne State University, University of Oklahoma, and Medical University of South Carolina) sought to address the benefit of treatment of BV in pregnant women both at average and at high risk for PTD. This is the largest U.S. trial and was the first U.S. study that prospectively examined high-risk patients in addition to average-risk patients. The study that provided data most reflective of community practice was conducted in Australia.^ 47 ^ The 4 studies conducted in the United States were conducted in tertiary referral clinics and public health clinics.

Table 1. Descriptive Features and Effect Sizes of Included Studies

Study, Year (Jadad^ 51 ^ Score*) | Number Completed/Enrolled | Screening Method and Timing (Weeks' Gestation) | PTD <37 wk | PTD <34 wk | PTD <32 wk | PPROM | LBW <2500 g
Study, Year (Jadad^ 51 ^ Score*) | Number Completed/Enrolled | Screening Method and Timing (Weeks' Gestation) | ARR** (90% CI) | ARR** (90% CI) | ARR** (90% CI) | ARR** (90% CI) | ARR** (90% CI)
Average-risk women
McGregor et al,^ 32 ^ 1994 (3) | 129/142 | Gram stain + Amsel (16-27) | −0.077 (−0.169 to 0.014) | | | −0.006 (−0.068 to 0.056) | −0.092 (−0.176 to −0.008)
Joesoef et al,^ 33 ^ 1995 (4) | 681/745 | Gram stain (14-26) | −0.015 (−0.059 to 0.029) | | −0.021 (−0.044 to 0.003) | | −0.021 (−0.056 to 0.012)
McDonald et al,^ 47 ^ 1997 (4) | 480/480 | Gram stain (16-26) | .0166 (−0.016 to 0.052) (spontaneous only) | | | 0.0017 (−0.010 to 0.044) | −0.003 (−0.034 to 0.027)
Carey et al,^ 50 ^ 2000 (5) | 1919/1953 | Gram stain (16-23) | 0.030 (−0.021 to 0.028) | | 0.004 (−0.008 to 0.016) | −0.014 (−0.028 to 0.000) | .005 (−0.019 to 0.029)
High-risk women
Morales et al,^ 48 ^ 1994 (4) | 80/94 | Amsel (16-20) | 0.263 (0.096 to 0.429) | 0.066 (−0.035 to 0.166) | | 0.288 (0.149 to 0.427) | 0.197 (0.042 to 0.362)
Hauth et al,^ 46 ^ 1995 (4) | 177/177 | Amsel (< 24) | 0.183 (0.052 to 0.314)
McDonald et al,^ 47 ^ 1997 (4) | 34/34 | Gram stain (16-26) | 0.294 (0.082 to 0.507) | 0.118 (−0.061to 0.296) | | 0.176 (0.024 to 0.329) | 0.235 (0.005 to 0.465)
Carey et al,^ 50 ^ 2000 (5) | 210/213 | Gram stain (16-23) | −0.075 (−0.189 to 0.039) | 0.012 (−0.055 to 0.078) | | −0.036 (−0.101 to 0.030) | −0.040 (−0.137 to 0.057)
Vermeulen and Bruinse^ 43 ^ 1999 (4) | 22/22 | Gram stain (<26) | | 0.000 (−0.202 to 0.202)

PTD indicates preterm delivery; PPROM, preterm premature rupture of membranes; LBW, low birth weight; ARR, absolute risk reduction; CI, confidence interval.

*Measures quality of randomized controlled trials on a 5-point scale.

**Negative value indicates that outcome was more common in treated group than in controls (ie, adverse effect of treatment).

Women who had significant maternal medical complications were generally excluded from all studies. Some studies excluded women who had other infectious diseases, whereas others screened and treated for infectious diseases such as asymptomatic bacteriuria, group B Streptococcus, or sexually transmitted diseases.

After manuscript review and discussions with authors and by use of the Jadad criteria, we judged all studies to be of generally good quality. Study scores were as follows: One study^ 50 ^ received a score of 5; 5 studies^33,43,46-48^ received a score of 4 because of inadequate description of dropouts; and 1 study^ 32 ^ received a score of 3 for inadequate description both of the randomization method and of the dropouts.

Gram stain was used as the primary screening test in 5 studies (3 in which the criteria of Nugent et al^ 29 ^ were used and 1 in which the criteria of Spiegel et al^ 24 ^ were, and the criteria of Amsel et al^ 1 ^ were used in 2 studies. In addition to Gram stain, the NICHD study ^ 50 ^ added vaginal pH >4.5 as another criterion for diagnosis.

The choice of antibiotic, route of administration, duration and timing of treatment, and compliance with medication might influence the effect of therapy on adverse pregnancy outcomes. Oral metronidazole alone was used in 3 trials,^47,48,50^ oral metronidazole plus erythromycin was used in 1 trial,^ 46 ^ and intravaginal clindamycin alone was used in 3 trials.^32,33,43^ The measurement for eradication of BV, used in 5 of the 7 studies, was a negative test of cure at 4 to 7 weeks. Treatment was effective in eradicating BV in 3 of the 5 studies reporting these results. The 2 studies in which metronidazole was used^46,50^ pooled with a difference in probability of 0.49; however, the study in which vaginal clindamycin was used remained separate, with a difference in probability of 0.30.^ 33 ^

The trials varied with regard to treatment timing and regimen. Timing of initial treatment varied widely: between 16 and 24 weeks (Carey et al^ 50 ^), at 24 weeks (McDonald et al^ 47 ^), at 13 to 20 weeks (Morales et al^ 48 ^), at 22 to 24 weeks (Hauth et al^ 46 ^), at 14 to 26 weeks (Joesoef et al^ 33 ^), at 16 to 27 weeks (McGregor et al^ 32 ^), and at 26 weeks (Vermeulen and Bruinse^ 43 ^). In 3 studies, participants were given only 1 course of treatment.^32,33,48^ In 2 studies, women were treated 2 to 4 weeks after initial treatment only if they were found to be BV positive at follow-up screening.^46,47^ In contrast, NICHD^ 50 ^ and Vermeulen and Bruinse^ 43 ^ repeated treatment regardless of presence of BV on follow-up examination.

Compliance and side effects were not reported in all trials. Compliance rates were reported from 3 of the 4 metronidazole trials and from 1 of the 3 clindamycin trials. Carey et al^ 50 ^ reported that 3 or more doses were taken by 79% of women in the metronidazole group and 82% of women in the placebo group. Hauth et al^ 46 ^ reported that compliance with medication in the metronidazole-erythromycin group for the first and the second treatment was 65% and 71%, respectively, and in the placebo group, 72% and 75%, respectively. Morales et al^ 48 ^ reported that 6/94 (6%) patients failed to complete metronidazole treatment. Vermeulen and Bruinse^ 43 ^ reported 84% compliance with vaginal clindamycin versus 85% compliance in the placebo group. Joesoef et al^ 33 ^ monitored compliance, but did not report rates. McGregor et al^ 32 ^ followed only those women who completed 7 days of clindamycin treatment. They reported that 13/142 (9%) of the women were lost to follow-up.

Medication side effects were reported in 3 studies,^33,43,47^ 1 in which oral metronidazole was used and 2 in which intravaginal clindamycin was used. In the study conducted by McDonald et al,^ 47 ^ 27/429 (6%) women reported side effects of metronidazole treatment in the active group, compared with 16/428 (4%) in the placebo group. The most common side effects were nausea and vomiting (3%). A meta-analysis of the safety of metronidazole treatment^ 36 ^ found 2 studies that reported the incidence of yeast vaginitis after treatment. Rates were 12% to 25%, with variation according to treatment regimen. Joesoef et al^ 33 ^ notes that 2.7% of women in the clindamycin group and 1.8% in the placebo group reported vulvar or vaginal irritation. Vermeulen and Bruinse^ 43 ^ reports 1 case of yeast vaginitis in both the placebo and the clindamycin groups and 3 complaints of troublesome discharge in the clindamycin group. None of the RCTs of women at average or at high risk reported sufficient information on neonatal sepsis, endometritis, or spontaneous abortion to allow inclusion of these outcomes in the meta-analysis.

## Does Treatment of BV Reduce Adverse Pregnancy Outcomes in the General Population of Pregnant Women (Average Risk)?

Results for pregnancy in average-risk women were reported in 4 studies.^32,33,47,50^ None of the 4 studies found significant differences between the control and the treatment groups in any of the pregnancy outcomes studied . There was no evidence of heterogeneity among the results of these studies. There was no difference between treatment and placebo groups in the rate of PTD before 37 weeks (pooled ARR 0.001, 90% CI, −0.017 to 0.019). Spontaneous PTD before 37 weeks was separately reported in 2 studies.^47,50^ In one study there was a suggestion of benefit (ARR 0.02, 90% CI, −0.02 to 0.06), but in the other and in the pooled result, there was not (pooled ARR 0.00). We performed a sensitivity analysis to determine the effect of including data from the 2 abstracts (Kekki et al^ 44 ^ and Alvi and Lamont.^ 45 ^) excluded for insufficient data. Data were available only for PTD before 37 weeks. Both studies used clindamycin. The addition of the data from Kekki et al^ 44 ^ did not change the pooled estimate of effect (ARR 0.0, 90% CI, −0.01 to 0.02). The Alvi and Lamont^ 45 ^ data, which showed a trend toward benefit to treatment, was not sufficiently similar to the other studies to allow pooling (ARR 0.05, 90% CI, −0.004 to 0.102).

PTD before 34 weeks was not reported in any of the studies of average-risk women; however, results for PTD before 32 weeks were reported in 2 studies.^33,50^ Neither of these had a significant effect, and the pooled difference in probability was 0.0. The study in which clindamycin was used^ 33 ^ had a nonsignificant trend, indicating potential harm of treatment.

Rates of PPROM were reported in 3 studies^32,47,50^ of average-risk women; 2 studies had sufficiently similar results that allowed pooling and showed harm (pooled ARR −0.014, 90% CI, −0.027 to 0.000).^32,50^ Results from McDonald et al^ 47 ^ did not pool with the other studies and showed no benefit (ARR 0.017, 90% CI, −0.010 to 0.044). Three of the 4 studies reporting low birth weight^33,47,50^ showed no benefit (pooled ARR −0.004; 90% CI, −0.020 to 0.013), whereas one^ 32 ^ suggested harm (ARR −0.092, 90% CI, −0.176 to −0.008).

## Does Treatment of BV Reduce Adverse Pregnancy Outcomes in Women at High Risk for Preterm Delivery?

Results for high-risk patients were reported in 5 studies.^43,46-48,50^ The first of these studies^ 48 ^ examined the efficacy of oral metronidazole between 16 and 20 weeks of gestation in 80 women who had BV and a previous PTD from either PPROM or idiopathic preterm labor. It was conducted in a high-risk obstetric clinic. Patients who had symptomatic BV were not explicitly excluded. The second trial, Hauth et al,^ 46 ^ included 177 patients who had BV and a history of spontaneous PTD; these patients were from several public health clinics in Jefferson County, Alabama. Patients who had symptomatic BV were not specifically excluded. The third trial, McDonald et al,^ 47 ^ included 34 patients who had BV and a history of spontaneous PTD; it explicitly excluded symptomatic patients. The fourth trial, Vermuelen and Bruinse,^ 43 ^ included 22 patients who had spontaneous PTD in their last pregnancy and who had BV. The fifth trial, Carey et al,^ 50 ^ was the NICHD Maternal-Fetal Network Study, which focused exclusively on asymptomatic patients and consisted of 210 patients who had BV and a history of spontaneous PTD.

Results for PTD before 37 weeks were reported in 4 studies (Figure 4).^46-48,50^ In the stepwise pooling procedure, 3 of these studies with statistically significant benefit ranging from ARR 0.183 to 0.294 (Table 1) were homogeneous (Hauth et al,^ 46 ^ 1995; Morales et al,^ 48 ^ 1994; and McDonald et al,^ 47 ^ 1994), but the NICHD trial,^ 50 ^ which showed no benefit, (ARR −0.075, 90% CI, −0.189 to 0.039) remained separate. The 3 homogeneous studies had a mean pooled ARR of 0.22 (90% CI, 0.13 to 0.31), indicating 22 fewer PTDs at less than 37 weeks per 100 patients treated (Figure 5). Data for spontaneous PTD before 37 weeks were provided by 2 studies.^46,47^ In these studies, the mean pooled ARR was 0.208 (90% CI, 0.096 to 0.321). The smaller study, with a total sample size of 34, showed a stronger benefit.^ 47 ^

Figure 4. Individual results of four studies reporting rates of preterm delivery (PTD) before 37 weeks in high-risk patients. The measure of effect is a difference in probability of benefit from control minus treatment (absolute risk reduction, ARR). The width of the curve indicates the precision of the estimate and is used to calculate 90% confidence intervals

Figure 5. Pooled results of four studies reporting rates of preterm delivery (PTD) before 37 weeks in high-risk patients. The pooled absolute risk reduction for Hauth et al^ 46 ^, McDonald et al^ 47 ^ and Morales et al^ 48 ^ was 0.22 (90% CI, 0.13 to 0.31), indicating 22 fewer PTDs before 37 weeks per 100 patients treated. One study, Carey et al^ 50 ^, was dissimilar from the others and did not pool. In that study, the ARR was −0.075 (90% CI, −0.189 to 0.039), indicating seven additional PTDs before 37 weeks per 100 patients treated

Four studies reported PTD or spontaneous PTD before 34 weeks.^43, 47,48,50^ Of the 4 studies reporting results on this outcome, none showed statistically significant improvement in the treatment group (pooled ARR 0.036, 90% CI, −0.021 to 0.092) (Figure 6). The study that showed the trend toward greatest benefit also had the least precision because of small sample size (17 patients in each group).^ 47 ^

Figure 6. Pooled results of four studies reporting rates of preterm delivery (PTD) before 34 weeks in high-risk patients. None of the four studies reported a statistically significant decrease in PTD before 34 weeks with treatment, and their pooled effect was not statistically different from zero (0.036, 90% CI, −0.021 to 0.092)

Three studies reported results on PPROM.^47,48,50^ Results from the study by Morales^ 48 ^ showed the greatest benefit (ARR 0.288, 90% CI, 0.149 to 0.427). McDonald et al^ 47 ^ reported an ARR of 0.176 (90% CI, 0.024 to 0.329), whereas Carey^ 50 ^ showed no benefit, with an ARR of −0.036 (90% CI, −0.101 to 0.030). Results from studies by McDonald et al^ 47 ^ and Morales et al^ 48 ^ were sufficiently similar to pool with a pooled ARR of 0.259 (90% CI, 0.149 to 0.369). A similar trend across studies was found for low birth weight less than 2,500 g. Results on this outcome were reported in 3 studies,^47,48,50^ with 2 studies^47,48^ suggesting a benefit to treatment (pooled ARR 0.206, 90% CI, 0.078 to 0.335) and 1 study^ 50 ^ suggesting potential harm (ARR −0.040, 90% CI, −0.137 to 0.057).

## Do Study Characteristics Explain the Different Results of Heterogeneous Studies?

We examined all high-risk studies for factors that could explain variation and possibly define a subgroup of high-risk patients that appeared to respond favorably to treatment of asymptomatic BV (see Table 2). These factors included baseline PTD rate in the placebo group, whether the study intended a priori to examine high-risk patients, number and immediacy of previous PTDs, and therapeutic issues such as choice of antibiotic, route of delivery, timing of treatment during pregnancy, and duration of therapy.

Table 2. Overview of Studies of High-Risk Pregnant Women

Factor | Carey^ 50 ^ | McDonald^ 47 ^ | Hauth et al^ 46 ^ | Morales et al^ 48 ^ | Vermuelen and Bruinse^ 43 ^
PTD <37 wk, placebo | 23% | 35% | 57% | 39%
GA (wk) at treatment | 16-24 | 24 | 22-24 | 13-20 | 26
Treatment | Oral metronidazole 2 g, repeat at 48 h | Oral metronidazole 400 mg bid, 2 d | Oral metronidazole 250 mg tid, 7 d, plus oral erythromycin 333 mg tid, 14 d | Oral metronidazole 250 mg tid, 7 d | Clindamycin 2% vaginal cream daily, 7 d
Second treatment | All, 24-29 wk | If positive test, 4 wk post-treatment | If positive test, at 28 wk | No second treatment | All, 32 wk

PTD indicates preterm delivery; GA, gestational age.

The most striking difference among studies was their variation in PTD rates before 37 weeks in the placebo groups. The NICHD study,^ 50 ^ at 23% had the lowest rate, followed by the studies of McDonald et al^ 47 ^ at 35%, Morales et al^ 48 ^ at 39%, and Hauth et al^ 46 ^ at 57%. It was not possible to calculate the PTD rate for BV patients for Vermeulen and Bruinse,^ 43 ^ although the PTD rate among the entire high-risk group (those who had and did not have BV) was 21%. The results from Carey et al^ 50 ^ may have portrayed the experience for general high-risk patients, whereas McDonald et al,^ 47 ^ Morales et al,^ 48 ^ and Hauth et al^ 46 ^ may have identified a more-selected high-risk group that was more likely to benefit from BV treatment. However, the factor that defined this subgroup of high-risk women is not known.

Of the 5 studies, only 3 intended a priori to study women at high risk for PTD prospectively.^43,46,48^ In the others, post hoc analyses were performed on subgroups of high-risk women. The population of high-risk women studied was not large in any of these studies. The largest sample size was that of Carey et al^ 50 ^ (210), followed by Hauth et al^ 46 ^ (177), Morales et al^ 48 ^ (80), McDonald et al^ 47 ^ (34), and Vermeulen and Bruinse^ 43 ^ (22). The percentage of high-risk patients was 100% in the studies by Morales et al^ 48 ^ and by Vermeulen and Bruinse,^ 43 ^ 38% in the study by Hauth et al,^ 46 ^ 10.9% in the study by Carey et al,^ 50 ^ and 5.4% in the study by McDonald et al.^ 47 ^

In the Morales et al^ 48 ^ study, which had one of the highest effect sizes, indicating the greatest benefit of treatment, approximately 50% of the study participants reported more than 1 previous PTD. The other studies did not provide data on the number of previous PTDs in their populations, so it is not possible to compare them on this factor. The study by Morales et al^ 48 ^ was also the only study that specifically included only patients who had a PTD in their last pregnancy, whereas the other trials included women who had a PTD in any previous pregnancy.

There were considerable differences among antibiotic(s) choice, administration route, therapy duration, and treatment timing during pregnancy. Because each study differed in therapeutic regimens, we could not determine if these differences explained differences in results.

## What Adverse Effects Does the Treatment of BV Have on Pregnancy Outcomes?

Adverse effects were examined in 2 studies^43,46^ of BV treatment on BV-negative women, and both found increased rates of PTD before 34 weeks in the treated groups. Hauth et al^ 46 ^ randomized high-risk patients to BV treatment regardless of BV screening status, resulting in the treatment of a subgroup of women who did not have BV. Women who did not have BV and who were treated with antibiotics had an increased rate of PTD before 34 weeks (13.4%) compared with women who did not have BV and who were not given antibiotics (4.8%). Similarly, Vermeulen and Bruinse^ 43 ^ found an increased rate of PTD before 34 weeks in women who did not have BV and who were treated with antibiotics (12.5%) versus women who did not have BV and who were not given antibiotics (4.1%). Additionally, Vermeulen and Bruinse^ 43 ^ reported a statistically significant increase in neonatal sepsis rates in the treated BV-negative group (0% versus 8%, p<0.05). We do not know what proportion of the NICHD^ 50 ^ patients were BV negative at the time of second treatment.