# Methods

## Literature Search Strategy

We searched the MEDLINE database for the years 1966 to 1999 for evidence on the key questions in our analytic framework (see Appendix 1 for the search strategy). We also used the Cochrane Library, reference lists of relevant reviews, and expert recommendations to identify additional papers. The search was updated monthly during the course of the project. We included only RCTs of BV treatment during pregnancy that contained data on pregnancy outcomes and sufficient detail on subjects and methods to allow interpretation of results (Figure 3). The search identified 1,253 abstracts, 486 of which were included as possibly relevant. Of these, 178 were reviews, letters, or editorials, some of which we read for background and contextual information. Of the remaining 308 citations, 129 were about treatment of BV, and of these, 28 were about treatment during pregnancy. Full-text articles (if published) of these 28 studies were read to identify 12 RCTs, 11 in full text and 1 in abstract form. Because they did not contain data on pregnancy outcomes, 5 of the 12 were excluded and 1 was excluded because subjects were all hospitalized for preterm labor. One published study with complete data was identified from expert peer review.^ 43 ^ Experts in the field identified 2 additional studies^44,45^ in abstract form with preliminary data,^44,45^ for a total of 9 RCTs identified, 6 full-text^32,33,43,46-48^ and 3 abstracts.^44,45,49^ The National Institute of Child Health and Human Development (NICHD) Maternal-Fetal Medicine Network study,^ 49 ^ 1 of the 3 trials published in abstract form at the time of initial data analysis,^ 49 ^ was subsequently published in full manuscript form in March 2000.^ 50 ^ We updated our analyses using the most recent data from this study. The other 2 studies^44,45^ were not available in manuscript form. These studies were excluded because we could not obtain sufficient information, through the abstracts or by contact with study authors, to assess study quality or to interpret results. For example, 1 of these studies did not provide an explicit definition of low risk,^ 44 ^ and 1 provided no description of the patient population.^ 45 ^ We did, however, perform a sensitivity analysis including the data from these 2 studies. Excluded trials are listed in Appendix 2.

Figure 3. Literature search: inclusion criteria

## Literature Synthesis and Preparation of Systematic Evidence Review

### Data Abstraction

Using a standardized form, 2 reviewers independently abstracted the following descriptive data from RCTs: population and setting, prevalence of BV in the sample, treatment regimen, type of control, diagnostic test for BV, timing of screening and treatment, comorbidities such as group B Streptococcus, or gonorrhea, follow-up and compliance rate, outcomes reported, exclusion criteria, and any potential biases or confounders. We also recorded event rates for the following outcomes: BV eradication as measured by negative test of cure; PTD before 37 weeks and spontaneous PTD before 37 weeks; PTD and spontaneous PTD before 34 weeks; PTD before 32 weeks, PPROM, low birth weight (<2,500 g), spontaneous abortion, postpartum endometritis, and neonatal sepsis.

Of the average-risk studies, 2 reported results for a subgroup of high-risk patients,^47,50^ defined by the study authors as patients who had at least 1 previous PTD. In 3 studies, high-risk patients were the exclusive focus.^43,46,48^ We contacted authors of all studies that included high-risk patients to obtain data on outcomes that had not been reported. Data were entered into a spreadsheet program. The scoring system developed by Jadad and colleagues^ 51 ^ was used to summarize the quality of methods for randomization, masking, and handling of dropouts and withdrawals.

### Data Analysis

For each study we measured the effect of treatment by calculating the difference in the rate of a pregnancy outcome in the control group minus the treatment group. This difference, also known as the absolute risk reduction (ARR), can be converted to a number needed to treat by taking its inverse.^ 52 ^ Using STATA software,^ 53 ^ we applied a stepwise procedure based on the profile likelihood^54-57^ to assess heterogeneity, to pool studies when appropriate, and to calculate the mean and the 90% CIs for the pooled ARR (see Appendix 3 for a more-detailed description of this method). The stepwise procedure can result either in clusters of studies with similar results or in 1 cluster in which all studies have similar results. This method was chosen because of its robustness in simultaneously presenting estimates of treatment effect and precision of the estimate in cases with few studies. Studies (profiles) were considered sufficiently similar to allow pooling if their combined profile was consistent with the hypothesis that their true effect sizes were equal at the greater than or equal to 0.10 (two-sided) level. ORs were also calculated for the studies and pooled with the standard Peto method, as described by Yusuf et al,^ 58 ^ using RevMan software.^ 59 ^ Only the results from the profile method are reported. To provide a clinical interpretation of the results, we used estimates derived from both the meta-analysis and a systematic review of studies of screening for BV conducted by the authors and then constructed a balance sheet that summarizes the benefits and harms of screening for BV in 1,000 high-risk women.^ 60 ^