# Introduction

Bacterial vaginosis (BV) has been identified in high-quality epidemiologic studies to be an independent risk factor for preterm delivery (PTD). PTD is associated with respiratory, neurologic, and developmental abnormalities in the newborn that might result in death or in long-term disability. BV involves an imbalance in the vaginal bacterial ecosystem, such that hydrogen peroxide-producing Lactobacilli are diminished and Gardnerella, anaerobes, and Mycoplasma species are abundant. Although the exact organism(s) responsible for the symptoms and sequelae of BV is unknown, the prevailing hypothesis is that abnormal vaginal flora ascend and infect the upper reproductive tract, causing premature birth.

Certain features of BV support the feasibility and potential benefit of screening: BV is common, it can be diagnosed quickly and inexpensively during routine pelvic examination, and it is strongly associated with adverse pregnancy outcomes in epidemiologic studies. Approximately 50% of the women who have BV are asymptomatic.^1-3^ Once diagnosed, the microflora imbalance can be altered with a short course of antibiotic therapy. However, despite intense interest in early detection and treatment of BV to reduce neonatal mortality and morbidity, randomized trials of treatment of BV during pregnancy have had disparate results.

## Burden of Suffering and Epidemiology

### Prevalence of Disease

The prevalence of BV among pregnant women depends on several factors, including the clinical setting, sociodemographic factors, diagnostic criteria, and timing of testing for BV. Most data on the prevalence of infection come from studies of women who are of predominantly low-socioeconomic status seen at academic medical centers or public hospitals. In several large, multicenter, prospective, longitudinal studies performed in these settings, the prevalence of BV was 9% to 23%.^4-8^ In the Vaginal Infections and Prematurity (VIP) study, performed from 1984 to 1989 with 13,747 pregnant women at 7 urban US academic medical centers, 23% of black women and 9% of white women had BV.^ 9 ^

The prevalence of BV in pregnant women seen in community settings is not well studied, and there are no population-based studies of prevalence in the United States. A Finnish study^ 10 ^ found a prevalence of 21.4% among 790 unselected, healthy, nulliparous women seen at an urban prenatal clinic; sociodemographic factors such as occupation and education did not affect the prevalence.In report from Italy of 1,441 asymptomatic pregnant women, representing 30% of all pregnancies in a defined geographic area, a prevalence of 4.9% was found.^ 11 ^

### BV and Pregnancy Outcomes

In the 1980s, well-done case-control studies demonstrated an association between BV and adverse pregnancy outcomes.^ 12 ^ Since then, 2 large, prospective, longitudinal, multicenter cohort studies,^4-6,13^ as well as several smaller studies,^3,10,14^ have confirmed these associations.

The VIP study assessed BV status and pregnancy outcomes in 10,397 women seen at 7 academic centers. Among women who had BV, the risk of PTD of an infant weighing less than 2,500 was 6.3%, versus 4.2% [odds ratio (OR) 1.5, 95% confidence interval (CI), 1.2-1.9)] among women who did not have BV.^ 5 ^

The Preterm Prediction study, in which 2,929 pregnancies at 10 centers were observed, reported rates of spontaneous PTD at 37, 35, and 32 weeks.^ 4 ^ In univariate analysis, BV was significantly associated with spontaneous PTD before 32 weeks. Among 678 patients who had BV, 3.2% had PTD before 32 weeks versus 1.2% among 2,222 women who did not have BV [relative risk (RR) 2.7, 95% CI, 1.6-4.6)]. The association was smaller for PTD before 35 weeks (5.5% versus 4%, RR 1.4, 95% CI, 0.9-;2.0) and for PTD before 37 weeks (12.3% versus 9.8%, RR 1.3, 95% CI, 0.98-1.6).

The Finnish study^ 10 ^ referred to above was conducted in a population free from many of the other risk factors for BV or PTD, such as black race, low-socioeconomic status, and previous pregnancies, and thus emphasizes BV as an independent risk factor even for women at low risk for PTD. In this community-based cohort study of 790 healthy nulliparous women, 6.8% of women who had BV had PTD before 37 weeks, compared with 1% who did not have BV (OR 6.9, 95% CI, 2.5-18.8). The association was stronger for preterm (before 37 weeks) premature rupture of membranes (PPROM) [3.7% in women who had BV versus 0.5% in women who did not have BV (OR 7.3, 95% CI, 1.8-29.4)]. These epidemiologic findings support the role for BV as a risk factor for PTD among women at low risk for PTD.

BV is also a risk factor for spontaneous abortion (RR 1.3 - 2.03),^15,16^ intra-amniotic infection (RR 1.5 - 1.7),^17,18^ PPROM (RR 2.0-7.3),^10,19^ and preterm labor (RR 2.0-2.6).^ 3 ^ In a cohort of 462 patients from a university setting nested within the VIP study, 55% of women who had BV experienced postcesarean endometritis versus 17% of women who did not have BV during pregnancy (adjusted OR 5.8, 95% CI, 3.0-10.9).^ 20 ^

The exact mechanism by which BV affects pregnancy outcomes is not known, but these epidemiologic studies lend credence to the hypothesis that BV is part of an ascending infection causing PTD. According to this theory, BV starts as a local vaginal bacterial infection, which then leads to a deciduitis, then possibly to intra-amniotic infection (amnionitis). This deciduitis or amnionitis increases inflammatory cytokines such as interleukin (IL)-1 and tumor necrosis factor and then releases either prostaglandins known to cause uterine contractions or proteases that may lead to PPROM. It is commonly believed that this inflammatory-immunologic relation is established early during pregnancy and consequently that early timing of treatment may be particularly important.

## Health Care Interventions

### Evolution of Nomenclature and Accuracy of Screening Tests

In 1921, using Gram stain, Schroder^ 21 ^ identified 3 distinct levels of vaginal flora, 1 of which was nonspecific “vaginitis,” a condition with few Lactobacillus and abundant anaerobes. Little attention was given to this common syndrome until 1955, when Gardner and Dukes^ 22 ^ performed a landmark study of 602 obstetric and 579 gynecologic patients presenting to one clinician's office with symptoms of vaginitis or “gross evidence of vaginitis on inspection.” They found that 127 of 138 women who had clinical “bacterial vaginitis” were culture positive for Haemophilus vaginalis, leading them to conclude that it was the specific bacteria responsible for nonspecific bacterial vaginitis. After several changes in taxonomy, in 1980 the organism was reclassified as Gardnerella vaginalis, the only member of its genus. Subsequent studies found culture for G vaginalis to be nonspecific in that 31% to 50% of women who did not have BV were culture positive for G vaginalis.^1,23^

In the early 1980s, researchers recognized that the syndrome was polymicrobial, at which point it was renamed “bacterial vaginosis.”^24,25^ This name change reflected the observation that there is often a vaginal discharge without significant inflammatory reaction. Organisms identified as involved in BV include G vaginalis, Bacteroides species, Mobiluncus species, Peptostreptococcus species, Ureaplasma urealyticum, and Mycoplasma hominis.^ 24 ^

Although Gardner and Dukes^ 22 ^ measured clinical parameters for the syndrome, including clue cells (found in almost every case), pH, consistency of vaginal discharge, and odor, these signs were not universally accepted as diagnostic criteria for the syndrome until 1983, when Amsel et al^ 1 ^ proposed that clinical criteria be standardized to 3 out of 4 of the following: vaginal discharge pH greater than 4.5; homogeneous discharge adherent to the vaginal wall; amine, fishy odor immediately upon mixture of discharge with 10% KOH solution; or clue cells on a wet mount.

The reliability of these clinical signs in community practice, and especially in obstetric practice, is unknown. Measurement of pH in the vagina varies by whether the sample is taken from a vaginal wall, vaginal fornix, or cervical os, with the cervix having higher pH than the rest of the vagina. The specificity of homogeneous discharge during pregnancy has been questioned because many pregnant women experience an increase in vaginal discharge.^23,26^ Clue cells are frequently used in clinical practice (at times as the sole criterion for treatment) because of their high predictive value, but they are subject to interobserver variation.^ 27 ^ Recently, test kits with simple indicators, such as plus signs for pH greater than 4.5 and the presence of amines, have been marketed in attempts to improve reproducibility in everyday clinical practice.

Gram stain of vaginal discharge may be a more reliable means of diagnosing BV and offers the added ability of quantifying and classifying bacterial load.^28,29^ For these reasons, Gram stain has been the primary means used to diagnose BV in epidemiologic and treatment studies. Gram stain is often impractical for routine clinical use because of the need for laboratory facilities and the consequent delay in receiving diagnostic results.Because most of our data on pregnancy outcomes and their association with BV and improvement with BV treatment are based on studies that used Gram stain as their diagnostic criteria, a question remains as to whether research findings for pregnancy outcomes can be directly translated into practice. The preferred diagnostic test would be the one that best predicts pregnancy outcomes.

Two different Gram stain scoring systems (that of Nugent et al^ 29 ^ and of Spiegel et al^ 28 ^) have been developed and compared with the clinical criteria of Amsel et al.^ 1 ^ Comparisons of Spiegel's^ 28 ^ Gram stain scoring system to Amsel's criteria^ 1 ^ reveal sensitivities and specificities ranging from 62% to 97% and 66% to 95%, respectively.^23,26^ Similar comparisons of the Nugent et al^ 29 ^ criteria have shown a sensitivity of 89% and a specificity of 83%.^ 30 ^ The VIP study examined the interobserver variability among their 5 study centers and found that the scoring system of Nugent et al^ 29 ^ had greater intercenter reliability with a Spearman's rank correlation of r=0.82 versus that of r=0.61, obtained with the scoring system of Spiegel et al.^ 28 ^ Consequently, the criteria of Nugent et al^ 29 ^ were accepted as the preferred method for Gram stain evaluation.

### Treatment of BV

Oral metronidazole and oral clindamycin, as well as vaginal metronidazole gel or clindamycin cream, can treat BV. According to the US Centers for Disease Control and Prevention (CDC), cure rates are 78% to 84% in gynecologic patients taking oral metronidazole 500 mg twice a day for 7 days, 82% for clindamycin 2% vaginal cream taken once daily for 7 days, and 75% for metronidazole gel taken twice a day for 5 days.^ 31 ^ Side effects from oral metronidazole include gastrointestinal upset, nausea, metallic taste, and disulfiram reaction. The CDC-recommended treatment for BV during pregnancy is 250 mg of oral metronidazole taken 3 times a day for 7 days.^ 31 ^ This lower dosage is recommended to minimize exposure to the fetus. Alternative regimens include 2 g of metronidazole taken once a day or 300 mg of oral clindamycin taken twice a day for 7 days. The CDC does not recommend the use of clindamycin vaginal cream during pregnancy, since 2 randomized controlled trials (RCTs) have suggested an increase in PTD in treated patients.^32,33^

Studies that longitudinally tested pregnant women for BV have shown that as pregnancy progresses, acquisition of BV decreases^ 34 ^ and spontaneous resolution increases.^ 35 ^ This finding poses a challenge to studies of treating BV to show a clinical benefit and leads many investigators to believe that identification and treatment of BV before the second trimester may have the largest effect on pregnancy outcomes.

In a meta-analysis of 10 controlled trials, with a total of 1,203 gynecologic patients, it was found that all oral regimens, whether single dose or full 7-day course, eradicated BV in 85% to 87% of women before 4 weeks posttreatment and in 72% to 78% of women at 4-week follow up.^ 36 ^ This meta-analysis did not address metronidazole therapy in obstetric patients, for whom investigators speculate that longer courses may be necessary to treat any upper-tract disease. A Cochrane Collaboration review of RCTs of BV treatment during pregnancy found all compared treatments to be effective for eradicating BV, with a summary OR of 0.22 (95% CI, 0.17-0.27) for all trials.^ 37 ^ Results were not affected by route of antibiotic administration (OR 0.20, 95% CI, 0.15-0.27 for oral therapies and OR 0.24, 95% CI, 0.17-0.33 for vaginal treatment).

Clinicians were initially hesitant to prescribe metronidazole during pregnancy, particularly in the first trimester, out of concern for possible teratogenic effects. Two meta-analyses of case-control and cohort studies found no evidence for teratogenesis, with summary ORs of 1.02 and 1.08 (CI, 0.98, 1.27).^38,39^

## Previous Recommendations

Currently, the CDC states that “high-risk women [defined as those who previously delivered a premature infant] may be tested, and those positive treated.”^ 31 ^ The American College of Obstetricians and Gynecologists^ 40 ^ (ACOG) recommends that screening for BV “be considered” in women at high risk for preterm labor and that treatment with oral metronidazole be given to women diagnosed to have BV.^ 40 ^ They also state that “routine BV screening of asymptomatic women at low risk for PTD and the subsequent treatment of women who had positive results cannot be endorsed based on current studies.”^ 40 ^

The second US Preventive Services Task Force (USPSTF) did not consider screening for BV. This report was prepared for the third USPSTF to examine the effectiveness of screening for BV in pregnancy. We conducted a meta-analysis of RCTs of treatment for BV during pregnancy to examine the relation between risk status and effectiveness of treatment, to assess the generalizability of the trials, and to estimate the major benefits and risks of screening in the general obstetric population and in high-risk groups.

## Analytic Framework and Key Questions

An analytic framework was developed to outline issues and to focus the literature search (Figure 1). This framework begins with a population of pregnant women asymptomatic for BV who were at average (general population) or high risk for PTD. Women were considered high risk for PTD if they had a previous PTD. Asymptomatic patients were defined as those who presented for routine prenatal visits and not for evaluation specifically of vaginal discharge, odor, or itching. Under this definition, asymptomatic could include both patients who lacked symptoms and those who were unaware of symptoms. This population was felt to best reflect that encountered in everyday practice.

Figure 1. Analytic framework

The accompanying key questions (Figure 2) correspond to the numbered arrows in the analytic framework and articulate the main questions that guided our literature review and analysis of data. We first sought studies that addressed the overriding question of whether there are RCTs or case-control studies comparing pregnancy outcomes in a screened population with those of an unscreened population (Figure 1, Arrow 3). We found no studies addressing this question. In the absence of controlled studies of screening, the case for screening depends on whether screening can accurately identify patients who have BV (Figure 1, Arrow 1), whether early treatment of these patients prevents adverse pregnancy outcomes (Figure 1, Arrow 4), and whether there are significant harms of treatment (Figure 1, Arrow 5). We also asked what the overall effect was if studies were homogeneous, and what characteristics were associated with treatment benefit or harm if studies were heterogeneous. Our intention was to explore the relation between the patient characteristics, including risk factors for PTD, and the effectiveness of BV therapy to eradicate BV.

Figure 2. Key questions in analytic framework

#### Accuracy of Screening

Arrow 1

Is there direct evidence that screening for skin cancers leads to reduced morbidity and mortality?

Arrow 2a

1. How accurate is total-body skin examination in the detection of cancer?

2. How accurate are risk-assessment tools as a screening test for skin cancer?

#### Consequences of Screening

Arrow 2b

1. How often does screening detect suspicious lesions?

2. How often does screening result in a diagnosis of melanoma?

3. How often does screening result in a diagnosis of nonmelanoma skin cancer?

4. How often does screening lead to referral for follow up and biopsy?

5. How do characteristics of the screening program affect the yield of screening?

6. Compared with usual care, how much earlier does screening detect skin cancers and precancerous lesions?

Arrow 2c

What is the effect of screening on patients' skin knowledge and self-care behavior?

Arrow 3

What are the adverse effects of screening?

#### Effectiveness of Early Treatment

Arrow 4a

Does treatment of nonmelanoma skin cancer found by screening reduce morbidity and mortality?

Arrow 4b

Does treatment of malignant melanoma found by screening reduce morbidity and mortality?

Editor's note: For more information on using analytic frameworks, see Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med 2001;20(3S):21-35.

The box in the far right of the analytic framework (Figure 1) lists the outcome measures we examined. The primary outcome measure is PTD, which is the probability of delivery before a certain gestational age. Many studies report the overall probability of delivery before 37 weeks. PTD may be further subdivided into spontaneous PTD and indicated PTD. Spontaneous PTD arises mainly from PPROM or preterm labor. We looked for data on these outcomes as well. Medically indicated PTDs would include vaginal or cesarean deliveries for medical conditions such as hypertensive disorders, intrauterine growth restriction, and abruption; maternal conditions such as cervical or breast cancer; and fetal conditions requiring neonatal surgery. Treatment of BV would not be expected to affect the rate of indicated PTD,^ 42 ^ but it should reduce not only spontaneous PTD before 37 weeks, but the overall PTD rate as well.

As gestational-age-specific neonatal outcomes have improved, PTD before 37 weeks has become less clinically important as a pregnancy outcome. Because PTD before 34 weeks is clinically more important, we were most interested in this outcome. We also looked for evidence of the effect of treatment of BV on spontaneous abortion, postpartum endometritis, and neonatal sepsis.