# Appendix 3: Pooling of Results for Meta-Analysis

The problem addressed here is whether to pool the results of certain studies, and if so, how to express the results. In all studies reported here the measure of effect is the difference between the probability of benefit in the control group minus the probability of benefit in the treated group. There is one analysis for each definition of the endpoint.

The method is based on the credibility function for a parameter. Here, the parameter is D is the difference between the probabilities. For each study, one first computes the maximum likelihood estimate (MLE) ď and then the credibility function

cr(D = d:data) = L(d/L(ď),

where L is the likelihood function for the data, as it depends on D. The values of the credibility function lie between 0 and 1. In this application, credibility of 1 is attained only at the MLE. The credibility function has an objective interpretation. If, for example, cr(D= 0.20) = 0.5, then the parameter value 0.20 gives the actual observations only half as much probability as the MLE does. If cr(D = 0.30) = 0.10 then the MLE gives the actual observations 10 times more probability than the parameter value 0.30 does. In this way, parameter values are graded from the most credible (the MLE, with credibility of 1) to those that are incredible (credibility less than 0.01).

To consider whether to combine the results of 2 studies, the first step is to compute the credibility functions for each of them:

cr(D _1_ = d _1_: data_1_),

cr(D _2_ = d _2_: data_2_).

As the subscript notation indicates, we consider the possibility that the 2 studies have actually gathered evidence about 2 different parameters. The credibility that they are both considering the same parameter is

cr(D _1_ = D _2_: data_1_, data_2_) = max cr(D _1_ = d: data_1_)cr(D _2_ = d: data_2_),

that is, the maximum of the product of the 2 separate credibility functions. If this credibility is sufficiently high, then we might judge the studies to be referring to the same parameter and thus pool their credibility functions. In this application we use the cutoff credibility of 0.25, because it corresponds nearly to a 0.10-level 2-sided hypothesis test. If the decision is to pool, then the pooled credibility function is

cr(D = d: data_1_, data_2_) = cr(D _1_ = d: data_1_)cr(D _2_ = d: data_2_)/cr(D _1_ = D _2_).

The analysis of a set of studies proceeds as follows. First, compare all pairs of studies. Pool the 2 with the highest value of cr(D _1_=D _2_) if the value exceeds 0.25. This process leaves 1 fewer credibility function than at the outset, so continue in the same way, comparing all pairs and pooling the most credibly alike. Eventually, all the original studies will be in one pool, or there will be several pools that cannot be combined.