# Appendix 2: Table 1. Excluded Studies

Appendix 2: Table 1. Excluded Studies

Study, Year | Reason for Exclusion
Begum, 1997^ 1 ^ | Not RCT
Calleri, 1997 ^ 2 ^ | Not RCT
Carey, 1993 ^ 3 ^ | Not RCT
Ferris, 1995 ^ 4 ^ | Not RCT
Fule, 1990 ^ 5 ^ | Not RCT
Hay, 1994 ^ 6 ^ | Not RCT
Hill, 1994 ^ 7 ^ | Not RCT
Hillier, 1990 ^ 8 ^ | Not RCT
James, 1992 ^ 9 ^ | Not RCT
McGregor, 1990 ^ 10 ^ | Not RCT
McGregor, 1995 ^ 11 ^ | Not RCT
McGregor, 1997 ^ 12 ^ | Not RCT
Platz-Christensen, 1993 ^ 13 ^ | Not RCT
Watts, 1989 ^ 14 ^ | Not RCT
Sweeten, 1997 ^ 15 ^ | Not bacterial vaginosis
Stein, 1993 ^ 16 ^ | Not pregnant women
Duff, 1991 ^ 17 ^ | No pregnancy outcomes
Holst, 1990 ^ 18 ^ | No pregnancy outcomes
Karnaky, 1972 ^ 19 ^ | No pregnancy outcomes
Neri, 1993 ^ 20 ^ | No pregnancy outcomes
McDonald, 1994 ^ 21 ^ | No pregnancy outcomes
McGregor, 1991 ^ 22 ^ | Hospitalized patients
Kekki, 1997 ^ 23 ^ | Insufficient data
Alvi, 1999 ^ 24 ^ | Insufficient data

## References

1 Begum S, Sagawa T, Fujimoto S. Screening for bacterial vaginosis and cervicitis aimed at preventing premature delivery. J Obstet Gynaecol Res. 1997;23:103-110. [pmid: 9094827].
2 Calleri L, Porcelli A, Gallello D, Taccani C, Surico N. [Bacterial vaginosis and premature membrane rupture: an open study. Preliminary data]. Minerva Ginecol. 1997;49:19-23. [pmid: 9162880].
3 Carey JC, Yaffe SJ, Catz C. The Vaginal Infections and Prematurity Study: an overview. Clin Obstet Gynecol. 1993;36:809-820. [pmid: 8293583].
4 Ferris DG, Litaker MS, Woodward L, Mathis D, Hendrich J. Treatment of bacterial vaginosis: a comparison of oral metronidazole, metronidazole vaginal gel, and clindamycin vaginal cream. J Fam Prac. 1995;41:443-449.
5 Fule RP, Kulkarni K, Jahagirdar VL, Saoji AM. Incidence of Gardnerella vaginalis infection in pregnant & non-pregnant women with non-specific vaginitis. Indian J Med Res. 1990;91:360-363. [pmid: 2269507].
6 Hay PE, Morgan DJ, Ison CA, et al. A longitudinal study of bacterial vaginosis during pregnancy. Br J Obstet Gynaecol. 1994;101:1048-1053. [pmid: 7826957].
7 Hill GB, Livengood CH. 3rd. Bacterial vaginosis-associated microflora and effects of topical intravaginal clindamycin. Am J Obstet Gynecol. 1994;171:1198-1204. [pmid: 7977519].
8 Hillier S, Krohn MA, Watts DH, Wolner-Hanssen P, Eschenbach D. Microbiologic efficacy of intravaginal clindamycin cream for the treatment of bacterial vaginosis. Obstet Gynecol. 1990;76:407-413. [pmid: 2381617].
9 James JA, Thomason JL, Gelbart SM, Osypowski P, Kaiser P, Hanson L. Is trichomoniasis often associated with bacterial vaginosis in pregnant adolescents?. Am J Obstet Gynecol. 1992;166:859-863. [pmid: 1372472].
10 McGregor JA, French JI, Richter R, et al. Cervicovaginal microflora and pregnancy outcome: results of a double-blind, placebo-controlled trial of erythromycin treatment. Am J Obstet Gynecol. 1990;163:1580-1591. [pmid: 2240110].
11 McGregor JA, French JI, Parker R, et al. Prevention of premature birth by screening and treatment for common genital tract infections: results of a prospective controlled evaluation. Am J Obstet Gynecol. 1995;173:157-167. [pmid: 7631673].
12 McGregor JA, Roberts AM. First antenatal visits and metronidazole. Am J Obstet Gynecol. 1997;176:887-888. [pmid: 9125616].
13 Platz-Christensen JJ, Pernevi P, Hagmar B, Andersson E, Brandberg A, Wiqvist N. A longitudinal follow-up of bacterial vaginosis during pregnancy. Acta Obstet Gynecol Scand. 1993;72:99-102. [pmid: 8383416].
14 Watts DH, Eschenbach DA, Kenny GE. Early postpartum endometritis: the role of bacteria, genital mycoplasmas, and Chlamydia trachomatis. Obstet Gynecol. 1989;73:52-60. [pmid: 2783262]. [pmcid: 1041643].
15 Sweeten KM, Eriksen NL, Blanco JD. Chlorhexidine versus sterile water vaginal wash during labor to prevent peripartum infection. Am J Obstet Gynecol. 1997;176:426-430. [pmid: 9065193].
16 Stein GE, Christensen SL, Mummaw NL, Soper DE. Placebo-controlled trial of intravaginal clindamycin 2% cream for the treatment of bacterial vaginosis. Ann Pharmacother. 1993;27:1343-1345. [pmid: 8286805].
17 Duff P, Lee ML, Hillier SL, Herd LM, Krohn MA, Eschenbach DA. Amoxicillin treatment of bacterial vaginosis during pregnancy. Obstet Gynecol. 1991;77:431-435. [pmid: 1992412].
18 Holst E, Brandberg A. Treatment of bacterial vaginosis in pregnancy with a lactate gel. Scand J Infect Dis. 1990;22:625-626. [pmid: 2259873].
19 Karnaky KJ. Trimonil in a micronized form fro the treatment and the prevention of Trichomonas vaginalis, Hemophilus vaginalis, Candida (Monilia) albicans and cervical ectropions. Southwest Med. 1972;53:10-12. [pmid: 5060785].
20 Neri A, Sabah G, Samra Z. Bacterial vaginosis in pregnancy treated with yoghurt. Acta Obstet Gynecol Scand. 1993;72:17-19. [pmid: 8382424].
21 McDonald HM, O'Loughlin JA, Vigneswaran R, Jolley PT, McDonald PJ. Bacterial vaginosis in pregnancy and efficacy of short-course oral metronidazole treatment: a randomized controlled trial. Obstet Gynecol. 1994;84:343-348. [pmid: 8058228].
22 McGregor JA, French JI, Seo K. Adjunctive clindamycin therapy for preterm labor: results of a double-blind, placebo-controlled trial. Am J Obstet Gynecol. 1991;165:867-875. [pmid: 1951545].
23 Kekki M, Kurki T, Pelkonen J, Kurkinen-Raty M, Cacciatore B, Paavonen J. Bacterial vaginosis in pregnancy is associated with increased infectious morbidity: a randomized placebo-controlled intervention trial with vaginal clindamycin (abstract). Acta Obstet Gynecol Scand. 1997;76 (suppl).
24 Alvi SA, Lamont RF. Pregnancy outcome following the use of clindamycin intravaginal cream. J Soc Gynecol Investig. 1999;6.