# Appendix 1: Strategy for Bacterial Vaginosis Search

1. vaginosis, bacterial or exp bacterial infections and vaginitis
  - (bacterial vaginosis became a MeSH in 1992, so the combination of bacterial infections and vaginitis was used for the backfiles in MEDLINE)
2. exp mass screening
  - genetic screening
  - mass chest x-ray
  - multiphasic screening
  - vision screening
  - mandatory screening
3. screen$.tw
4. exp clinical trials
  - clinical trials, phases 1 through 4
  - controlled clinical trials
  - multicenter studies
  - randomized, controlled trials
5. labor, premature
6. infant, premature
7. exp pregnancy
  - corpus luteum maintenance
  - labor
  - labor presentation
  - maternal-fetal exchange
  - pregnancy, high-risk
  - pregnancy maintenance
  - pregnancy outcome
  - pregnancy, prolonged
8. exp pregnancy complications
  - abortion
  - fetal death
  - fetal diseases
  - herpes gestationis
  - labor complications
  - labor premature
  - oligohydramnios
  - phenylketonuria, maternal
  - polyhydramnios
  - complications, cardiovascular, hematologic, infectious and neoplastic
9. exp sensitivity and specificity
  - predictive value of tests
  - ROC curve
10. procedures
  - abortion, induced
  - delivery
11. exp gynecologic surgical procedures
  - circumcision, female
  - dilatation and curettage
  - hysterectomy
  - ovariectomy
  - salpingostomy
  - sterilization, tubal
12. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11
13. 1 and 12
14. vaginosis, bacterial/ep (epidemiology)
15. 13 or 14
16. limit 15 to human
17. limit 16 to English language
18. looked at English abstracts for foreign language articles