# References

Aitken M, Taylor JA. Prevalence of clinical sinusitis in young children followed up by primary care pediatricians. Arch Pediatr Adolesc Med. 1998;152:244-8. [pmid: 9529461].
Barlan IB, Erkan E, Bakir M, et al. Intranasal budesonide spray as an adjunct to oral antibiotic therapy for acute sinusitis in children. Ann Allergy Asthma Immunol. 1997;78:598-601. [pmid: 9207726].
Careddu P, Bellosta C, Tonelli P, et al. Efficacy and tolerability of brodimoprim in pediatric infections. J Chemother. 1993;5:543-5. [pmid: 8195853].
Ficnar B, Huzjak N, Oreskovic K, et al. Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. J Chemother. 1997;9:38-43.
Glasier CM, Mallory GB, Steele RW. Significance of opacification of the maxillary and ethmoid sinuses in infants. J Pediatr. 1989;114:45-50. [pmid: 2909706].
Gurses N, Kalayci AG, Islek I, et al. Cefuroxime axetil in the treatment of acute sinusitis in childhood. J Antimicrob Chemother. 1996;38:547-50. [pmid: 8889729].
Hager C, Bamberg P, Dorn G, et al. The use of cotrimazine once daily in acute otitis media and maxillary sinusitis in children. J Int Med Res. 1980;8:413-6. [pmid: 7439517].
Helin I, Andreasson L, Jannert M, et al. Acute sinusitis in children -- results of different therapeutic regimens. Helv Paediatr Acta. 1982;37:83-8. [pmid: 6806215].
Herz G, Gfeller J. Sinusitis in pediatrics. Chemotherapy. 1977;23:50-7. [pmid: 830515].
Jannert M, Andreasson L, Helin I, et al. Acute sinusitis in children -- symptoms, clinical findings and bacteriology related to initial radiologic appearance. Int J Pediatr Otorhinolaryngol. 1982;4:139-48. [pmid: 6982255].
Jeppesen F, Illum P. Pivampicillin in the treatment of maxillary sinusitis. Acta Otolaryngol. 1972;74:375-82. [pmid: 4565339].
Kogutt MS, Swischuk LE. Diagnosis of sinusitis in infants and children. Pediatrics. 1973;52:121-4. [pmid: 4724426].
Lau J, Zucker D, Engels, EA, et al. Diagnosis and treatment of acute bacterial rhinosinusitis. Evidence report/technology assessment no. 9. Rockville (MD): Agency for Health Care Policy and Research; 1999.
McCormick DP, John SD, Swischuk LE, et al. A double-blind, placebo-controlled trial of decongestant-antihistamine for the treatment of sinusitis in children. Clin Pediatr. 1996;35:457-60.
McLean D. Sinusitis in children: Lessons from twenty-five patients. Clin Pediatr. 1970;9:342-5.
Nylen O, Jeppsson P-H, Branefors-Helander P. Acute sinusitis. Scand J Infect Dis. 1972;4:43-8. [pmid: 4401780].
Puhakka H, Virolainen E. Cefadroxil in the treatment of susceptible infections in infants and children. Drugs. 1986;32(suppl 3):21-8. [pmid: 3803250].
Revonta M, Suonpaa J. Diagnosis and follow-up of ultrasonographical sinus changes in children. Int J Pediatr Otorhinolaryngol. 1982;4:301-8. [pmid: 6185449].
van Buchem FL, Peeters MF, Knottnerus JA. Maxillary sinusitis in children. Clin Otolaryngol. 1992;17:49-53. [pmid: 1555318].
Wald ER, Chiponis D, Ledesma-Medina J. Comparative effectiveness of amoxicillin and amoxicillin-clavulanate potassium in acute paranasal sinus infections in children: A double-blind, placebo-controlled trial. Pediatrics. 1986;77:795-800. [pmid: 3520469].
Wald ER, Reilly JS, Casselbrant M, et al. Treatment of acute maxillary sinusitis in childhood: A comparative study of amoxicillin and cefaclor. J Pediatr. 1984;104:297-302. [pmid: 6363660].
Watt-Boolsen S, Karle A. The clinical use of radiological examination of the maxillary sinuses. Clin Otolaryngol. 1977;2:41-3. [pmid: 589833].