# Evidence Tables

## Key to Abbreviations in Evidence Tables

- amox= amoxicillin
- ct= computed tomography
- cl= clinical
- d= day
- dis= discharge
- dx= diagnosis
- ent= ear, nose, and throat
- gp= general practice
- hx= history
- ped= pediatric
- pharm= pharmaceutical
- pn= postnasal
- rad= radiology
- rct= randomized controlled trial
- rx= medication
- sx= symptoms
- urti= upper respiratory tract infection
- us= ultrasound

Evidence Table 1a. Studies on efficacy of antibiotics: Study parameters

Author, unique identifier | Journal, year | Number of centers | Country | Funding | Design | Number of patients | Specialty | Age range
McLean 70203274 | Clin Pediatr 1970 | 1 | USA | no data | case series | 25 | Pediatrics | 4 to 15
Nylen 72167412 | Scand J Infect Dis 1972 | 1 | Sweden | no data | case series | 25 | ENT | 5 to 15
Jeppesen 73056388 | Acta Otolaryng 1972 | 1 | Denmark | no data | RCT | arm 1-7 sinuses | ENT | 6 to 10
Jeppesen 73056388 | Acta Otolaryng 1972 | 1 | Denmark | no data | RCT | arm 2-8 sinuses | ENT | 6 to 10
Herz 77067994 | Chemotherapy 1977 | 1 | Swiss | no data | case series | 106 | Pediatrics | 6 to 17
Hager 81067509 | J Int Med Res 1980 | 1 | Germany | Pharm | case series | 30 | no data | 1 to 12
Helin 82213306 | Helv Paediatr Acta 1982 | 1 | Sweden | no data | case series | arm 1-61 | ENT | 1 to 15
Helin 82213306 | Helv Paediatr Acta 1982 | 1 | Sweden | no data | case series | arm 2-16 | ENT | 1 to 15
Helin 82213306 | Helv Paediatr Acta 1982 | 1 | Sweden | no data | case series | arm 3-15 | ENT | 1 to 15
Wald 84114106 | J Pediatr 1984 | 1 | USA | Pharm | RCT | arm 1-27 | Pediatrics | 1 to 16
Wald 84114106 | J Pediatr 1984 | 1 | USA | Pharm | RCT | arm 2-23 | Pediatrics | 1 to 16
Puhakka 87105160 | Drugs 1986 | 1 | Finland | no data | case series | 14 | ENT | 0 to 15
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 1-28 | Pediatrics | 2 to 16
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 2-30 | Pediatrics | 2 to 16
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 3-35 | Pediatrics | 2 to 16
Careddu 94253888 | J Chemother 1993 | 1 | Italy | no data | RCT | arm 1-25 | Pediatrics | 2 to 14
Careddu 94253888 | J Chemother 1993 | 1 | Italy | no data | RCT | arm 2-27 | Pediatrics | 2 to 14
Gurses 97044658 | J Antimicrob Chem 1996 | 1 | Turkey | no data | case series | 39 | Pediatrics | 5 to 14
Ficnar 97259917 | J Chemother 1997 | 24 | Croatia | Pharm | RCT | arm 1-27 | Pediatrics | 1/2 to 12
Ficnar 97259917 | J Chemother 1997 | 24 | Croatia | Pharm | RCT | arm 2-18 | Pediatrics | 1/2 to 12
Aitken 98190258 | Arch Ped Adol Med 1998 | 6 | USA | Private | case series | cases-68 | Pediatrics | 1 to 5
Aitken 98190258 | Arch Ped Adol Med 1998 | 6 | USA | Private | case series | control-19 | Pediatrics | 1 to 5

Evidence Table 1b. Studies on efficacy of antibiotics: History, symptoms, and diagnosis

Author, unique identifier | Duration of symptoms | Past history of sinusitis | Dx: aspirate/irrigation | Dx: nasal swab and culture | Dx: X-ray
McLean 70203274 | no data | no data | done in 4 children | done prn | required for diagnosis: air-fluid level, opacification or mucous thickening (≥ 2/3 criteria)
Nylen 72167412 | no data | no data | prn | done | performed in most, not required
Jeppesen 73056388 | no data | no data | done | not done | five standard projections required
Herz 77067994 | no data | no data | not done | not done | required for diagnosis
Hager 81067509 | no data | no data | not done | not done | "positive" required
Helin 82213306 | no data | no data | not done | done | swelling or complete opacification required
Wald 84114106 | <30 days | no data | done prn, but not required for diagnosis | not done | required for diagnosis: air-fluid level, opacification, or >4 mm mucous thickening
Puhakka 87105160 | 0-3(2), 4-10(10), >10(2) | no data | prn | prn | not required
Wald 86232357 | <30 days | no data | not done | not done | required for diagnosis: air-fluid level, opacification, or >4 mm mucous thickening: present in 136/171 with clinical symptoms screened
Careddu 94253888 | no data | no data | not done | not done | no data
Gurses 97044658 | less than 30 days | no data | not done | not done | swelling or opacification or air-fluid level required
Ficnar 97259917 | no data | no data | prn | prn | required for diagnosis
Aitken 98190258 | case-21/68 more than 29 days | no data | not done | not done | not required
Aitken 98190258 | control-all less than 30 days | no data | not done | not done | not required

Evidence Table 1c. Studies on efficacy of antibiotics: Clinical diagnosis and antibiotic treatment

Author, unique identifier | Dx: clinical (specify) | Antibiotic | Dose | Duration
McLean 70203274 | rhinitis (21/25), pain (2/25), cough (15/25), pus (16/25), purulent sputum (8/25), fever (3/25), tenderness (2), etc. | various | - | 14-21 days
Nylen 72167412 | yes, but not specified | penicillin | 30 mg/kg/d | 10 days
Jeppesen 73056388 | careful H+P, mucopurulent secretions, edema and dilated vessels on sinoscopy | arm 1-pivampicillin | 178 mg qid | 7-30 days
Jeppesen 73056388 | careful H+P, mucopurulent secretions, edema and dilated vessels on sinoscopy | arm 2-placebo | 178 mg qid | 7-30 days
Herz 77067994 | cough, H/A, fever, rhinitis, pn drip, tenderness, and others (listed in tables 2, 4) | doxycycline | 4 mg/kg for 1 day, then 2 mg/kg | 10-28 days
Hager 81067509 | red and swollen mucosa with purulent or mucopurulent discharge | co-trimazine | 45 or 90 mg TMP (for 1-5 and 6-12 y) | 10 days
Helin 85053615 | URTI, local pain/tenderness, pus in the nose | arm 1-penicillin V | 50-100 mg/kg bw/day | 10 days
Helin 85053615 | URTI, local pain/tenderness, pus in the nose | arm 2-pivampicillin | 25-50 mg/kg bw/day | 10 days
Helin 85053615 | URTI, local pain/tenderness, pus in the nose | arm 3-erythromycin | 40-50 mg/kg bw/day | 10 days
Wald 84114106 | ER or ENT presenting symptoms | arm 1-amoxicillin | 40 mg/kg/d tid | 10 days
Wald 84114106 | ER or ENT presenting symptoms | arm 2-cefaclor | 40 mg/kg/d tid | 10 days
Puhakka 87105160 | purulent drainage and transillumination of paranasal sinuses | cefadroxil | 30-50 mg/kg | 7-17 days
Wald 86232357 | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | arm 1-amox/clavulanate | 40 mg/kg/d tid | 10 days
Wald 86232357 | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | arm 2-amoxicilln | 40 mg/kg/d tid | 10 days
Wald 86232357 | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | arm 3-placebo | | 10 days
Careddu 94253888 | not mentioned how diagnosed--presumably on clinical grounds | arm 1-brodimoprim | 10 mg/kg for 1 day, then 5 mg/kg | 8 days
Careddu 94253888 | not mentioned how diagnosed--presumably on clinical grounds | arm 2-amox/clavulanate | not specified | 8 days
Gurses 97044658 | cough (64%), nasal discharge (54%), H/A (49%), large tonsils (44%), tenderness (31%), postnasal drip (26%) | cefuroxime | 20 mg/kg/d | 7 days
Ficnar 97259917 | yes, but not specified | arm 1-azithromycin | 10 mg/kg | 3 days
Ficnar 97259917 | yes, but not specified | arm 2-azithromycin | 10 mg/kg for 1 day, then 5 mg/kg d2-5 | 5 days
Aitken 98190258 | nasal congestion/drainage, cough or both for >9 days without improvement | case-various | - | various
Aitken 98190258 | nasal congestion/drainage, cough or both for >9 days without improvement | control-none | -

Evidence Table 1d. Studies on efficacy of antibiotics: Decongestant use and treatment response

Author, unique identifier | | Decongestant (dose, duration) | Response assessed at | Response: cure | Response: at least improved | Clinical failure | Radiologic improvement
McLean 70203274 | - | no data | 21 days | 20/21 | 20/21 | 1 of 21 | 14 of 14
Nylen 72167412 | - | given for 7 days | 9-11 days | 12 of 25 | - | - | no data
Jeppesen 73056388 | arm 1 | all pts got ephedrinechloride and daily lavage | daily | mean and sd time to recovery: 7.86, 3.69 | - | - | can't separate
Jeppesen 73056388 | arm 2 | | daily | mean and sd time to recovery: 6.38, 1.45 | - | -
Herz 77067994 | - | no data | end of treatment | 77/106 | 100/106 | 6 of 106 | 80/106 at 21 days
Hager 81067509 | - | no data | 11-13 days | 23/28 | 26/28 | 2 of 28 | no data
Helin 85053615 | arm 1 | nose drops and phenylpropanolamine | 1 month | 53/61 | 53/61 | 8 of 61 | 51/61
Helin 85053615 | arm 2 | nose drops and phenylpropanolamine | 1 month | 14/16 | 14/16 | 2 of 16 | 14/16
Helin 85053615 | arm 3 | nose drops and phenylpropanolamine | 1 month | 12 of 15 | 12 of 15 | 3 of 15 | 12 of 15
Wald 84114106 | arm 1 | antihistamine decongestants | 10-14 days | - | 23/27 | 4 of 27 | 16 of 22
Wald 84114106 | arm 2 | antihistamine decongestants | 10-14 days | - | 20/23 | 3 of 23 | 18 of 22
Puhakka 7105160 | - | no data | 10 days? | 13/14 | 13/14 | 1 of 14 | no data
Wald 86232357 | arm 1 | antihistamine decongestants | 10 days | - | 21/28 | 7 of 28 | can't separate
Wald 86232357 | arm 2 | antihistamine decongestants | 10 days | - | 25/30 | 5 of 30 | can't separate
Wald 86232357 | arm 3 | antihistamine decongestants | 10 days | - | 21/35 | 14 of 35 | can't separate
Careddu 94253888 | arm 1 | no data | not specified | 24/25 | 24/25 | 1 of 25 | no data
Careddu 94253888 | arm 2 | no data | not specified | 23/27 | 23/27 | 4 of 27 | no data
Gurses 97044658 | | no data | 7 days | | 36/39 | 3 of 39 | no data
Ficnar 97259917 | arm 1 | no data | 10 days | 23/24 | 23/24 | 1 relapse | no data
Ficnar 97259917 | arm 2 | no data | 10 days | 18/18 | 18/18 | 0 of 18 | no data
Aitken 98190258 | case | no data | 10-14 days | 37/43 | 44/45 | 1 of 45 | no data
Aitken 98190258 | control | no data | | 10 of 14 | 12 of 15 | 3 of 15 | no data

Evidence Table 1e. Studies on efficacy of antibiotics: Bacteriological eradication, adverse effects, subgroup data, and comments

Author, unique identifier | | Bacteriologic eradication | Adverse effects | Subgroup data | Other comments
McLean 70203274 | - | no data | no data | no | antibiotics included penicillin (10), ampicillin (4), tetracycline (9); poor response rates after 2 weeks; good response rates after 3 weeks; history of asthma in 10 children
Nylen 72167412 | - | can't separate | no data | no | can't separate bacteriologic data in pediatric age group
Jeppesen 73056388 | - | can't separate | can't separate by dx | no | arm 1-reported as time to recovery, no way to assess number of patients cured or improved at different time points; total n in all age groups = 63 (piv+79 placebo)
Jeppesen 73056388 | - | can't separate | can't separate by dx | no | arm 2-as above
Herz 77067994 | - | no data | 1 pt vomited | no
Hager 81067509 | - | no data | 1 pt stopped rx | per dose given (age) | at 4-6 days: cure 4, improved 4+23, no failures.
Helin 85053615 | arm 1 | no data | no data | no | all failures had sensitive bacteria or no growth
Helin 85053615 | arm 2 | no data | no data | no | all failures had sensitive bacteria or no growth
Helin 85053615 | arm 3 | no data | no data | no | all failures had sensitive bacteria or no growth
Wald 84114106 | arm 1 | no data | 1 utricarial rash | no
Wald 84114106 | arm 2 | | none
Puhakka 87105160 | - | can't separate | can't separate by dx | no | can't separate from data on other type of infections (total n = 395); cure rate 13/14 or 14/14 (tables are discrepant)
Wald 86232357 | arm 1 | no data | diarrhea n = 5 | no
Wald 86232357 | arm 2 | | rash n = 1
Wald 86232357 | arm 3 | | rash (1), diarrhea (1)
Careddu 94253888 | arm 1 | no data | can't separate by dx | no | can't separate adverse effects in sinusitis group only
Careddu 94253888 | arm 2 | no data | can't separate by dx | no | can't separate adverse effects in sinusitis group only
Gurses 97044658 | - | no data | 1 pt had diarrhea | no | throat cultures performed instead of sinus aspirates or even swabs
Ficnar 97259917 | arm 1 | 2 of 2 | can't separate by dx | no | can't separate adverse effects in sinusitis group only
Ficnar 97259917 | arm 2 | 1 of 2 | can't separate by dx | no | can't separate adverse effects in sinusitis group only
Aitken 98190258 | - | no data | no data | no | data also available for response at 48-72 hours; note that some antibiotic-treated cases are probably subacute chronic sinusitis

Evidence Table 2a. Studies on efficacy of ancillary measures: Study parameters

Author, unique identifier | Journal, year | Number of centers | Country | Funding | Design | Number of patients | Specialty | Age range (years) | Duration of symptoms
Revonta 83107994 | Int J Ped Otorhinolar 1982 | 1 | Finland | no data | RCT | arm 1-50 (72 sinuses) | ENT | 4 to 10 | no sinusitis sx
Revonta 83107994 | Int J Ped Otorhinolar 1982 | 1 | Finland | no data | RCT | arm 2-36 (49 sinuses) | ENT | 4 to 10 | no sinusitis sx
McCormick 97031318 | Clin Pediatr 1996 | 1 | USA | pharmaceutical | RCT | arm 1-34 | Ped | 1 to 18 | 7-30 days
McCormick 97031318 | Clin Pediatr 1996 | 1 | USA | pharmaceutical | RCT | arm 2-34 | Ped | 1 to 18 | 7-30 days
Barlan 97351444 | Ann All Asth Immunol 1997 | 1 | Turkey | no data | RCT | arm 1-43 | Allergy | 2 to 14 | >7 days
Barlan 97351444 | Ann All Asth Immunol 1997 | 1 | Turkey | no data | RCT | arm 2-46 | Allergy | 1 to 15 | >7 days

Evidence Table 2b. Studies of efficacy on ancillary measures: History, diagnosis, and antibiotic use

Author, unique identifier | Past history of sinusitis | Dx: aspirate/irrigation | Dx: nasal swab and culture | Dx: x-ray | Dx: other imaging | Dx: clinical (specify) | Antibiotic | Dose | Duration
Revonta 83107994 | no data | arm 1-fluid in 94% of sinuses (68/72) | not done | arm 1-done, no data except that radiographic findings seen in 168/452 children who came for various ENT surgeries without sinusitis sx | ultrasound done to define cases and follow response to therapy | no symptoms of sinusitis except for rhinorrhea | amoxicillin | 30 mg/kg/d | 10 days
Revonta 83107994 | no data | arm 2-not done | not done | arm 2-as above | ultrasound done to define cases and follow response to therapy | no symptoms of sinusitis except for rhinorrhea | amoxicillin | 30 mg/kg/d | 10 days
McCormick 97031318 | no data | not done | not done | required for diagnosis | not done | symptom score established at baseline, d3 and d14 from questionnaire | amoxicillin | | 14 days
Barlan 97351444 | no data | not done | not done | arm 1-thickening in 14/43; opacification in 22/43; 69/89 had abnormal radiographs in both arms combined | not done | two major criteria (purulent nasal dis, or pharyngeal drainage, or cough) or 1+2 minor criteria (of 9 listed) | amoxicillin/ clavulanate | 40 mg/kg/d tid | 21 days
Barlan 97351444 | no data | not done | not done | arm 2-thickening in 15/46; opacification in 28/46; 69/89 had abnormal radiographs in both arms combined | not done | two major criteria (purulent nasal dis, or pharyngeal drainage, or cough) or 1+2 minor criteria (of 9 listed) | amoxicillin/ clavulanate | 40 mg/kg/d tid | 21 days

Evidence Table 2c. Studies on efficacy of ancillary measures: Decongestant use, treatment response, and adverse effects

Author, unique identifier | Decongestant (dose, duration) | Response assessed at | Response: cure | Response: at least improved | Clinical failure | Radiologic improvement | Bacteriologic eradication | Adverse effects
Revonta 83107994 | arm 1-phenylpropanolamino-hydrochloride + lavage | ultrasound evaluation at 10 days | arm 1-no symptoms | - | - | arm 1-62/72 | no data | no data
Revonta 83107994 | arm 2-phenylpropanolamino- hydrochloride only | ultrasound evaluation at 10 days | arm 2-as above | - | - | arm 2-36/49
McCormick 97031318 | arm 1-oxymetazoline+ brompheniramine+ ppa | symptom score at 3 and 14 days | no difference in clinical scores and radiography scores at 3 and 14 days-no discrete cure and failure data | - | - | | no data | no data
McCormick 97031318 | arm 2-placebo | symptom score at 3 and 14 days | no difference in clinical scores and radiography scores at 3 and 14 days-no discrete cure and failure data | - | - | | no data | no data
Barlan 97351444 | arm 1-budenoside 50 microgram bid | daily scores in diaries | arm 1-data given as cough and nasal discharge scores per week in the two groups; budenoside superior at the second week | - | - | no data | no data | no data
Barlan 97351444 | arm 2-placebo bid | daily scores in diaries | arm 2-as above | - | - | no data | no data | no data

Evidence Table 2d. Studies on efficacy of ancillary measures: Subgroup data and comments

Author, unique identifier | Subgroup data | Other comments
Revonta 83107994 | no | the study also has data qualifying for the evaluation of diagnostic tests (see diagnostic database)
McCormick 97031318 | no | -
Barlan 97351444 | no | arm 1-of 151 enrolled only 89 recorded daily symptoms and complied with visits; analysis based on these 89
Barlan 97351444 | no | arm 2-as above

Evidence Table 3a. Studies on efficacy of diagnostic tests: Study parameters

Author, unique identifier | Journal, year | Number of centers | Country | Funding | Design | Number of patients | Specialty | Age range
Population with acute sinusitis
Kogutt 73234788 | Pediatrics 1973 | 1 | USA | Private | case series | 100 | Rad and ped | 1/2 to 14
Watt-Boolsen 78063171 | Clin Otolaryng 1977 | 1 | Denmark | no data | case series | 86 (155 sinuses) | Rad and ENT | 3 to 12
Jannert 83030026 | Int J Ped Otorhinolar 1982 | 1 | Sweden | no data | case series | 175 | ENT | 0 to 15
Glasier 89080930 | J Pediatr 1989 | 1 | USA | no data | case series | 15 with URI sx | Rad and ped | less than 1
Glasier 89080930 | J Pediatr 1989 | 1 | USA | no data | case series | 85 without URI sx | Rad and ped | less than 1
van Buchem 92209107 | Clin Otolaryng 1992 | 1 | Netherlands | no data | case series | 68 rhinitis + 79 sinusitis | GP and ENT | 2 to 12
Population with incidental sinusitis before scheduled adenotonsillectomy or adenoidectomy
Revonta 83107994 | Int J Ped Otorhinolar 1982 | 1 | Finland | no data | RCT (lavage vs. no) | 452 children without sinus sx | ENT | 4 to 10
Primary treatment study with diagnostic data
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 1-28 | Pediatrics | 2 to 16
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 2-30 | Pediatrics | 2 to 16
Wald 86232357 | Pediatrics 1986 | 1 | USA | Pharm | RCT | arm 3-35 | Pediatrics | 2 to 16
Ancillary treatment study with diagnostic data
Barlan 97351444 | Ann All Asth Immunol 1997 | 1 | Turkey | no data | RCT | arm 1-43 | Allergy | 2 to 14
Barlan 97351444 | Ann All Asth Immunol 1997 | 1 | Turkey | no data | RCT | arm 2-46 | Allergy | 1 to 15

Evidence Table 3b. Studies on efficacy of diagnostic tests: History, symptoms, and diagnosis

Author, unique identifier | Duration of symptoms | Past history of sinusitis | Dx: aspirate/irrigation | Dx: nasal swab and culture | Dx: x-ray
Population with acute sinusitis
Kogutt 73234788 | no data | no data | not done | not done | clouding of sinuses in 81/100
Kogutt 73234788 | no data | no data | not done | not done | mucosal thickening in 79/100
Kogutt 73234788 | no data | no data | not done | not done | air-fluid levels in 5/100
Kogutt 73234788 | no data | no data | not done | not done | any radiographic abnormality in 96/100
Watt-Boolsen 78063171 | no data | no data | fluid in 80/114 sinuses with abnormal x-ray | | abnormal sinuses (114/155) = fluid or complete opacification, almost complete density or mucous thickening, cysts, or polyps
Watt-Boolsen 78063171 | no data | no data | fluid in 16/41 sinuses with normal x-ray | | normal sinuses (41/155) = none of the above
Jannert 83030026 | no data | no data | not done | not done | 97/175 had positive Ro (75 with cl-score>1, 22 with cl-score<2); 78 had negative Ro (21 with cl-score<2, 57 with cl-score>1)
Glasier 89080930 | no sinusitis sx | no data | not done | not done | not done
van Buchem 92209107 | no data | no data | done in 54/83 children referred with "sinusitis" | done in "sinusitis" referred children | done in referred ("sinusitis") children: veiling in 49/124 and mucosal swelling in 35/124 sinuses; normal in 40/124 sinuses
van Buchem 92209107 | no data | no data | abnormal fluid found in 17/107 sinuses irrigated | pathogenic bacteria found in 68/93 sinuses | done in referred ("sinusitis") children: veiling in 49/124 and mucosal swelling in 35/124 sinuses; normal in 40/124 sinuses
van Buchem 92209107 | no data | no data | pathogenic bacteria found in 31/93 sinuses | pathogenic bacteria found in 68/93 sinuses | done in referred ("sinusitis") children: veiling in 49/124 and mucosal swelling in 35/124 sinuses; normal in 40/124 sinuses
Population with incidental sinusitis before scheduled adenotonsillectomy or adenoidectomy
Revonta 83107994 | no sinusitis sx | no data | done in 50 children (72 sinuses) who were US(+): fluid in 68/72 | not done | abnormal x-ray reported in 168/452 children referred for adenoidectomy or ad-tonsillectomy without sinusitis sx
Primary treatment study with diagnostic data
Wald 86232357 | <30 days | no data | not done | not done | required for diagnosis: air-fluid level, opacification, or >4 mm mucous thickening in 136/171 with clinical symptoms screened
Ancillary treatment study with diagnostic data
Barlan 97351444 | >7 days | no data | not done | not done | arm 1-thickening in 14/43; opacification in 22/43; 69/89 had abnormal radiographs in both arms combined
Barlan 97351444 | >7 days | no data | not done | not done | arm 2-thickening in 15/46; opacification in 28/46; 69/89 had abnormal radiographs in both arms combined

Evidence Table 3c. Studies on efficacy of diagnostic tests: Diagnosis (continued), antibiotic use, and subgroup data

Author, unique identifier | Dx: other imaging | Dx: clinical (specify) | Antibiotic | Dose | Subgroup data
Population with acute sinusitis
Kogutt 73234788 | not done | rhinorrhea (77), persistent cough (48), otic involvement (68), pain/H/A (13), fever>101 (21) | not pertinent | not applicable | yes
Watt-Boolsen 78063171 | not done | not specified | not pertinent | | no
Jannert 83030026 | not done | clinical score: purulent secretion, h/o URI in prior 2 weeks, sinus pain or tenderness | not pertinent | not applicable | no
Glasier 89080930 | 13/15 opacified maxillary, 10/15 opacified ethmoid s. | no children had sinusitis-specific symptoms; CT was done on children with unrelated problems | not pertinent | not applicable | no
Glasier 89080930 | 57/85 maxillary, 38/84 ethmoid s.; excluding sinus hypoplasia: 41/69 and 29/75
van Buchem 92209107 | US (+) in 32/124 of the sinusitis group | 68 children with "rhinitis" did not differ from 79 children with "sinusitis" in any of the symptoms listed below | not pertinent | not applicable | no
van Buchem 92209107 | US (+) in 32/124 of the sinusitis group | fever 13/68 vs. 10/79, purulent secretion 35/68 vs. 52/79, tenderness 7/68 vs. 12/79, H/A 13/68 vs. 10/79
van Buchem 92209107 | US (+) in 32/124 of the sinusitis group | but they differed in frequent cough 54/68 vs. 39/79 and in prolonged runny nose 72% vs. 36%
Population with incidental sinusitis before scheduled adenotonsillectomy or adenoidectomy
Revonta 83107994 | US showed secretion on 86/452 of referred children without sinusitis sx | no children had sinusitis-specific symptoms | amoxicillin | see above under therapeutic interventions database for details | no
Primary treatment study with diagnostic data
Wald 86232357 | - | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | amoxicillin/ clavulanate | 40 mg/kg/d tid | no
Wald 86232357 | - | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | amoxicillin | 40 mg/kg/d tid | no
Wald 86232357 | - | clinical severity score assigned; nasal discharge or cough not improving >10 days required for study entry | placebo | 40 mg/kg/d tid | no
Ancillary treatment study with diagnostic data
Barlan 97351444 | not done | two major criteria (purulent nasal dis, or pharyngeal drainage, or cough) or 1+2 minor criteria (of 9 listed) | amoxicillin/ clavulanate | 40 mg/kg/d tid | no

Evidence Table 3d. Studies on efficacy of diagnostic tests: Comments

Author, unique identifier | Other comments
Population with acute sinusitis
Kogutt 73234788 | 5/5 children with immunodeficiencies had radiographically pansinusitis
Watt-Boolsen 78063171 | -
Jannert 83030026 | 2x2 tables possible for different thresholds of clinical score against radiography; see also complementary report by Helin, et al., 1982
Glasier 89080930 | plain radiography considered worthless due to technical and developmental reasons in infants
van Buchem 92209107 | 2x2 tables for comparative diagnostic accuracy available for radiography, US, nasal culture, irrigation fluid, pathogens on irrigation fluid, and leukocyte count in irrigation fluid
Population with incidental sinusitis before scheduled adenotonsillectomy or adenoidectomy
Revonta 83107994 | ultrasound felt to be reliable for determining response to therapy (antibiotics +/- lavage)
Primary treatment study with diagnostic data
Wald 86232357 | -
Ancillary treatment study with diagnostic data
Barlan 97351444 | of 151 enrolled only 89 recorded daily symptoms and complied with visits; analysis based on these 89
Barlan 97351444 | as above

Evidence table 4. Concordance of diagnostic findings on imaging and aspiration tests: Positive and negative likelihood ratios

Study | Evaluated diagnostic test and finding | Reference test and finding | LR+ | LR-
Jannert | Plain x-ray: any abnormality^1^ | Clinical criteria: 2-3 vs. 1 of pus, upper respiratory secretion, sinus pain/tenderness | 2.8 | 0.3
Glasier | CT scan of maxillary sinuses in infants: opacification^2^ | Clinical diagnosis: upper respiratory infection | 1.5 | 0.3
Glasier | CT scan of ethmoid sinuses in infants: opacification^2^ | Clinical diagnosis: upper respiratory infection | 1.7 | 0.5
van Buchem | Ultrasound: any abnormality | Plain film radiography: any abnormality^1^ | 1.7 | 0.9
van Buchem | Ultrasound: any abnormality | Sinus aspirate: nonclear fluid | 0.5 | 1.2
van Buchem | Plain film radiography: any abnormality^1^ | Sinus aspirate: nonclear fluid | 1.1 | 0.9
van Buchem | Sinus aspirate: nonclear fluid | Sinus aspirate: pathogenic microorganisms | 0.9 | 1.0
van Buchem | Sinus aspirate: >3 leukocytes per visual field | Sinus aspirate: pathogenic microorganisms | 4.0 | 0.9
Watt-Boolsen | Plain film radiography: any abnormality^1^ | Sinus aspirate: any fluid | 2.7 | 0.2