# Methodology

## Inclusion Criteria

Studies qualified for inclusion in this report regardless of study design if they

- Were pertinent to the questions identified above.
- Studied only patients younger than 18 years of age (or included subgroups of patients under age 18 that could be readily identified in the presented data).
- Included at least 10 children.
- Included only patients who were symptomatic for less than 30 days.

Studies of chronic sinusitis were excluded. Subgroup data on acute sinusitis in studies with 10 or more patients in which both acute and chronic sinusitis or other infections were considered qualified for inclusion in this evidence report. Studies limited to complications (neurologic, local soft tissue, or other) of acute sinusitis were excluded.

## Search Strategy and Retrievals

We searched MEDLINE using a broad search strategy covering the period from 1966 to March 1999. The word "sinusitis" was used in the search as a text word and as a MeSH term. We then limited the search results to human studies and English-language studies that included pediatric patients using the terms "infant, newborn," "infant," "child, preschool," "child," and "adolescent." The titles and abstracts of the resulting 1,857 citations were retrieved and screened for articles that might have data on treatment of acute sinusitis in children. We immediately rejected 1,719 papers on the basis of their titles and abstracts. Notably, these included 450 articles on complications of acute sinusitis and 233 nonsystematic review articles without original data. The remaining 138 articles not previously examined in the earlier evidence report (Lau, Zucker, Engels, et al., 1999) were retrieved in full and examined. These articles included mostly nonrandomized studies and a few new randomized trials. A total of 21 studies ultimately qualified for inclusion in this supplemental report.

## Statistical Analysis

Given the paucity and heterogeneity of the data for specific questions, we did not attempt the application of formal meta-analytic techniques in most circumstances. When possible, rates were pooled across different studies, and heterogeneity was assessed with a chi-square statistic. Odds ratios for efficacy (clinical improvement) were also estimated by the Mantel-Haenszel formula stratified per antibiotic use.

For diagnostic modalities, we expressed concordance by using the positive likelihood ratio, which is calculated as

LR+ = sensitivity/(1-specificity)

and the negative likelihood ratio, which is calculated as

LR- = (1-sensitivity)/specificity

The positive likelihood ratio gives an estimate of how much more common a specific diagnostic finding is in the positive group versus the negative group as defined by a different diagnostic standard. The higher the positive likelihood ratio, the better the concordance of the two diagnostic modalities. A positive likelihood ratio of 1 shows there is no concordance. The positive likelihood ratio can take values up to infinity. There is no threshold value that characterizes a test of very good diagnostic performance, but values less than 5 probably are not sufficient. For example, a positive likelihood ratio of 5 corresponds to a sensitivity of 50 percent with specificity of 90 percent or a sensitivity of 90 percent with specificity of 82 percent. The inverse considerations hold true for the negative likelihood ratio, where good concordance is shown by diminishing values. A negative likelihood ratio of 1 also shows lack of concordance.

All reported p-values are two-tailed.