# Introduction

In March 1999, the Agency for Healthcare Research and Quality (previously the Agency for Health Care Policy and Research) published the original Evidence Report/Technology Assessment No. 9, Diagnosis and Treatment of Acute Bacterial Rhinosinusitis (Lau, Zucker, Engels, et al., 1999), which we at the New England Medical Center Evidence-based Practice Center (EPC) prepared under contract to the Agency. This original report dealt mostly with treatment of acute rhinosinusitis in adults. In preparing that report, our EPC found only two randomized controlled trials that were devoted exclusively to the efficacy of using antibiotics to treat this condition in children (Wald, Chiponis, and Ledesma-Medina, 1986; Wald, Reilly, Casselbrant, et al., 1984).

For this supplemental report, our objective was to identify and analyze evidence from nonrandomized studies that pertains to the diagnosis and therapeutic management of acute sinusitis in children. Compared with adults, children have a different and constantly evolving sinus anatomy, and they probably have an increased incidence of upper respiratory tract infections.

## Research Questions

With these differences in mind, the main questions addressed in this report are as follows:

1 What is the evidence for the efficacy of various antibiotics in children with a diagnosis of acute sinusitis?
2 What is the evidence for the efficacy of various ancillary regimens that do not include antibiotics in the treatment of children with acute sinusitis?
3 What is the diagnostic accuracy and concordance of clinical symptoms, radiography and other imaging methods, and aspiration for the diagnosis of acute sinusitis in children?

## Definitions

As in the original evidence report, we focused on acute uncomplicated bacterial sinusitis. Inflammation of the paranasal sinuses may be accompanied by inflammation of the nasal passages. As such, the clinical condition termed "sinusitis" may in fact be rhinosinusitis. We excluded cases where clinically evident neurological, soft tissue, or other complications were present. Usually, these cases present as medical or surgical emergencies. Acute sinusitis is defined typically by symptoms that have persisted for less than 30 days. We did not attempt to separate bacterial from nonbacterial cases in the considered reports, as this would have been impossible. But, obviously, determining the effectiveness of antibiotic management is important for the treatment of cases with a bacterial etiology.

Cure, improvement, and treatment failure definitions are based on the original reports. Cures and failures were recorded as defined by the individual study. Cure generally meant resolution of all signs and symptoms, and failure generally signified no change or a worsening of signs and symptoms. Finally, in the absence of a gold standard for diagnosing "acute uncomplicated bacterial rhinosinusitis" (other than sinus aspiration and culture, which is very infrequently used), diagnostic parameters in the comparison of diagnostic methods should be interpreted as estimates of concordance between these diagnostic modalities rather than proof of diagnostic accuracy or lack thereof.