# Evidence Table References

Ammerman A, Washington C, Jackson B, et al. The PRAISE! Project: A church-based nutrition intervention designed for cultural appropriateness, sustainability and diffusion. J Health Promotion Pract. 2002;3(2):286-301.
Angell K L, Kreshka M A, McCoy R, et al. Psychosocial intervention for rural women with breast cancer. J Gen Intern Med. 2003;18(7):499-507. [pmid: 12848832]. [pmcid: 1494883].
Arcury T A, Austin C K, Quandt S A, et al. Enhancing community participation in intervention research: farmworkers and agricultural chemicals in North Carolina. Health Educ Behav. 1999;26(4):563-78. [pmid: 10435238].
Arthur H M, Wright D M, Smith K M. Women and heart disease: the treatment may end but the suffering continues. Can J Nurs Res. 2001;33(3):17-29. [pmid: 11845619].
Baker E A, Israel B A, Schurman S J. A participatory approach to worksite health promotion. J Ambul Care Manage. 1994;17(2):68-81. [pmid: 10133290].
Baldwin J H, Rawlings A, Marshall E S, et al. Mom empowerment, too! (ME2): a program for young mothers involved in substance abuse. Public Health Nurs. 1999;16(6):376-83. [pmid: 10620246].
Banner R O, DeCambra H, Enos R, et al. A breast and cervical cancer project in a native Hawaiian community: Wai'anae cancer research project. Prev Med. 1995;24(5):447-53. [pmid: 8524718].
Becker A B, Israel B A, Schulz A J, et al. Predictors of perceived control among African American women in Detroit: exploring empowerment as a multilevel construct. Health Educ Behav. 2002;29(6):699-715. [pmid: 12456130].
Chen A M, Wismer B A, Lew R, et al. ‘Health is strength’: a research collaboration involving Korean Americans in Alameda County. Am J Prevent Med. 1997;13(6 Suppl):93-100.
Clark N M, Brown R W, Parker E, et al. Childhood asthma. Environ Health Perspect. 1999;107(Suppl 3):421-9. [pmid: 10423388]. [pmcid: 1566232].
Corbie-Smith G, Ammerman A S, Katz M L, et al. Trust, benefit, satisfaction, and burden: a randomized controlled trial to reduce cancer risk through African-American churches. J Gen Intern Med. 2003;18(7):531-41. [pmid: 12848836]. [pmcid: 1494890].
Daniel M, Green L W, Marion S A, et al. Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada. Soc Sci Med. 1999;48(6):815-32. [pmid: 10190643].
Eng E, Parker E. Measuring community competence in the Mississippi Delta: the interface between program evaluation and empowerment. Health Educ Q. 1994;21(2):199-220. [pmid: 8021148].
Evans D T, Fullilove M T, Green L, et al. Awareness of environmental risks and protective actions among minority women in Northern Manhattan. Environ Health Perspect. 2002;110(Suppl 2):271-5. [pmid: 11929738]. [pmcid: 1241173].
Factor S H, Galea S, de Duenas Geli L G, et al. Development of a “survival” guide for substance users in Harlem, New York City. Health Educ Behav. 2002;29(3):312-25. [pmid: 12038741].
Flaskerud J H, Calvillo E R. Beliefs about AIDS, health, and illness among low-income Latina women. Res Nurs Health. 1991;14(6):431-8. [pmid: 1792345].
Flaskerud J H, Nyamathi A M. Collaborative inquiry with low-income Latina women. J Health Care Poor Underserv. 2000;11(3):326-42.
Flaskerud J H, Nyamathi A M. Home medication injection among Latina women in Los Angeles: implications for health education and prevention. AIDS Care. 1996;8(1):95-102. [pmid: 8664373].
Flaskerud J H, Nyamathi A M, Uman G C. Longitudinal effects of an HIV testing and counseling programme for low-income Latina women. Ethn Health. 1997;2(12):89-103. [pmid: 9395592].
Flaskerud J H, Uman G, Lara R, et al. Sexual Practices, Attitudes and Knowledge Related to HIV Transmission in Low Income Los Angeles Hispanic Women. J Sex Res. 1996;33(4):343-53.
Galea S, Factor S H, Palermo A G, Aaron D, Canales E, Vlahov D. Access to resources for substance users in Harlem, New York City: Service provider and client perspectives. Health Educat Behav. 2002;29(3):296-311.
Gotay C C, Banner R O, Matsunaga D S, et al. Impact of a culturally appropriate intervention on breast and cervical screening among native Hawaiian women. Prev Med. 2000;31(5):529-37. [pmid: 11071833].
Green L, Fullilove M, Evans D, et al. “Hey, mom, thanks!”: use of focus groups in the development of place-specific materials for a community environmental action campaign. Environ Health Perspect. 2002;110(Suppl 2):265-9. [pmid: 11929738]. [pmcid: 1241172].
Green L W, Levine D M, Deeds S. Clinical Trials of Health Education for Hypertensive Outpatients: Design and Baseline Data. Prev Med. 1975;4:417-25. [pmid: 813195].
Heaney C A, Israel B A, Schurman S J, et al. Industrial Relations, Worksite Stress Reduction, and Employee Well-Being: A Participatory Action Research Investigation. J Org Behav. 1993;14(5):495-510.
Herbert C P. Community-based research as a tool for empowerment: the Haida Gwaii Diabetes Project example. Can J Pub Health. 1996;87(2):109-12. [pmid: 8753639].
Hugentobler M K, Israel B A, Schurman S J. An action research approach to workplace health: Integrating methods. Health Educat Q. 1992;19(1):55-76.
Israel B A, Farquhar S A, Schulz A J, et al. The relationship between social support, stress, and health among women on Detroit's East Side. Health Educ Behav. 2002;29(3):342-60. [pmid: 12038743].
Israel B A, Schurman S J, House J S. Action research on occupational stress: involving workers as researchers. Int J Health Serv. 1989;19(1):135-55. [pmid: 2925298].
Israel B A, House J S, Schurman S J, et al. The relation of personal resources, participation, influence, interpersonal relationships and coping strategies to occupational stress, job strains and health: a multivariate analysis. Work Stress. 1989;3(2):163-94.
Israel B A, Schurman S J, Hugentobler M K. Conducting Action Research: Relationships Between Organization Members and Researchers. J App Behav Science. 1992;28(1):74-101.
Keeler G J, Dvonch T, Yip F Y, et al. Assessment of personal and community-level exposures to particulate matter among children with asthma in Detroit, Michigan, as part of Community Action Against Asthma (CAAA). Environ Health Perspect. 2002;110(Suppl 2):173-81. [pmid: 11929726]. [pmcid: 1241161].
Kegler M C, Malcoe L H, Lynch R A, et al. A community-based intervention to reduce lead exposure among Native American children. Environ Epidemiol Toxicol. 2000;2:121-32.
Koopman C, Angell K, Turner-Cobb J M, et al. Distress, coping, and social support among rural women recently diagnosed with primary breast cancer. Breast J. 2001;7(1):25-33. [pmid: 11348412].
Krieger J W, Castorina J S, Walls M L, et al. Increasing influenza and pneumococcal immunization rates: a randomized controlled study of a senior center-based intervention. Am J Prev Med. 2000;18(2):123-31. [pmid: 10698242].
Krieger J W, Song L, Takaro T K, et al. Asthma and the home environment of low-income urban children: preliminary findings from the Seattle-King County healthy homes project. J Urban Health. 2000;77(1):50-67. [pmid: 10741842].
Lam T K, McPhee S J, Mock J, et al. Encouraging Vietnamese-American women to obtain Pap tests through lay health worker outreach and media education. J Gen Intern Med. 2003;18(7):516-24. [pmid: 12848834]. [pmcid: 1494888].
Levine D M, Becker D M, Bone L R, et al. A Partnership with Minority Populations: A Community Model of Effectiveness Research. Ethnic Dis. 1992;2:296-305.
Levine D M, Lawrence W G, Deeds S G, et al. Health Education for Hypertensive Patients. J Am Med Assoc. 1979;241(16):1700-3.
Macaulay A C, Cross E J, Delormier T, Potvin L, Paradis G, McComber A. Developing a Code of Research Ethics for research with a Native community in Canada: a report from the Kahnawake Schools Diabetes Prevention Project. Int J Circumpolar Health. 1998;57(Suppl 1):38-40. [pmid: 10093242].
Macaulay A C, Delormier T, McComber A M, et al. Participatory research with native community of Kahnawake creates innovative Code of Research Ethics. Can J Pub Health. 1998;89(2):105-8. [pmid: 9583251].
Macaulay A C, Paradis G, Potvin L, et al. The Kahnawake Schools Diabetes Prevention Project: intervention, evaluation, and baseline results of a diabetes primary prevention program with a native community in Canada. Prev Med. 1997;26(6):779-90. [pmid: 9388789].
Maciak B J, Guzman R, Santiago A, Villalobos G, Israel B A. Establishing LA VIDA: a community-based partnership to prevent intimate violence against Latina women. Health Educ Behav. 1999;26(6):821-40. [pmid: 10608573].
Maciak B J, Moore M T, Leviton L C, et al. Preventing Halloween arson in an urban setting: a model for multisectoral planning and community participation. Health Educ Behav. 1998;25(2):194-211. [pmid: 9548060].
Masi C M, Suarez-Balcazar Y, Cassey M Z, et al. Internet access and empowerment: a community-based health initiative. J Gen Intern Med. 2003;18(7):525-30. [pmid: 12848835]. [pmcid: 1494891].
Matsunaga D S, Enos R, Gotay C C, et al. Participatory research in a Native Hawaiian community. The Wai'anae Cancer Research Project. Cancer. 1996;78(7 Suppl):1582-6. [pmid: 8839575].
McComber A M, Macaulay A C, Kirby R, et al. The Kahnawake Schools Diabetes Prevention Project: community participation in a diabetes primary prevention research project. Int J Circumpolar Health. 1998;57(Suppl 1):370-4. [pmid: 10093308].
Morisky D A, Levine D M, Green L W, et al. Five-year blood pressure control and mortality following health education for hypertensive patients. Am J Pub Health. 1983;73(2):153-62. [pmid: 6849473]. [pmcid: 1650522].
Moyer A, Coristine M, Jamault M, Roberge G, O'Hagan M. Identifying older people in need using action research. J Clin Nurs. 1999;8(1):103-11. [pmid: 10214176].
Moyer A, Coristine M, MacLean L, Meyer M. A model for building collective capacity in community-based programs: the Elderly in Need Project. Pub Health Nurs. 1999;16(3):205-14. [pmid: 10388338].
Parker E A, Israel B A, Williams M, et al. Community action against asthma: examining the partnership process of a community-based participatory research project. J Gen Intern Med. 2003;18(7):558-67. [pmid: 12848839]. [pmcid: 1494884].
Parker E A, Lichtenstein R L, Schulz A J, et al. Disentangling measures of individual perceptions of community social dynamics: results of a community survey. Health Educ Behav. 2001;28(4):462-86. [pmid: 11465157].
Parker E A, Schulz A J, Israel B A, Hollis R. Detroit's East Side Village Health Worker Partnership: community-based lay health advisor intervention in an urban area. Health Educ Behav. 1998;25(1):24-45. [pmid: 9474498].
Perera F P, Illman S M, Kinney P L, et al. The challenge of preventing environmentally related disease in young children: community-based research in New York City. Environ Health Perspect. 2002;110(2):197-204. [pmid: 11836150]. [pmcid: 1240736].
Potvin L, Cargo M, McComber A M, et al. Implementing participatory intervention and research in communities: lessons from the Kahnawake Schools Diabetes Prevention Project in Canada. Soc Sci Med. 2003;56(6):1295-305. [pmid: 12600366].
Quandt S A, Arcury T A, Pell A I. Something for everyone? A community and academic partnership to address farmworker pesticide exposure in North Carolina. Environ Health Perspect. 2001;109(Suppl 3):435-41. [pmid: 11427393]. [pmcid: 1240562].
Quigley D, Handy D, Goble R, Sanchez V, George P. Participatory research strategies in nuclear risk management for native communities. J Health Communic. 2000;5(4):305-31.
Rosenberg Z, Findley S, McPhillips S, et al. Community-based strategies for immunizing the “hard-to-reach” child: the New York State immunization and primary health care initiative. Am J Prev Med. 1995;11(3 Suppl):14-20. [pmid: 7669356].
Schulz A J, Israel B, Williams D, et al. Social inequalities, stressors and self reported health status among African American and white women in the Detroit metropolitan area. Soc Sci Med. 2000;51(11):1639-53. [pmid: 11072884].
Schulz A J, Israel B A, Becker A B, et al. “It's a 24-hour thing … a living-for-each-other concept”: identity, networks, and community in an urban village health worker project. Health Educ Behav. 1997;24(4):465-80. [pmid: 9247825].
Schulz A J, Israel B A, Parker E A, Lockett M, Hill Y, Wills R. The East Side Village Health Worker Partnership: integrating research with action to reduce health disparities. Public Health Rep. 2001;116(6):548-57. [pmid: 12196614]. [pmcid: 1497386].
Schulz A J, Parker E A, Israel B A, Allen A, Decarlo M, Lockett M. Addressing social determinants of health through community-based participatory research: the East Side Village Health Worker Partnership. Health Educ Behav. 2002;29(3):326-41. [pmid: 12038742].
Schulz A, Parker E, Israel D B, et al. Social context, stressors, and disparities in women's health. J Am Med Womens Assoc. 2001;56(4):143-9. [pmid: 11759781].
Schulz A J, Parker E A, Israel B A, Becker A B, Maciak B J, Hollis R. Conducting a participatory community-based survey for a community health intervention on Detroit's east side. J Pub Health Manag Pract. 1998;4(2):10-24. [pmid: 10186730].
Schurman S J. Making the ‘new American workplace’ safe and healthy: a joint labor-management-researcher approach. Am J Indust Med. 1996;29(4):373-7.
Stevens P E, Hall J M. Participatory action research for sustaining individual and community change: a model of HIV prevention education. AIDS Educ Prevent. 1998;10(5):387-402.
Stevens P E. HIV Prevention Education for Lesbians and Bisexual Women: A Cultural Analysis of a Community Intervention. Soc Sci Med. 1994;39(11):1565-78. [pmid: 7817221].
van Olphen J, Schulz A, Israel B, et al. Religious involvement, social support, and health among African-American women on the east side of Detroit. J Gen Intern Med. 2003;18(7):549-57. [pmid: 12848838]. [pmcid: 1494889].
Wagenaar A C, Murray D M, Gehan J P, et al. Communities mobilizing for change on alcohol: outcomes from a randomized community trial. J Stud Alcohol. 2000;61(1):85-94. [pmid: 10627101].
Wagenaar A C, Murray D M, Toomey T L. Communities mobilizing for change on alcohol (CMCA): effects of a randomized trial on arrests and traffic crashes. Addiction. 2000;95(2):209-17. [pmid: 10723849].
Wagenaar A C, Toomey T L, Murray D M, et al. Sources of alcohol for underage drinkers. J Stud Alcohol. 1996;57(3):325-33. [pmid: 8709591].
Wagenaar AC, Murray DM, Wolfson M, et al. Communities Mobilizing for Change on Alcohol: Design of a Randomized Community Trial. J Comm Psychol 1994; Special Issue:79–101.
Wagenaar A C, Perry C L. Community Strategies for the Reduction of Youth Drinking: Theory and Application. J Res Adolesc. 1994;4(2):319-45.
Wagenaar A C, Gehan J P, Jones Webb R, et al. Communities Mobilizing for Change on Alcohol: Lessons and results from a 15-community randomized trial. J Comm Psychol. 1999;27(3):315-26.
Wismer B A, Moskowitz J M, Chen A M, et al. Mammography and clinical breast examination among Korean American women in two California counties. Prev Med. 1998a;27(1):144-51. [pmid: 9465365].
Wismer B A, Moskowitz J M, Chen A M, et al. Rates and independent correlates of Pap smear testing among Korean-American women. Am J Public Health. 1998b;88(4):656-60. [pmid: 9551013]. [pmcid: 1508456].
Wismer B A, Moskowitz J M, Min K, et al. Interim assessment of a community intervention to improve breast and cervical cancer screening among Korean American women. J Public Health Manag Pract. 2001;7(2):61-70. [pmid: 12174401].