# Listing of Excluded Studies

1 Adams M J Jr, Hollowell J G. Community-based projects for the prevention of developmental disabilities. Mental Retardation. Dec. 1992;30(6):331-6. [pmid: 1474909].
Notes: No CBPR
2 Adrien, A.; Godin, G.; Cappon, P.; Singer, S. M.; Maticka-Tyndale, E., and Willms, D. Overview of the Canadian study on the determinants of ethnoculturally specific behaviours related to HIV/AIDS. Can J Public Health. 1996 May-1996 Jun 30; 87 Suppl 1:S4–10.
Notes: Review article
3 Ammerman, A; Lindquist, C; Hersey, J and others. Evidence report on the efficacy of interventions to modify dietary behavior related to evidence risk. Rockville, MD: Agency for Healthcare Research and Quality; 2001 Jan 25.
Notes: Not relevant to intervention
4 Bailey . Using participatory research in community consortia development and evaluation: Lessons from the beginning of a story. 1992.
Notes: Review article
5 Bailey. Using Participatory Research in community diagnosis: a health education tool. 1992.
Notes: Process Evaluation
6 Baker, E. L. and Tyler, C. W. Research linkages between academia and public health practice: can they become a practical reality? Am J Prev Med. 1995 May-1995 Jun 30; 11(3 Suppl):13
Notes: Review Article
7 Baquet C R, Hammond C, Commiskey P, Brooks S, Mullins C D. Health disparities research--a model for conducting research on cancer disparities: characterization and reduction. Journal of the Association for Academic Minority Physicians. Apr. 2002;13(2):33-40. [pmid: 12362565].
Notes: No CBPR
8 Benjamin, A. E. Consumer-directed services at home: a new model for persons with disabilities. Health Affairs. 2001 Nov-2001 Dec 31; 20(6):80–95.
Notes: No research
9 Blair, L. Cutting and pasting in Quebec. Community health centres and health care reform. Can Fam Physician. 1999 Feb; 45:261–4, 268–72.
Notes: Not relevant to intervention
10 Bond F W, Bunce D. Job control mediates change in a work reorganization intervention for stress reduction. Journal of Occupational Health Psychology. Oct. 2001;6(4):290-302. [pmid: 11605824].
Notes: Location
11 Booth, Tim and Booth, Wendy. Parents Together: Action Research and Advocacy Support for Parents with Learning Difficulties. Health-and-Social-Care-in-the-Community. 1999; 7(6):Nov, 464–474.
Notes: Location
12 Bourke L. Participatory research in breast cancer: a case study in regional Victoria. Contemporary Nurse. Jun. 2002;12(3):246-52. [pmid: 12219953].
Notes: Location
13 Brown and Detterman. Small interventions for large problems:Reshaping urban leadership networks. 1987; 23, (2): 151–168.
Notes: No CBPR
14 Chenoweth L, Kilstoff K. Facilitating positive changes in community dementia management through participatory action research. International Journal of Nursing Practice. Sep. 1998;4(3):175-88. [pmid: 9844092].
Notes: Location
15 Chrisman N J, Senturia K, Tang G, Gheisar B. Qualitative process evaluation of urban community work: a preliminary view. Health Education & Behavior. Apr. 2002;29(2):232-48. [pmid: 11942717].
Notes: No study
16 Classen, C.; Abramson, S.; Angell, K.; Atkinson, A.; Desch, C.; Vinciguerra, V. P.; Rosenbluth, R. J.; Kirshner, J. J.; Hart, R.; Morrow, G., and Spiegel, D. Effectiveness of a training program for enhancing therapists' understanding of the supportive-expressive treatment model for breast cancer groups. J Psychother Pract Res. 1997 Summer; 6(3):211–8.
Notes: Not relevant to intervention
17 Cockburn L, Trentham B. Participatory action research: integrating community occupational therapy practice and research. Canadian Journal of Occupational Therapy - Revue Canadienne d Ergotherapie. Feb. 2002;69(1):20-30. [pmid: 11852687].
Notes: No CBPR
18 Cohen L K. Market and community responses to changing demands from the workplace. Community Health Studies. 1985;9(1 Suppl):18S-24S. [pmid: 4006430].
Notes: No CBPR
19 Craft M J, Willadsen J A. Interventions related to family. [Review] [35 refs]. Nursing Clinics of North America. Jun. 1992;27(2):517-40. [pmid: 1584702].
Notes: Nursing participatory research
20 Davis S M, Going S B, Helitzer D L, Teufel N I, Snyder P, Gittelsohn J, Metcalfe L, Arviso V, Evans M, Smyth M, Brice R, Altaha J. Pathways: a culturally appropriate obesity-prevention program for American Indian schoolchildren. Am J Clin Nutr. Apr. 1999;69(4 Suppl):796S-802S. [pmid: 10195605].
Notes: No CBPR
21 Davis S M, Reid R. Practicing participatory research in American Indian communities. Am J Clin Nutr. Apr. 1999;69(4 Suppl):755S-759S. [pmid: 10195598].
Notes: No CBPR
22 Dearry; Collman; Sainr; Fields, and Redd. Building a network of research om children's environmental health. 1999.
Notes: Review article
23 Deutsch S, Ognibene A. ACP Community-Based Teaching Project. Am J Med. Jun. 1995;98(6):521-3. [pmid: 7778566].
Notes: Professional Development
24 Diaz T, Sturm T, Matte T, Bindra M, Lawler K, Findley S, Maylahn C. Medication use among children with asthma in East Harlem. Pediatrics. Jun. 2000;105(6):1188-93. [pmid: 10835056].
Notes: No CBPR
25 Dickson, G. and Green, K. L. Participatory action research: lessons learned with Aboriginal grandmothers. Health Care for Women International. 2001 Jul-2001 Aug 31; 22(5):471–82.
Notes: Insufficient Information
26 Eisen, A. Survey of neighborhood-based, comprehensive community empowerment initiatives. Health Educ Q. 1994 Summer; 21(2):235–52. Notes: No Research
Notes: No Research
27 Eng, Toung. Lay Health Advisors as community change agents. Fam Community Health. 1992;15(1):24-40.
Notes: Review Article
28 Eng E and Hatch J. Networking Between Agencies and Black Churches: The Lay Health Advisor Model. In K. Pargament, K. Maton and R. Hess (eds) Religion and Prevention in Mental Health Research Vision, and Action. Springfield, IL: Haworth Press; 1993.
Notes: Book
29 Ervin, Alexander M. Collaborative and Participatory Research in Urban Social Planning and Restructuring: Anthropological Experiences from a Medium-Sized Canadian City. Human-Organization. 1996; 55(3):fall, 324–333.
Notes: Review Article
30 Felix-Aaron, Stryer. Moving from rhetoric to evidence based action in health care. 2003.
Notes: Review Article
31 Flaskerud J H, Nyamathi A M. Effects of an AIDS education program on the knowledge, attitudes and practices of low income black and Latina women. J Community Health. Dec. 1990;15(6):343-55. [pmid: 2280034].
Notes: Not relevant to intervention
32 Flaskerud, J. H. and Uman, G. Directions for AIDS education for Hispanic women based on analyses of survey findings. Public Health Rep. 1993 May-1993 Jun 30; 108(3):298–304.
Notes: Not relevant to intervention
33 Flaskerud, J. H. and Winslow, B. J. Conceptualizing vulnerable populations health-related research. Nurs Res. 1998 Mar-1998 Apr 30; 47(2):69–78.
Notes: Not relevant to intervention
34 Flynn, B. C. ; Ray, D. W., and Rider, M. S. Empowering communities: action research through healthy cities. Health Education Quarterly. 1994 Fall; 21(3):395–405.
Notes: Review Article
35 Ford M E, Edwards G, Rodriguez J L, Gibson R C, Tilley B C. An empowerment-centered, church-based asthma education program for African American adults. Health & Social Work. Feb. 1996;21(1):70-5. [pmid: 8626161].
Notes: Insufficient information
36 Levi, Lennart. Wroking Life. New York: University Press ; 1981.
Notes: Book chapter
37 Green, L. W.; George, M. A.; Daniel, M.; Franking, C. J.; Herbert, C. J.; Bowie, W. R., and et al. Study of Participatory Research in Health Promotion: Review and Recommendations for the Development of Participatory Research in Health Promotion in Canada. Ottawa, Canada: The Royal Society of Canada; 1995; ISBN-0-920064-55-8.
Notes: Book Chapter
38 Higgins, D. L.; Maciak, B.; Metzler, M., and CDC Urban Research, Centers. CDC Urban Research Centers: community-based participatory research to improve the health of urban communities. Journal of Womens Health & Gender-Based Medicine. 2001 Jan-2001 Feb 28; 10(1):9–15.
Notes: Review Article
39 Higgins D L, Metzler M. Implementing community-based participatory research centers in diverse urban settings. J Urban Health. Sep. 2001;78(3):488-94. [pmid: 11564851].
Notes: Process Evaluation
40 Holder Harold D, Moore Roland S. Institutionalization of community action projects to reduce alcohol-use related problems: Systematic facilitators. Substance-Use-and-Misuse. 2000;35(12):75-86. [pmid: 10677876].
Notes: Not research, unobtainable
41 Huby G. Interpreting silence, documenting experience: an anthropological approach to the study of health service users' experience with HIV/AIDS care in Lothian, Scotland. Social Science & Medicine. Apr. 1997;44(8):1149-60. [pmid: 9131739].
Notes: Location
42 Hugentobler Margrit K, Israel Barbara A, Schurman Susan J. An action research approach to workplace health: Integrating methods. Health-Education-Quarterly. 1992;19(1):55-76. [pmid: 1568874].
Notes: Process Evaluation
43 Israel, B. A.; Checkoway, B.; Schulz, A., and Zimmerman, M. Health education and community empowerment: conceptualizing and measuring perceptions of individual, organizational, and community control. Health Educ Q. 1994 Summer; 21(2):149–70.
Notes: Not relevant to intervention
44 Israel B A, Lichtenstein R, Lantz P, McGranaghan R, Allen A, Guzman J R, Softley D, Maciak B. The Detroit Community-Academic Urban Research Center: development, implementation, and evaluation. Journal of Public Health Management & Practice. Sep. 2001;7(5):1-19. [pmid: 11680026].
Notes: Process Evaluation
45 Jenkins C N, McPhee S J, Bird J A, Pham G Q, Nguyen B H, Nguyen T, Lai K Q, Wong C, Davis T B. Effect of a media-led education campaign on breast and cervical cancer screening among Vietnamese-American women. Prev Med. Apr. 1999;28(4):395-406. [pmid: 10090869].
Notes: Not relevant to intervention
46 Jenkins C N, McPhee S J, Le A, Pham G Q, Ha N T, Stewart S. The effectiveness of a media-led intervention to reduce smoking among Vietnamese-American men. Am J Public Health. Jun. 1997;87(6):1031-4. [pmid: 9224191]. [pmcid: 1380945].
Notes: Not relevant to intervention
47 Karim, K. Assessing the strengths and weaknesses of action research. [Review][25 refs]. Nursing Standard. 2001 Mar 14-2001 Mar 20; 15(26):33–5.
Notes: Review Article
48 Kieffer E C. Maternal obesity and glucose intolerance during pregnancy among Mexican-Americans. Paediatr Perinat Epidemiol. Jan. 2000;14(1):14-9. [pmid: 10703030].
Notes: No CBPR
49 Kieffer E C, Alexander G R, Kogan M D, Himes J H, Herman W H, Mor J M, Hayashi R. Influence of diabetes during pregnancy on gestational age-specific newborn weight among US black and US white infants. Am J Epidemiol. Jun 1. 1998;147(11):1053-61. [pmid: 9620049].
Notes: No CBPR
50 Kieffer, E. C.; Carman, W. J.; Gillespie, B. W.; Nolan, G. H.; Worley, S. E., and Guzman, J. R. Obesity and gestational diabetes among African-American women and Latinas in Detroit: implications for disparities in women's health. J Am Med Womens Assoc. 2001 Fall; 56(4):181–7, 196.
Notes: No CBPR
51 Kieffer E C, Martin J A, Herman W H. Impact of maternal nativity on the prevalence of diabetes during pregnancy among U.S. ethnic groups. Diabetes Care. May. 1999;22(5):729-35. [pmid: 10332673].
Notes: No CBPR
52 Kieffer E C, Nolan G H, Carman W J, Sanborn C Z, Guzman R, Ventura A. Glucose tolerance during pregnancy and birth weight in a Hispanic population. Obstet Gynecol. Nov. 1999;94(5 Pt 1):741-6. [pmid: 10546721].
Notes: No CBPR
53 Koopman, C.; Angell, K.; Turner-Cobb, J. M.; Kreshka, M. A.; Donnelly, P.; McCoy, R.; Turkseven, A.; Graddy, K.; Giese-Davis, J., and Spiegel, D. Distress, coping, and social support among rural women recently diagnosed with primary breast cancer. Breast J. 2001 Jan-2001 Feb 28; 7(1):25–33.
Notes: not relevant to intervention
54 Koopman, C.; Hermanson, K.; Diamond, S.; Angell, K., and Spiegel, D. Social support, life stress, pain and emotional adjustment to advanced breast cancer. Psychooncology. 1998 Mar-1998 Apr 30; 7(2):101–11.
Notes: No CBPR
55 Krieger James, Allen Carol, Cheadle Allen, Ciske Sandra, Schier James K, Senturia Kirsten, Sullivan Marianne. Using community-based participatory research to address social determinants of health: Lessons learned from Seattle Partners for Health Communities. Health-Education-and-Behavior. 2002;29(3):361-382. [pmid: 12038744].
Notes: Review Article
56 Labonte, R. Health promotion and empowerment: reflections on professional practice. Health Educ Q. 1994 Summer; 21(2):253–68.
Notes: Review Article
57 Lai; McPhee/Jenkins, and Wong. Applying the quit and win contest model in the Vietnamese community in Santa Clara county. Tob Control. 2000.
Notes: Not relevant to intervention
58 LaMontagne A D, Needleman C. Overcoming practical challenges in intervention research in occupational health and safety. American Journal of Industrial Medicine. Apr. 1996;29(4):367-72. [pmid: 8728141].
Notes: No CBPR
59 Lantz P M, Viruell-Fuentes E, Israel B A, Softley D, Guzman R. Can communities and academia work together on public health research? Evaluation results from a community-based participatory research partnership in Detroit. J Urban Health. Sep. 2001;78(3):495-507. [pmid: 11564852].
Notes: Process evaluation
60 Laurell A C, Noriega M, Martinez S, Villegas J. Participatory research on workers' health. Social Science & Medicine. Mar. 1992;34(6):603-13. [pmid: 1574728].
Notes: Location
61 Lemkau J P, Ahmed S M, Cauley K. “The history of health in Dayton”: a community-academic partnership. Am J Public Health. Aug. 2000;90(8):1216-7. [pmid: 10936999]. [pmcid: 1446339].
Notes: Report on forum
62 Lew, R.; Moskowitz, J. M.; Wismer, B. A.; Min, K.; Kang, S. H.; Chen, A. M., and Tager, I. B. Correlates of cigarette smoking among Korean American adults in Alameda County, California. Asian Am Pac Isl J Health. 2001 Winter-2002 Spring; 9(1):49–60.
Notes: not relevant to intervention
63 Lew, R.; Tanjasiri, S. P.; Kagawa-Singer, M., and Yu, J. H. Using a stages of readiness model to address community capacity on tobacco control in the Asian American and Pacific Islander community. Asian Am Pac Isl J Health. 2001 Winter-2002 Spring; 9(1):66–73.
Notes: not relevant to information
64 Lindqvist K, Timpka T, Schelp L. Ten years of experiences from a participatory community-based injury prevention program in Motala, Sweden. Public Health. Nov. 1996;110(6):339-46. [pmid: 8979749].
Notes: location
65 Malekoff Andrew. Action research: An approach to preventing substance abuse and promoting social competency. Health-and-Social-Work. 1994;19(1):46-53. [pmid: 8168779].
Notes: no research
66 McGovern T F. Vulnerability: reflection on its ethical implications for the protection of participants in SAMHSA programs. Ethics & Behavior. 1998;8(4):293-304. [pmid: 11660539].
Notes: review article
67 McPhee S J, Nguyen T, Euler G L, Mock J, Wong C, Lam T, Nguyen W, Nguyen S, Huynh Ha M Q, Do S T, Buu C. Successful promotion of hepatitis B vaccinations among Vietnamese-American children ages 3 to 18: results of a controlled trial. Pediatrics. Jun. 2003;111(6 Pt 1):1278-88. [pmid: 12777542]. [pmcid: 1592334].
Notes: Not relevant to intervention
68 Metzler M M, Higgins D L, Beeker C G, Freudenberg N, Lantz P M, Senturia K D, Eisinger A A, Viruell-Fuentes E A, Gheisar B, Palermo A G, Softley D. Addressing urban health in Detroit, New York City, and Seattle through community-based participatory research partnerships. Am J Public Health. May. 2003;93(5):803-11. [pmid: 12721148]. [pmcid: 1447843].
Notes: Review article
69 Moir S, Buchholz B. Emerging participatory approaches to ergonomic interventions in the construction industry. American Journal of Industrial Medicine. Apr. 1996;29(4):425-30. [pmid: 8728154].
Notes: insufficient information
70 Moos, R. H.; King, M. J.; Burnett, E. B., and Andrassy, J. M. Community residential program policies, services, and treatment orientations influence patients' participation in treatment. Journal of Substance Abuse. 1997; 8171–87.
Notes: review article
71 Morrison B, Lilford R. How can action research apply to health services?. Qualitative Health Research. Jul. 2001;11(4):436-49. [pmid: 11521603].
Notes: No CBPR
72 Murray D M, Clark M H, Wagenaar A C. Intraclass correlations from a community-based alcohol prevention study: the effect of repeat observations on the same communities. J Stud Alcohol. Nov. 2000;61(6):881-90. [pmid: 11188494].
Notes: not relevant to intervention
73 Nelson G, Ochocka J, Griffin K, Lord J. “Nothing about me, without me”: participatory action research with self- help/mutual aid organizations for psychiatric consumer/survivors. Am J Community Psychol. Dec. 1998;26(6):881-912. [pmid: 10085536].
Notes: review article
74 Nelson, G.; Prilleltensky, I., and MacGillivary, H. Building value-based partnerships: toward solidarity with oppressed groups. American Journal of Community Psychology. 2001 Oct; 29(5):649–77; ISSN: review article.
Notes: Review Article
75 Nguyen T T, McPhee S J, Nguyen T, Lam T, Mock J. Predictors of cervical Pap smear screening awareness, intention, and receipt among Vietnamese-American women. Am J Prev Med. Oct. 2002;23(3):207-14. [pmid: 12350454]. [pmcid: 1592337].
Notes: not relevant to intervention
76 Nyamathi, A. M.; Lewis, C.; Leake, B.; Flaskerud, J., and Bennett, C. Barriers to condom use and needle cleaning among impoverished minority female injection drug users and partners of injection drug users. Public Health Rep. 1995 Mar-1995 Apr 30; 110(2):166–72.
Notes: No CBPR
77 O'Fallon, Tyson, Dearry. Improving public health through community based participatory research and outreach. Environment Epidemol Toxicol. 2000;2:201-209.
Notes: Review Article
78 O'Fallon, L. R.; Collman, G. W., and Dearry, A. The National Institute of Environmental Health Sciences' research program on children's environmental health. J Expo Anal Environ Epidemiol. 2000 Nov-2000 Dec 31; 10(6 Pt 2):630–7.
Notes: REVIEW ARTICLE
79 O'Fallon L R, Dearry A. Commitment of the National Institute of Environmental Health Sciences to community-based participatory research for rural health. Environ Health Perspect. Jun. 2001;109(Suppl 3):469-73. [pmid: 11427398]. [pmcid: 1240567].
Notes: Review Article
80 ---. Community-based participatory research as a tool to advance environmental health sciences. Environmental Health Perspectives. 2002 Apr; 110 Suppl 2:155–9. Notes: Review Article
Notes: Review Article
81 Oliver S, Milne R, Bradburn J, Buchanan P, Kerridge L, Walley T, Gabbay J. Involving consumers in a needs-led research programme: a pilot project. [see comments.]. Health Expectations. Mar. 2001;4(1):18-28. [pmid: 11286596].
Notes: Locations
82 Paine-Andrews A, Harris K J, Fawcett S B, Richter K P, Lewis R K, Francisco V T, Johnston J, Coen S. Evaluating a statewide partnership for reducing risks for chronic diseases. Journal of Community Health. Oct. 1997;22(5):343-59. [pmid: 9353682].
Notes: process evaluation
83 Pellow, David N. Popular Epidemiology and Environmental Movements: Mapping Active Narratives for Empowerment. Humanity-and-Society. Aug. 1997;21(3):307-321.
Notes: no CBPR
84 Plough, A. and Olafson, F. Implementing the Boston Healthy Start Initiative: a case study of community empowerment and public health. Health Educ Q. 1994 Summer; 21(2):221–34.
Notes: NO RESEARCH
85 Reardon; Walsh; Kreiswirth, and Forester. Participatory action research from the inside: community development practice in East St. Loius. Am Sociol. 1993.
Notes: Review Article
86 Richardson M. How we live: participatory research with six people with learning difficulties. Journal of Advanced Nursing. Dec. 2000;32(6):1383-95. [pmid: 11136406].
Notes: location
87 Rodriguez, R. The power of the collective: battered migrant farmworker women creating safe spaces. Health Care for Women International. 1999 Jul-1999 Aug 31; 20(4):417–26; ISSN: no CBPR.
Notes: No CBPR
88 Sarri Rosemary C, Sarri Catherine M. Organizational and Community Change through Participatory Action. Administration-in-Social-Work. 1992;16(34):99-122.
Notes: Not research
89 Savitz; Arbuckle; Kaczor, and Curtis. Male Pesticide and pregnancy outcomes. Am J Epidemiol. 1997.
Notes: No CBPR
90 Schulz; Williams; Israel, and Lempert. Racial and spatial relationships as fundamantal determinants of health in Detroit. Milbank Quarter. 2002.
Notes: not revelevant to intervention
91 Secker-Walker; Gnich, and Platt. Cochrane Review: Community interventions for reducing smoking among adults. Cochrane Library . 2002; (4).
Notes: No CBPR
92 Sowden and Arblaster. Cochrane Review: Community interventions for preventing smoking in young people. Cochrane Library. 2002; (4).
Notes: No CBPR
93 Stebbins M W, Snow C C. Processes and payoffs of programmatic action research. [Review] [22 refs]. Journal of Applied Behavioral Science. 1982;18(1):69-86. [pmid: 10298658].
Notes: Not health
94 Stein B D, Kataoka S, Jaycox L H, Wong M, Fink A, Escudero P, Zaragoza C. Theoretical basis and program design of a school-based mental health intervention for traumatized immigrant children: a collaborative research partnership. Journal of Behavioral Health Services & Research. Aug. 2002;29(3):318-26. [pmid: 12216375].
Notes: professional development
95 Steuart GW. Social and cultural perspectives: community intervention and mental health. Health Educ Q. 1993.
Notes: Review article
96 Stoecker and Bonacich. Why Participatory Research? Guest Editors' Introduction. Am Sociol. 1992.
Notes: Review article
97 Stoecker and Stuber. Participatory Research, PT. II. Am Sociol. 1993.
Notes: Review article
98 Suderman, E. M.; Deatrich, J. V.; Johnson, L. S., and Sawatzky-Dickson, D. M. Action research sets the stage to improve discharge preparation. Pediatric Nursing. 2000 Nov-2000 Dec 31; 26(6):571–6.
Notes: Nursing participatory research
99 Sullivan; Kone; Senturia, and Chrisman. History of community-based research in Seattle. Health Educ. in progress.
Notes: review article
100 ---. Researcher and researched- community perspectives: Toward bridging the gap. Health Educ. 1993.
Notes: review article
101 Tasa, K.; Baker, G. R., and Murray, M. Using patient feedback for quality improvement. Quality Management in Health Care. 1996 Winter; 4(2):55–67.
Notes: No CBPR
102 Travers. Reducing inequities through participatory research and community empowerment. Health Educ. 1997.
Notes: No CBPR
103 Turner-Cobb/ /Sephton and Koopman. Social support and salivary cortisol in women with metastatic breast cancer. Psychosomatic Med. 2000.
Notes: not relevant to information
104 Turner, N. H.; O'Dell, K. J.; Weaver, G. D.; Ramirez, G. Y., and Turner, G. Community's role in the promotion of recovery from addiction and prevention of relapse among women: an exploratory study. Ethnicity & Disease. 1998 Winter; 8(1):26–35.
Notes: No CBPR
105 Wallerstein, N. A participatory evaluation model for Healthier Communities: developing indicators for New Mexico. Public Health Rep. 2000 Mar-2000 Jun 30; 115(2–3):199–204.
Notes: insufficient information
106 ---. Power between evaluator and community: research relationships within New Mexico's healthier communities. Social Science & Medicine. 1999 Jul; 49(1):39–53.
Notes: no study
107 ---. Powerlessness, empowerment, and health: implications for health promotion programs. Am J Health Promot. 1992 Jan-1992 Feb 28; 6(3):197–205.
Notes: No study
108 Wallerstein, N. and Bernstein, E. Introduction to community empowerment, participatory education, and health. Health Educ Q. 1994 Summer; 21(2):141–8.
Notes: no study/insufficient information
109 Walters S, East L. The cycle of homelessness in the lives of young mothers: the diagnostic phase of an action research project. Journal of Clinical Nursing. Mar. 2001;10(2):171-9. [pmid: 11820337].
Notes: location
110 West B J, Brockman S J, Scott A. Action research and standards of care. The prevention and treatment of pressure sores in elderly patients. Health Bulletin. Nov. 1991;49(6):356-61. [pmid: 1765486].
Notes: No CBPR
111 Willms, D.; Bhatia, R.; Lowe, J.; Niemi, F.; Stewart, D., and Westmoreland-Traore, J. Five conversations: reflections of stakeholders on the impact of the ethnocultural communities facing AIDS study. Canadian Journal of Public Health. Revue Canadienne De Sante Publique. 1996 May-1996 Jun 30; 87 Suppl 1:S44–8, S49–53.
Notes: process evaluation
112 Young L E, Jillings C R. Qualitative methods add quality to cardiovascular science. Can J Cardiol. Jun. 2000;16(6):793-7. [pmid: 10863170].
Notes: no research