# References and Included Studies

1 Institute of Medicine, Committee for the Study of the Future of Public Health, Division of Health Care Services. The Future of Public Health. Washington, D.C.: National Academy Press, 1988.
2 Green L W, Mercer S L. Can public health researchers and agencies reconcile the push from funding bodies and the pull from communities?. Am J Public Health. 2001;91(12):1926-9. [pmid: 11726367]. [pmcid: 1446906].
3 Olden K, Guthrie J, Newton S. A bold new direction for environmental health research. Am J Public Health. 2001;91(12):1964-7. [pmid: 11726375]. [pmcid: 1446914].
4 O'Neill EH. Health Professions education in the Future: Schools in Service to the Nation. San Francisco, Ca: Pew Health Professions Commission, 1993.
5 Cassel J C. The contribution of social environment to host resistance. Am J Epidemiol. 1976;104:107-23. [pmid: 782233].
6 Satel S. The indoctrinologists are coming. Atlantic Monthly 2001; 59–64.
7 Kaplan C D. What works in drug abuse epidemiology in Europe. J Addict Dis. 1991;11(1):47-59. [pmid: 1790152].
8 Berg A. Sliding toward nutrition malpractice: time to reconsider and redeploy. Am J Clin Nutr. 1993;57(1):3-7. [pmid: 8237881].
9 Mittelmark M B, Hunt M K, Heath G W, et al. Realistic outcomes: lessons from community-based research and demonstration programs for the prevention of cardiovascular diseases. J Public Health Policy. 1993;14(4):437-62. [pmid: 8163634].
10 Aguirre-Molina M, Gorman D M. Community-based approaches for the prevention of alcohol, tobacco, and other drug use. Annu Rev Public Health. 1996;17:337-58. [pmid: 8724231].
11 Israel B A, Schulz A J, Parker E A, et al. Review of community-based research: assessing partnership approaches to improve public health. Annu Rev Public Health. 1998;19:173-202. [pmid: 9611617].
12 Davis S M, Reid R. Practicing participatory research in American Indian communities. Am J Clin Nutr. 1999;69(4 Suppl):755S-9S. [pmid: 10195598].
13 Rappaport J. Research methods and the empowerment social agenda. In: Tolan P, Keys C, Chertok F, Jason L, eds. Research Community Psychology: Issues of Theory and Methods. Washington, DC: American Psychological Association, 1990.
14 Gamble V N. Under the shadow of Tuskegee: African Americans and health care. Am J Public Health. 1997;87(11):1773-8. [pmid: 9366634]. [pmcid: 1381160].
15 Corbie-Smith G, Thomas S B, Williams M V, et al. Attitudes and beliefs of African Americans toward participation in medical research. J Gen Intern Med. 1999;14(9):537-46. [pmid: 10491242]. [pmcid: 1496744].
16 Thomas S B, Quinn S C. The Tuskegee Syphilis Study, 1932 to 1972: implications for HIV education and AIDS risk education programs in the black community. Am J Public Health. 1991;81(11):1498-505. [pmid: 1951814]. [pmcid: 1405662].
17 Hatch J, Moss N, Saran A, et al. Community research: partnership in black communities. Am J Prev Med 1993; 9(6 Suppl):27–31; discussion 32–4.
18 Wallerstein N, Bernstein E. Introduction to community empowerment, participatory education, and health. Health Educ Q. 1994;21(2):141-8. [pmid: 8021144].
19 Goodman R M, Speers M A, McLeroy K, et al. Identifying and defining the dimensions of community capacity to provide a basis for measurement. Health Educ Behav. 1998;25(3):258-78. [pmid: 9615238].
20 Cornwall A, Jewkes R. What is participatory research?. Soc Sci Med. 1995;41(12):1667-76. [pmid: 8746866].
21 Green LW, George MA, Daniel M et al. Study of Participatory Research in Health Promotion: Review and Recommendations for the Development of Participatory Research in Health Promotion in Canada. Ottawa, Canada: The Royal Society of Canada, 1995; ISBN-0-920064-55-8.
22 Green LW, George MA, Daniel M, et al. Background on participatory research. In: Murphy D, Scammell M, Sclove R, eds. Doing Community-Based Research: A Reader. Amherst, MA: Loka Institute, 1997: 53–66.
23 George M A, Daniel M, Green L W. Apprasing and funding participatory research in health promotion. Int Q Comm Health Educ. 1998;18:181-97.
24 Steckler A, Dodds J. Changing promotion and tenure guidelines to include practice: one public health school's experience. J Public Health Manag Pract. 1998;4(4):114-9. [pmid: 10186751].
25 Schon DA. Knowing in action: The new scholarship requires a new epistemology. Change 1995; 27–34.
26 Seifer S D. Service-learning: community-campus partnerships for health professions education. Acad Med. 1998;73(3):273-7. [pmid: 9526454].
27 Stevens R H. Public health practice in schools of public health: is there a fit?. J Public Health Manag Pract. 2000;6(1):32-7. [pmid: 10724689].
28 Association of Schools of Public Health. Demonstrating Excellence in Academic Public Health Practice. Washington DC: Association of Schools of Public Health, 1999.
29 Stoecker R. Are academics irrelevant? Roles for scholars in participatory research. Am Behav Sci. 1999;42:840-54.
30 Brown L D, Tandon R. Ideology and political economy in inquiry: Action research and participatory research. J Appl Behav Sci. 1983;19:277-94.
31 Schensul S L. Science, theory and application in anthropology. Am Behav Scient. 1985;29:164-85.
32 Israel B A, Schurman S J, House J S. Action research on occupational stress: involving workers as researchers. Int J Health Serv. 1989;19(1):135-55. [pmid: 2925298].
33 Hall BL. From margins to center? The development and purpose of participatory research. Am Sociol 1992; 23(15–28).
34 Himmelman AT . Communities Working Collaboratively for a Change. Minneapolis, MN: Humphrey Institute for Public Affiars: University of Minnesota, 1992.
35 Butterfoss F D, Goodman R M, Wandersman A. Community coalitions for prevention and health promotion. Health Educ Res. 1993;8(3):315-30. [pmid: 10146473].
36 Altman D G. Sustaining interventions in community systems: on the relationship between researchers and communities. Health Psychol. 1995;14(6):526-36. [pmid: 8565927].
37 Schensul JJ, Denelli-Hess D, Borreo MG, et al. Urban comadronas: Maternal and child health research and policy formulation in a Puerto Rican community. In: Stull DD, Schensul JJ, eds. Collaborative Research and Social Changes: Applied Anthrology in Action. Boulder, Col: Westview Press, 1987.
38 Brown P. The role of the evaluator in comprehensive community initiatives. In: Connel JP, Kubisch AC, Schorr LB, Weiss CH, eds. New Approaches to Evaluating Community Initiatives. Washington, DC: Aspen, 1995.
39 Cousins JB, Earl LM, eds. Participatory Evaluation: Studies in Evaluation Use and Organizational Learning. London: Falmer, 1995.
40 Schulz A J, Parker E A, Israel B A, et al. Conducting a participatory community-based survey: Collecting and interpreting data from a community health intervention on Detroit's East Side. J Public Health Manag Pract. 1997;4(2):10-24. [pmid: 10186730].
41 Vega W A. Theoretical and pragmatic implications of cultural diversity for community research. Am J Comm Psychol. 1992;20:375-91.
42 Dressler W W. Commentary on “Community research: Partnership in Black communities”. J Prev Med. 1993;9:31-4.
43 Gaventa J. The powerful, the powerless, and the experts: Knowledge struggles in an information age. In: Park P, Brydon-Miller M, Hall B, Jackson T, eds. Voices of Change: Participatory Research in the United States and Canada. Westport, CT: Bergin, Garvey, 1993.
44 Elden M, Levin M. Natural Helper Models to Enhance a Community's Competence. In: Whyte WF, ed. Participatory Action Research. Newbury Park, CA: Sage, 1994.
45 Bishop R. Addressing issues of self-determination and legitimation in Kaupapa Maori research. In: Webber B, ed. Research Perspectives in Maori Education. Wellington, New Zealand: Council on Education Research, 1996.
46 deKoning K, Martin M. Participatory research in health: Setting the context. In: deKoning K, Martin M, eds. Participatory Research in Health: Issues and Experiences. London: Zed Books, 1996.
47 Maguire P. Considering more feminist participatory research: What's congruency got to do with it?. Qual Inq. 1996;2:106-18.
48 Conference on Community-Based Participatory Research -- Conference Minutes [Web Page]. Available at http://www.ahcpr.gov/about/cpcr/cbpr/.
49 Suderman E M, Deatrich J V, Johnson L S, Sawatzky-Dickson D M. Action research sets the stage to improve discharge preparation. Pediat Nurs. 2000;26(6):571-6.
50 Craft M J, Willadsen J A. Interventions related to family. Nurs Clin North Am. 1992;27(2):517-40. [pmid: 1584702].
51 Glasgow R E, Bull S S, Gillette C, et al. Behavior change intervention research in healthcare settings: a review of recent reports with emphasis on external validity. Am J Prev Med. 2002;23(1):62-9. [pmid: 12093425].
52 Keyserling T C, Ammerman A S, Davis C E, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135-45. [pmid: 9075448].
53 Israel B A, Lichtenstein R, Lantz P, et al. The Detroit Community-Academic Urban Research Center: development, implementation, and evaluation. J Pub Health Manag Pract. 2001;7(5):1-19. [pmid: 11680026].
54 Higgins D L, Maciak B, Metzler M. CDC Urban Research C. CDC Urban Research Centers: community-based participatory research to improve the health of urban communities. J Womens Health Gend Based Med. 2001;10(1):9-15. [pmid: 11224940].
55 Higgins D L, Metzler M. Implementing community-based participatory research centers in diverse urban settings. J Urban Health. 2001;78(3):488-94. [pmid: 11564851].
56 Freudenberg N. Case history of the Center for Urban Epidemiologic Studies in New York City. J Urban Health. 2001;78(3):508-18. [pmid: 11564853].
57 Eisinger A, Senturia K. Doing community-driven research: a description of Seattle Partners for Healthy Communities. J Urban Health. 2001;78(3):519-34. [pmid: 11564854].
58 Lantz P M, Viruell-Fuentes E, Israel B A, et al. Can communities and academia work together on public health research? Evaluation results from a community-based participatory research partnership in Detroit. J Urban Health. 2001;78(3):495-507. [pmid: 11564852].
59 O'Fallon L R, Dearry A. Community-based participatory research as a tool to advance environmental health sciences. Environ Health Perspect. 2002;110(Suppl 2):155-9. [pmid: 11929724]. [pmcid: 1241159].
60 National Institute of Environmental Health Sciences, Division of Extramural Research and Training. Interagency Working Group for Community-based Participatory Research [Web Page]. Available at http://www.niehs.nih.gov/translat/IWG/iwghome.htm.
61 Lohr K N, Carey T S. Assessing “best evidence”: issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25(9):470-9. [pmid: 10481816].
62 West SL, King V, Carey TS et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report, Technology Assessment No. 47: Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016, 2002.
63 Graves W H. NIDRR plans for the future. Assist Technol. 1993;5(1):3-6. [pmid: 10171663].
64 Holder H D, Moore R S. Institutionalization of community action projects to reduce alcohol-use related problems: Systematic facilitators. Substance Use Misuse. 2000;35(12):75-86. [pmid: 10677876].
65 Batalden P B, Cronenwett L R, Brown L L, et al. Collaboration in improving care for patients: how can we find out what we haven't been able to figure out yet?. Jt Comm J Qual Improv. 1998;24(10):609-18. [pmid: 9801960].
66 Chesler M A. Participatory action research with self-help groups: an alternative paradigm for inquiry and action. Am J Comm Psychol. 1991;19(5):757-68.
67 Kovacs P J. Participatory action research and hospice: a good fit. Hospice J Physic Psychosoc Pastor Care Dying. 2000;15(3):55-62.
68 Mason R, Boutilier M. The challenge of genuine power sharing in participatory research: the gap between theory and practice. Can J Comm Ment Health. 1996;15(2):145-52.
69 Minkler M. Using Participatory Action Research to build Healthy Communities. Public Health Rep. 2000;115(23):191-7. [pmid: 10968753]. [pmcid: 1308710].
70 Quigley D, Handy D, Goble R, Sanchez V, George P. Participatory research strategies in nuclear risk management for native communities. J Health Communic. 2000;5(4):305-31.
71 Smith S E, Pyrch T, Lizardi A O. Participatory action-research for health. World Health Forum. 1993;14(3):319-24. [pmid: 8397751].
72 Stein B D, Kataoka S, Jaycox L H, et al. Theoretical basis and program design of a school-based mental health intervention for traumatized immigrant children: a collaborative research partnership. J Behav Health Serv Res. 2002;29(3):318-26. [pmid: 12216375].
73 Wang C C, Yi W K, Tao Z W, Carovano K. Photovoice as a participatory health promotion strategy. Health Promot Int. 1998;13(1):75-86.
74 Anyanwu C N. The technique of participatory research in community development. Community Develop J. 1988;23(1):11-5.
75 Badger T G. Action research, change and methodological rigour. J Nurs Manag. 2000;8(4):201-7. [pmid: 11309911].
76 Boston P, Jordan S, MacNamara E, et al. Using participatory action research to understand the meanings aboriginal Canadians attribute to the rising incidence of diabetes. Chron Dis Can. 1997;18(1):5-12.
77 Herbert C P. Community-based research as a tool for empowerment: the Haida Gwaii Diabetes Project example. Can J Pub Health. 1996;87(2):109-12. [pmid: 8753639].
78 Macaulay A C, Delormier T, McComber A M, et al. Participatory research with native community of Kahnawake creates innovative Code of Research Ethics. Can J Pub Health. 1998;89(2):105-8. [pmid: 9583251].
79 Seeley J A, Kengeya-Kayondo J F, Mulder D W. Community-based HIV/AIDS research--whither community participation? Unsolved problems in a research programme in rural Uganda. Soc Sci Med. 1992;34(10):1089-95. [pmid: 1641670].
80 Stewart R, Bhagwanjee A. Promoting group empowerment and self-reliance through participatory research: a case study of people with physical disability. Disabil Rehab. 1999;21(7):338-45.
81 Wallerstein N. A participatory evaluation model for Healthier Communities: developing indicators for New Mexico. Public Health Rep. 2000;115(23):199-204. [pmid: 10968754]. [pmcid: 1308711].
82 Drevdahl D. Coming to voice: the power of emancipatory community interventions. Adv Nurs Sci. 1995;18(2):13-24.
83 Hagey R S. The use and abuse of participatory action research. Chronic Dis Can. 1997;18(1):1-4. [pmid: 9188513].
84 Macleod C. Research as intervention within community mental health. Curationis. 1997;20(2):53-6. [pmid: 9418416].
85 Singer M. Community-Centered Praxis: Toward an Alternative Non-Dominative Applied Anthropology. Hum Organ 1994; 53(4):winter, 336–44.
86 Townsend E, Birch D E, Langley J, Langille L. Participatory research in a mental health clubhouse. Occupat Ther J Res. 2000;20(1):18-44.
87 VanderPlaat M. Emancipatory Politics, Critical Evaluation and Government Policy. Washington, DC: American Sociological Association, 1997.
88 Wing S. Social responsibility and research ethics in community-driven studies of industrialized hog production. Environ Health Perspect. 2002;110(5):437-44. [pmid: 12488227]. [pmcid: 1240831].
89 Stern G. Research, action, and social betterment. Am Behav Sci. 1985;29(2):229-48.
90 Weissberg R P, Greenberg M T. Prevention science and collaborative community action research: Combining the best from both perspectives. J Ment Health UK. 1998;7(5):479-92.
91 Diaz M, Simmons R. When is research participatory? Reflections on a reproductive health project in Brazil. J Womens Health. 1999;8(2):175-84. [pmid: 10100131].
92 Moyer A, Coristine M, MacLean L, Meyer M. A model for building collective capacity in community-based programs: the Elderly in Need Project. Pub Health Nurs. 1999;16(3):205-14. [pmid: 10388338].
93 Flynn B C, Ray D W, Rider M S. Empowering communities: action research through healthy cities. Health Educat Q. 1994;21(3):395-405.
94 Stebbins M W, Snow C C. Processes and payoffs of programmatic action research. J Appl Behav Sci. 1982;18(1):69-86. [pmid: 10298658].
95 Chrisman N J, Senturia K, Tang G, Gheisar B. Qualitative process evaluation of urban community work: a preliminary view. Health Educat Beh. 2002;29(2):232-48.
96 Biggs S . Resource-poor farmer participation in research: A synthesis of experiences from nine national agricultural research systems, OFCOR Comparative Study Paper 3. The Hague: International Service for National Agricultural Research, 1989.
97 Freire P. Pedagogy of the Oppressed. New York: Seabury Press, 1970.
98 Habermas J. The Theory of Communicative Action. Cambridge, Mass: Polity Press, 1984.
99 Wang C, Burris M A, Ping X Y. Chinese village women as visual anthropologists: a participatory approach to reaching policymakers. Soc Sci Med. 1996;42(10):1391-400. [pmid: 8735895].
100 Green L, Fullilove M, Evans D, et al. “Hey, mom, thanks!”: use of focus groups in the development of place-specific materials for a community environmental action campaign. Environ Health Perspect. 2002;110(Suppl 2):265-9. [pmid: 11929738]. [pmcid: 1241172].
101 Ivanov L L, Flynn B C. Utilization and satisfaction with prenatal care services. West J Nurs Res. 1999;21(3):372-86. [pmid: 11512204].
102 Giesbrecht N, Ferris J. Community-based research initiatives in prevention. Addiction. 1993;88(Suppl):83S-93S. [pmid: 8453349].
103 McQuiston T H. Empowerment evaluation of worker safety and health education programs. Am J Ind Med. 2000;38(5):584-97. [pmid: 11071691].
104 Wang C C. Photovoice: a participatory action research strategy applied to women's health. J Women Health. 1999;8(2):185-92.
105 Green L, Daniel M, Novick L. Partnerships and coalitions for community-based research. Public Health Rep. 2001;116(Suppl 1):20-31. [pmid: 11889272]. [pmcid: 1913672].
106 Schulz A J, Parker E A, Israel B A, Becker A B, Maciak B J, Hollis R. Conducting a participatory community-based survey for a community health intervention on Detroit's east side. J Pub Health Manag Pract. 1998;4(2):10-24. [pmid: 10186730].
107 Casswell S. A decade of community action research. Subst Use Misuse. 2000;35(12):55-74. [pmid: 10677875].
108 Spigner C. African Americans, Democracy, and Biomedical and Behavioral Research: Contradictions or Consensus in Community-Based Participatory Research?. Int Q Community Health Educ. 1999-2000;19(3):259. [pmid: 16021781].
109 Jensen G M, Royeen C B. Improved rural access to care: dimensions of best practice. J Interprof Care. 2002;16(2):117-28. [pmid: 12028893].
110 Labonte R. Health promotion and empowerment: reflections on professional practice. Health Educ Q. 1994;21(2):253-68. [pmid: 8021151].
111 Reason P, Torbert W R. The Action Turn: Toward a Transformational Social Science. Concepts Transform. 2001;6(1):1-37.
112 Schulz A J, Parker E A, Israel B A, Allen A, Decarlo M, Lockett M. Addressing social determinants of health through community-based participatory research: the East Side Village Health Worker Partnership. Health Educ Behav. 2002;29(3):326-41. [pmid: 12038742].
113 Wagenaar A C, Murray D M, Toomey T L. Communities mobilizing for change on alcohol (CMCA): effects of a randomized trial on arrests and traffic crashes. Addiction. 2000;95(2):209-17. [pmid: 10723849].
114 Wagenaar AC , Murray DM, Wolfson M, et al. Communities Mobilizing for Change on Alcohol: Design of a Randomized Community Trial. J Comm Psychol 1994; Special Issue:79–101.
115 Wagenaar A C, Murray D M, Gehan J P, et al. Communities mobilizing for change on alcohol: outcomes from a randomized community trial. J Stud Alcohol. 2000;61(1):85-94. [pmid: 10627101].
116 Wagenaar A C, Gehan J P, Jones Webb R, et al. Communities Mobilizing for Change on Alcohol: Lessons and results from a 15-community randomized trial. J Comm Psychol. 1999;27(3):315-26.
117 Wagenaar A C, Perry C L. Community Strategies for the Reduction of Youth Drinking: Theory and Application. J Res Adolesc. 1994;4(2):319-45.
118 Wagenaar A C, Toomey T L, Murray D M, et al. Sources of alcohol for underage drinkers. J Stud Alcohol. 1996;57(3):325-33. [pmid: 8709591].
119 Green L W, Levine D M, Deeds S. Clinical Trials of Health Education for Hypertensive Outpatients: Design and Baseline Data. Prev Med. 1975;4:417-25. [pmid: 813195].
120 Levine D M, Green L W, Deeds S G, et al. Health Education for Hypertensive Patients. J Am Med Assoc. 1979;241(16):1700-3.
121 Morisky D A, Levine D M, Green L W, et al. Five-Year Blood Pressure Control and Mortality Following Health Education for Hypertensive Patients. Am J Pub Health. 1983;73(2):153-62. [pmid: 6849473]. [pmcid: 1650522].
122 Levine D M, Becker D M, Bone L R, et al. A Partnership with Minority Populations: A Community Model of Effectiveness Research. Ethnic Dis. 1992;2:296-305.
123 Lam T K, McPhee S J, Mock J, et al. Encouraging Vietnamese-American women to obtain Pap tests through lay health worker outreach and media education. J Gen Intern Med. 2003;18(7):516-24. [pmid: 12848834]. [pmcid: 1494888].
124 Koopman C, Angell K, Turner-Cobb J M, et al. Distress, coping, and social support among rural women recently diagnosed with primary breast cancer. Breast J. 2001;7(1):25-33. [pmid: 11348412].
125 Angell K L, Kreshka M A, McCoy R, et al. Psychosocial intervention for rural women with breast cancer. J Gen Intern Med. 2003;18(7):499-507. [pmid: 12848832]. [pmcid: 1494883].
126 Flaskerud J H, Nyamathi A M, Uman G C. Longitudinal effects of an HIV testing and counseling programme for low-income Latina women. Ethn Health. 1997;2(12):89-103. [pmid: 9395592].
127 Flaskerud J H, Nyamathi A M. Collaborative inquiry with low-income Latina women. J Health Care Poor Underserv. 2000;11(3):326-42.
128 Flaskerud J H, Nyamathi A M. Home medication injection among Latina women in Los Angeles: implications for health education and prevention. AIDS Care. 1996;8(1):95-102. [pmid: 8664373].
129 Flaskerud J H, Uman G, Lara R, et al. Sexual Practices, Attitudes and Knowledge Related to HIV Transmission in Low Income Los Angeles Hispanic Women. J Sex Res. 1996;33(4):343-53.
130 Flaskerud J H, Calvillo E R. Beliefs about AIDS, health, and illness among low-income Latina women. Res Nurs Health. 1991;14(6):431-8. [pmid: 1792345].
131 Masi C M, Suarez-Balcazar Y, Cassey M Z, et al. Internet access and empowerment: a community-based health initiative. J Gen Intern Med. 2003;18(7):525-30. [pmid: 12848835]. [pmcid: 1494891].
132 Wismer B A, Moskowitz J M, Min K, et al. Interim assessment of a community intervention to improve breast and cervical cancer screening among Korean American women. J Public Health Manag Pract. 2001;7(2):61-70. [pmid: 12174401].
133 Chen A M, Wismer B A, Lew R, et al. ‘Health is strength’: a research collaboration involving Korean Americans in Alameda County. Am J Prevent Med. 1997;13(6 Suppl):93-100.
134 Wismer B A, Moskowitz J M, Chen A M, et al. Rates and independent correlates of Pap smear testing among Korean-American women. Am J Public Health. 1998;88(4):656-60. [pmid: 9551013]. [pmcid: 1508456].
135 Daniel M, Green L W, Marion S A, et al. Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada. Soc Sci Med. 1999;48(6):815-32. [pmid: 10190643].
136 Gotay C C, Banner R O, Matsunaga D S, et al. Impact of a culturally appropriate intervention on breast and cervical screening among native Hawaiian women. Prev Med. 2000;31(5):529-37. [pmid: 11071833].
137 Matsunaga D S, Enos R, Gotay C C, et al. Participatory research in a Native Hawaiian community. The Wai'anae Cancer Research Project. Cancer. 1996;78(7 Suppl):1582-6. [pmid: 8839575].
138 Banner R O, DeCambra H, Enos R, et al. A breast and cervical cancer project in a native Hawaiian community: Wai'anae cancer research project. Prev Med. 1995;24(5):447-53. [pmid: 8524718].
139 Rosenberg Z, Findley S, McPhillips S, et al. Community-based strategies for immunizing the “hard-to-reach” child: the New York State immunization and primary health care initiative. Am J Prev Med. 1995;11(3 Suppl):14-20. [pmid: 7669356].
140 Hugentobler M K, Israel B A, Schurman S J. An action research approach to workplace health: Integrating methods. Health Educat Q. 1992;19(1):55-76.
141 Heaney C A, Israel B A, Schurman S J, et al. Industrial Relations, Worksite Stress Reduction, and Employee Well-Being: A Participatory Action Research Investigation. J Org Behav. 1993;14(5):495-510.
142 Baker E A, Israel B A, Schurman S J. A participatory approach to worksite health promotion. J Ambul Care Manage. 1994;17(2):68-81. [pmid: 10133290].
143 Schurman S J. Making the ‘new American workplace’ safe and healthy: a joint labor-management-researcher approach. Am J Indust Med. 1996;29(4):373-7.
144 Stevens P E. HIV Prevention Education for Lesbians and Bisexual Women: A Cultural Analysis of a Community Intervention. Soc Sci Med. 1994;39(11):1565-78. [pmid: 7817221].
145 Stevens P E, Hall J M. Participatory action research for sustaining individual and community change: a model of HIV prevention education. AIDS Educ Prevent. 1998;10(5):387-402.
146 Keeler G J, Dvonch T, Yip F Y, et al. Assessment of personal and community-level exposures to particulate matter among children with asthma in Detroit, Michigan, as part of Community Action Against Asthma (CAAA). Environ Health Perspect. 2002;110(Suppl 2):173-81. [pmid: 11929726]. [pmcid: 1241161].
147 Parker E A, Israel B A, Williams M, et al. Community action against asthma: examining the partnership process of a community-based participatory research project. J Gen Intern Med. 2003;18(7):558-67. [pmid: 12848839]. [pmcid: 1494884].
148 Clark N M, Brown R W, Parker E, et al. Childhood asthma. Environ Health Perspect. 1999;107(Suppl 3):421-9. [pmid: 10423388]. [pmcid: 1566232].
149 Corbie-Smith G, Ammerman A S, Katz M L, et al. Trust, benefit, satisfaction, and burden: a randomized controlled trial to reduce cancer risk through African-American churches. J Gen Intern Med. 2003;18(7):531-41. [pmid: 12848836]. [pmcid: 1494890].
150 Ammerman A, Washington C, Jackson B, et al. The PRAISE! Project: A church-based nutrition intervention designed for cultural appropriateness, sustainability and diffusion. J Health Promotion Pract. 2002;3(2):286-301.
151 Krieger J W, Song L, Takaro T K, et al. Asthma and the home environment of low-income urban children: preliminary findings from the Seattle-King County healthy homes project. J Urban Health. 2000;77(1):50-67. [pmid: 10741842].
152 Krieger J W, Castorina J S, Walls M L, et al. Increasing influenza and pneumococcal immunization rates: a randomized controlled study of a senior center-based intervention. Am J Prev Med. 2000;18(2):123-31. [pmid: 10698242].
153 Kegler M C, Malcoe L H, Lynch R A, et al. A community-based intervention to reduce lead exposure among Native American children. Environ Epidemiol Toxicol. 2000;2:121-32.
154 Moyer A, Coristine M, Jamault M, Roberge G, O'Hagan M. Identifying older people in need using action research. J Clin Nurs. 1999;8(1):103-11. [pmid: 10214176].
155 van Olphen J, Schulz A, Israel B, et al. Religious involvement, social support, and health among African-American women on the east side of Detroit. J Gen Intern Med. 2003;18(7):549-57. [pmid: 12848838]. [pmcid: 1494889].
156 Becker A B, Israel B A, Schulz A J, et al. Predictors of perceived control among African American women in Detroit: exploring empowerment as a multilevel construct. Health Educ Behav. 2002;29(6):699-715. [pmid: 12456130].
157 Israel B A, Farquhar S A, Schulz A J, et al. The relationship between social support, stress, and health among women on Detroit's East Side. Health Educ Behav. 2002;29(3):342-60. [pmid: 12038743].
158 Schulz A J, Israel B A, Parker E A, Lockett M, Hill Y, Wills R. The East Side Village Health Worker Partnership: integrating research with action to reduce health disparities. Public Health Rep. 2001;116(6):548-57. [pmid: 12196614]. [pmcid: 1497386].
159 Parker E A, Lichtenstein R L, Schulz A J, et al. Disentangling measures of individual perceptions of community social dynamics: results of a community survey. Health Educ Behav. 2001;28(4):462-86. [pmid: 11465157].
160 Schulz A, Parker E, Israel D B, et al. Social context, stressors, and disparities in women's health. J Am Med Womens Assoc. 2001;56(4):143-9. [pmid: 11759781].
161 Schulz A, Israel B, Williams D, et al. Social inequalities, stressors and self reported health status among African American and white women in the Detroit metropolitan area. Soc Sci Med. 2000;51(11):1639-53. [pmid: 11072884].
162 Parker E A, Schulz A J, Israel B A, Hollis R. Detroit's East Side Village Health Worker Partnership: community-based lay health advisor intervention in an urban area. Health Educ Behav. 1998;25(1):24-45. [pmid: 9474498].
163 Schulz A J, Israel B A, Becker A B, et al. “It's a 24-hour thing … a living-for-each-other concept”: identity, networks, and community in an urban village health worker project. Health Educ Behav. 1997;24(4):465-80. [pmid: 9247825].
164 Perera F P, Illman S M, Kinney P L, et al. The challenge of preventing environmentally related disease in young children: community-based research in New York City. Environ Health Perspect. 2002;110(2):197-204. [pmid: 11836150]. [pmcid: 1240736].
165 Evans D T, Fullilove M T, Green L, et al. Awareness of environmental risks and protective actions among minority women in Northern Manhattan. Environ Health Perspect. 2002;110(Suppl 2):271-5. [pmid: 11929738]. [pmcid: 1241173].
166 Macaulay A C, Paradis G, Potvin L, et al. The Kahnawake Schools Diabetes Prevention Project: intervention, evaluation, and baseline results of a diabetes primary prevention program with a native community in Canada. Prev Med. 1997;26(6):779-90. [pmid: 9388789].
167 Potvin L, Cargo M, McComber A M, et al. Implementing participatory intervention and research in communities: lessons from the Kahnawake Schools Diabetes Prevention Project in Canada. Soc Sci Med. 2003;56(6):1295-305. [pmid: 12600366].
168 Macaulay A C, Cross E J, Delormier T, Potvin L, Paradis G, McComber A. Developing a Code of Research Ethics for research with a Native community in Canada: a report from the Kahnawake Schools Diabetes Prevention Project. Int J Circumpolar Health. 1998;57(Suppl 1):38-40. [pmid: 10093242].
169 McComber A M, Macaulay A C, Kirby R, et al. The Kahnawake Schools Diabetes Prevention Project: community participation in a diabetes primary prevention research project. Int J Circumpolar Health. 1998;57(Suppl 1):370-4. [pmid: 10093308].
170 Maciak B J, Guzman R, Santiago A, Villalobos G, Israel B A. Establishing LA VIDA: a community-based partnership to prevent intimate violence against Latina women. Health Educ Behav. 1999;26(6):821-40. [pmid: 10608573].
171 Baldwin J H, Rawlings A, Marshall E S, et al. Mom empowerment, too! (ME2): a program for young mothers involved in substance abuse. Public Health Nurs. 1999;16(6):376-83. [pmid: 10620246].
172 Arcury T A, Austin C K, Quandt S A, et al. Enhancing community participation in intervention research: farmworkers and agricultural chemicals in North Carolina. Health Educ Behav. 1999;26(4):563-78. [pmid: 10435238].
173 Quandt S A, Arcury T A, Pell A I. Something for everyone? A community and academic partnership to address farmworker pesticide exposure in North Carolina. Environ Health Perspect. 2001;109(Suppl 3):435-41. [pmid: 11427393]. [pmcid: 1240562].
174 Eng E, Parker E. Measuring community competence in the Mississippi Delta: the interface between program evaluation and empowerment. Health Educ Q. 1994;21(2):199-220. [pmid: 8021148].
175 Maciak B J, Moore M T, Leviton L C, et al. Preventing Halloween arson in an urban setting: a model for multisectoral planning and community participation. Health Educ Behav. 1998;25(2):194-211. [pmid: 9548060].
176 Factor S H, Galea S, de Duenas Geli L G, et al. Development of a “survival” guide for substance users in Harlem, New York City. Health Educ Behav. 2002;29(3):312-25. [pmid: 12038741].
177 Galea S, Factor S H, Palermo A G, Aaron D, Canales E, Vlahov D. Access to resources for substance users in Harlem, New York City: Service provider and client perspectives. Health Educat Behav. 2002;29(3):296-311.
178 Arthur H M, Wright D M, Smith K M. Women and heart disease: the treatment may end but the suffering continues. Can J Nurs Res. 2001;33(3):17-29. [pmid: 11845619].
179 Sloane D C, Diamant A L, Lewis L B, et al. Improving the nutritional resource environment for healthy living through community-based participatory research. J Gen Intern Med. 2003;18(7):568-75. [pmid: 12848840]. [pmcid: 1494887].
180 Reese D J, Ahern R E, Nair S, et al. Hospice access and use by African Americans: addressing cultural and institutional barriers through participatory action research. Soc Work. 1999;44(6):549-59. [pmid: 10568027].
181 McCauley L A, Lasarev M R, Higgins G, et al. Work characteristics and pesticide exposures among migrant agricultural families: a community-based research approach. Environ Health Perspect. 2001;109(5):533-8. [pmid: 11401767].
182 McCauley L A, Beltran M, Phillips J, et al. The Oregon migrant farmworker community: an evolving model for participatory research. Environ Health Perspect. 2001;109(Suppl 3):449-55. [pmid: 11427395].
183 Mergler D, Brabant C, Vezina N, et al. The weaker sex? Men in women's working conditions report similar health symptoms. J Occup Med. 1987;29(5):417-21. [pmid: 3598733].
184 Mergler D. Worker participation in occupational health research: theory and practice. Int J Health Serv. 1987;17(1):151-67. [pmid: 3557770].
185 Lee P T, Krause N. The impact of a worker health study on working conditions. J Public Health Policy. 2002;23(3):268-85. [pmid: 12325285].
186 Flocks J, Clarke L, Albrecht S, et al. Implementing a community-based social marketing project to improve agricultural worker health. Environ Health Perspect. 2001;109(Suppl 3):461-8. [pmid: 11427397]. [pmcid: 1240566].
187 Kieffer E C, Willis S K, Arellano N, et al. Perspectives of pregnant and postpartum latino women on diabetes, physical activity, and health. Health Educ Behav. 2002;29(5):542-56. [pmid: 12238699].
188 Tsark J A. A participatory research approach to address data needs in tobacco use among Native Hawaiians. Asian Am Pacific Island J Health. 2001-2002;9(1):40-8.
189 Minkler M, Thompson M, Bell J, Rose K. Contributions of community involvement to organizational-level empowerment: the federal Healthy Start experience. Health Educ Behav. 2001;28(6):783-807. [pmid: 11720278].
190 Horowitz C R, Williams L, Bickell N A. A community-centered approach to diabetes in East Harlem. J Gen Intern Med. 2003;18(7):542-8. [pmid: 12848837]. [pmcid: 1494885].
191 Minkler M, Fadem P, Perry M, Blum K, Moore L, Rogers J. Ethical dilemmas in participatory action research: a case study from the disability community. Health Educ Behav. 2002;29(1):14-29. [pmid: 11822550].
192 Dickson G, Green K L. Participatory action research: lessons learned with Aboriginal grandmothers. Health Care Women Int. 2001;22(5):471-82. [pmid: 11508099].
193 Dickson G. Aboriginal grandmothers' experience with health promotion and participatory action research. Qualit Health Res. 2000;10(2):188-213.
194 Hiebert W, Swan D. Positively Fit: A Case Study in Community Development and the Role of Participatory Action Research. Comm Develop J. Oct. 1999;34(4):356-64.
195 Eng E, Blanchard L. Action-Oriented Community Diagnosis: A Health Education Tool. Int Q Comm Health Educat. 1991;11(2):93-110.
196 Stajduhar K I, Lindsey E. Home away from home: essential elements in developing housing options for people living with HIV/AIDS. AIDS Patient Care Stds. 1999;13(8):481-91. [pmid: 10800527].
197 Plaut T, Landis S, Trevor J. Enhancing Participatory Research with the Community Oriented Primary Care Model: A Case Study in Community Mobilization. Am Sociol 1992; 56–70.
198 Rains J W, Ray D W. Participatory action research for community health promotion. Pub Health Nurs. 1995;12(4):256-61. [pmid: 7667179].
199 Lauderdale D S, Kuohung V, Chang S L, et al. Identifying older Chinese immigrants at high risk for osteoporosis. J Gen Intern Med. 2003;18(7):508-15. [pmid: 12848833]. [pmcid: 1494886].
200 Ledogar R J, Acosta L G, Penchaszadeh A. Building international public health vision through local community research: the El Puente-CIET partnership. Am J Public Health. 1999;89(12):1795-7. [pmid: 10589305]. [pmcid: 1509016].
201 Ledogar R J, Penchaszadeh A, Garden C C, et al. Asthma and Latino cultures: different prevalence reported among groups sharing the same environment. Am J Public Health. 2000;90(6):929-35. [pmid: 10846511]. [pmcid: 1446273].
202 Corburn J. Combining community-based research and local knowledge to confront asthma and subsistence-fishing hazards in Greenpoint/Williamsburg, Brooklyn, New York. Environ Health Perspect. 2002;110(Suppl 2):241-8. [pmid: 11929734].
203 Adrien A, Godin G, Cappon P, et al. Overview of the Canadian study on the determinants of ethnoculturally specific behaviours related to HIV/AIDS. Can J Public Health. 1996;87(Suppl 1):S4-10. [pmid: 8705923].
204 Willms D, Bhatia R, Lowe J, Niemi F, Stewart D, Westmoreland-Traore J. Five conversations: reflections of stakeholders on the impact of the ethnocultural communities facing AIDS study. Can J Public Health 1996; 87 Suppl 1:S44–8, S49–53.
205 Willms D, Singer SM, Adrien A, et al. Participatory aspects in the qualitative research design of phase II of the ethnocultural communities facing AIDS study. Can J Public Health 1996; 87 Suppl 1:S15–25, S16–27.
206 Singer SM, Willms DG, Adrien A, et al. Many voices--sociocultural results of the ethnocultural communities facing AIDS study in Canada. Can J Public Health 1996; 87 Suppl 1:S26–32, S28–35.
207 Maticka-Tyndale E, Godin G, LeMay G, et al. Canadian ethnocultural communities facing AIDS: overview and summary of survey results from phase III. Can J Public Health 1996; 87 Suppl 1:S38–43, S42–8.
208 Cappon P, Adrien A, Godin G, et al. HIV/AIDS in the context of culture: selection of ethnocultural communities for study in Canada. Can J Public Health 1996; 87 Suppl 1:S11–4, S11–5.
209 Mullings L, Wali A, McLean D, et al. Qualitative methodologies and community participation in examining reproductive experiences: the Harlem Birth Right Project. Matern Child Health J. 2001;5(2):85-93. [pmid: 11573843].
210 Parsons M L, Warner-Robbins C. Formerly incarcerated women create healthy lives through participatory action research. Holist Nurs Pract. 2002;16(2):40-9. [pmid: 11845765].
211 Parsons M L, Warner-Robbins C. Factors that support women's successful transition to the community following jail/prison. Health Care Women Int. 2002;23(1):6-18. [pmid: 11822560].
212 Stratford D, Chamblee S, Ellerbrock T V, et al. Integration of a participatory research strategy into a rural health survey. J Gen Intern Med. 2003;18(7):586-8. [pmid: 12848842]. [pmcid: 1494892].
213 Kinney P L, Aggarwal M, Northridge M E, et al. Airborne concentrations of PM(2.5) and diesel exhaust particles on Harlem sidewalks: a community-based pilot study. Environ Health Perspect. 2000;108(3):213-8. [pmid: 10706526]. [pmcid: 1637978].
214 Northridge M E, Yankura J, Kinney P L, et al. Diesel exhaust exposure among adolescents in Harlem: a community-driven study. Am J Public Health. 1999;89(7):998-1002. [pmid: 10394306]. [pmcid: 1508854].
215 Wing S, Wolf S. Intensive livestock operations, health, and quality of life among eastern North Carolina residents. Environ Health Perspect. 2000;108(3):233-8. [pmid: 10706529]. [pmcid: 1637983].
216 Wing S, Cole D, Grant G. Environmental injustice in North Carolina's hog industry. Environ Health Perspect. 2000;108(3):225-31. [pmid: 10706528].
217 Vander Stoep A, Williams M, Jones R, Green L, Trupin E. Families as full research partners: what's in it for us?. J Behav Health Serv Res. 1999;26(3):329-44. [pmid: 10425870].
218 el-Askari G, Freestone J, Irizarry C, et al. The Healthy Neighborhoods Project: a local health department's role in catalyzing community development. Health Educ Behav. 1998;25(2):146-59. [pmid: 9548057].
219 Yoshihama M, Carr E S. Community Participation Reconsidered: Feminist Participatory Action Research With Hmong Women. J Comm Pract. 2002;10(4):85-103.
220 Choudhry U K, Jandu S, Mahal J, Singh R, Sohi Pabla H, Mutta B. Health promotion and participatory action research with South Asian women. J Nurs Scholarsh. 2002;34(1):75-81. [pmid: 11901971].
221 Green L, Daniel M. Guidelines and Categories for Classifying Participatory Research Projects in Health Promotion [Web Page]. Available at http://lgreen.net/guidelines/html. (Accessed 29 October 2003).
222 Wismer B A, Moskowitz J M, Chen A M, et al. Mammography and clinical breast examination among Korean American women in two California counties. Prev Med. 1998;27(1):144-51. [pmid: 9465365].
223 Israel B A, House J S, Schurman S J, et al. The relation of personal resources, participation, influence, interpersonal relationships and coping strategies to occupational stress, job strains and health: a multivariate analysis. Work Stress. 1989;3(2):163-94.
224 Israel B A, Schurman S J, Hugentobler M K. Conducting Action Research: Relationships Between Organization Members and Researchers. J App Behav Science. 1992;28(1):74-101.
225 Godin G, Maticka-Tyndale E, Adrien A, et al. Understanding use of condoms among Canadian ethnocultural communities: methods and main findings of the survey. Can J Public Health 1996; 87 Suppl 1:S33–7, S36–41.
226 Israel B A, Schulz A J, Parker E A, et al. Community-based Participatory Research: Policy Recommendations for Promoting a Partnership Approach in Health Research. Educ Health. 2001;14(2):182-97.
227 O'Fallon LR , Tyson FL, Dearry A. Successful Models of Community-Based Participatory Research. Final Report of a meeting hosted by the National Institute of Environmental Health Sciences. March 29–31, 2000 - Washington, DC [Web Page]. Available at http://www.niehs.nih.gov/translat/cbr-final.pdf. (Accessed 13 January 2004).
228 Green LW. . Tracing Federal Support for Participatory Research in Public Health. Minkler M, Wallerstein N, eds. Community-Based Participatory Research for Health. San Francisco, CA: Jossey-Bass, 2003. Appendix B
229 Shepard PM, Northridge ME, Prakash S, et al. Preface: Advancing Environmental Justice through Community-Based Participatory Research. Environmental Health Perspectives Supplements 2002; 110(2).
230 Seifer SD, Shore N, Holmes SL. Developing and sustaining community-university partnerships for health research: infrastructure requirements. A report to the NIH Office of Behavioral and Social Sciences Research. 2003.
231 Moher D, Schulz K F, Altman D. The CONSORT Statement: Revised Recommendations for Improving the Quality of Reports of Parallel-Group Randomized Trials. J Am Med Assoc. 2001;285(15):1987-91.
232 Stroup D F, Berlin J A, Morton S C, et al. Meta-analysis of observational studies in epidemmiology: a proposal for reporting. Meta-analysis of Observational Studies in Epidemiology (MOOSE) group. J Am Med Assoc. 2000;283(15):2008-12.
233 Soares H P, Daniels S, Kumar A, et al. Bad reporting does not mean bad methods for randomised trials: observational study of randomised controlled trials performed by the Radiation Therapy Oncology Group. BMJ. 2004;328:22-4. [pmid: 14703540]. [pmcid: 313900].
234 del Giglio A, Costa LJ. The quality of randomised controlled trials may be better than assumed. BMJ 2004; 24–25.
235 O'Toole T P, Aaron K F, Chin M H, et al. Community-based participatory research: opportunities, challenges, and the need for a common language. J Gen Intern Med. 2003;18:592-4. [pmid: 12848844]. [pmcid: 1494882].