# Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 2. Partial funding for the evidence report was provided by the National Cancer Institute, Division of Cancer Control and Population Sciences, and by the National Institutes of Health's Office of Behavioral and Social Sciences Research. We acknowledge the continuing support of Jacqueline Besteman, JD, MA, former director of the AHRQ Evidence-based Practice Center Program; Margaret Coopey, RN, MGA, MPS, the AHRQ Task Order Officer for this project; and Kaytura Felix-Aaron, MD, Senior Advisor, Minority Health.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI and UNC. From UNC, we thank the EPC Co-Director, Timothy S. Carey, MD, MPH; Research Assistant Donna Curasi; and abstractors, Karen Pilliod, MPH; Jill McClain, MA; and Laura Sterling, MD. We also express our gratitude to Debra J. Bost, editor, and Loraine Monroe, EPC word processing specialist, at RTI International.

We also extend our appreciation to the members of our Technical Expert Advisory Group (TEAG), who provided advice and input during our research process. TEAG members were Jack Geiger, MD; Russell Glasgow, PhD; Barbara Sabol, RN; Deborah Jones-Saumty, PhD; Jesus Ramirez-Valles, MPH, PhD; Gwen Bampfield-Wright, JD, MSW; Glenn White, PhD; Alex Allen, MSA; Meredith Minkler, DrPH; Barbara Israel, DrPH; and Monika Suchowierska, MA, BCBA. We would also like to thank those who did not serve in the capacity as TEAG members, but were Expert Meeting participants: Benjamin Fraticelli, MDiv, MPH; Tom Kelly; Elmer Freeman; Linda Randolph, MD, MPH; Victor Rubin, PhD; Jeam Schensul, PhD; JoAnn Umilani Tsark, MPH; Tony Whitehead, PhD; and Jon Kerner, PhD.

We deeply appreciate the insights of our peer reviewers. The TEAG members who served as peer reviewers include Alex Allen, Gwen Bampfield-Wright, Barbara Israel, Deborah Jones-Saumty, Mereidith Minkler, and Jesus Ramirez-Valles. In addition, Ann Beal, MD, Tom Bruce, MD, Paul Estabrooks, PhD, Victor Rubin, PhD, Sarena Seifer, MD, Shobha Srinivasan, Ph.D., JoAnn Umilani Tsark, MPH, and Tony Whitehead, PhD.