# Appendix D Expert Meeting Attendees/Technical Expert Advisory Group Members /Peer Review

## Community-Based Participatory Expert Meeting Attendees

We extend our appreciation to the members of our Community-Based Participatory Expert Meeting attendees who provided us with advice and input at the initiation of our project. Their guidance was invaluable in setting the direction of our review.

Name | Affiliation
Allex Allen, III, MSA | AJA Consulting
| Princeton, NJ
Alice S. Ammerman, DrPH, RD | ^‡^RTI-UNC EPC
| Co-Scientific Director
| Chapel Hill, NC
Gwen Bampfield-Wright, JD, MSW | SC HIV Prevention Community Planning Group and The ACCESS Network
| Ridgeland, SC
Timothy Carey, MD, MPH | RTI-UNC EPC, Co-EPC Director
| Chapel Hill, NC
Susan C. Clark, MPH, CHES | Centers for Disease Control and Prevention Public Health Program Office
| Atlanta, GA
Felicia Collins, MD, MPH | Office of Data, Evaluation, Analysis and Research Health Resources and Services Administration
| Bethesda, MA
Margaret Coopey, RN, MGA, MPS | Agency for Health Research and Quality
| Task Order Officer
| Rockville, MD
Eugenia Eng, MPH, DrPH | RTI-UNC EPC
| Co-Scientific Director
| Chapel Hill, NC
Kaytura Felix-Aaron, MD | Center for Primary Care Research
| Agency for Healthcare Research and Quality
| Rockville, MD
Benjamin Fraticelli, MDiv, MPH | Community Health Academy
| Oakland, CA
Elmer Freeman, PhD, MSW | Center for Community Health Education Research and Services, Inc.
| Boston, MA
Jack Geiger, MD | Professor Emeritus
| School of Medicine
| City University of New York
| New York, NY
Russell Glasgow, PhD | AMC Cancer Center
| Canyon City, CO
Derek Griffith, PhD | RTI-UNC EPC
| Community Health Scholar
| Chapel Hill, NC
Jon Kerner | Division of Cancer Control and Population Sciences
| Bethesda, MD
Barbara Israel, DrPH | Department of Health Behavior and Health Education
| University of Michigan
| Ann Arbor, MI
Deborah Jones-Saumty,PhD | CEO
| American Indian Associates
| Talihina, OK
Siobhan Maty, PhD | RTI-UNC EPC
| Community Health Scholar
| Chapel Hill, NC
Meredith Minkler, DrPH | Public Health Department
| University of California at Berkeley
| Berkeley, CA
Jesus Ramirez-Valles, MPH, PhD | School of Public Health
| University of Illinois-Chicago
| Chicago, IL
Linda Randolph, MD, MPH | DC Developing Families Center
| Washington, DC
Scott Rhodes, PhD | RTI-UNC EPC
| Community Health Scholar
| Chapel Hill, NC
Victor Rubin, PhD | Policy Link
| Oakland, CA
Barbara Sabol, RN | Program Director
| W.K. Kellogg Foundation
| Battle Creek, MI
Jean Schensul, PhD | Institute for Community Research
| Hartford, CT
Sonya Sutton, BSPH | RTI-UNC EPC
| RTI Project Manager
| Research Triangle Park, NC
Monika Suchowierska, MA/BCBA | Department of Developmental and Child Psychology
| University of Kansas
| Lawrence, KS
Virginia Taggert | National Heart, Lung, and Blood Institute
| Bethesda, MD
JoAnn Umilani Tsark, MPH | Papa Ola Lokahi
| Honolulu, HI
Meera Viswanathan, PhD | RTI-UNC EPC
| Project Director
| Research Triangle Park, NC
Nada Vydelinguui | Center to Reduce Cancer Health Disparities
| National Cancer Institute
| Rockville, MD
Lucille H. Webb, Med | RTI-UNC EPC
| Community Lead
| Raleigh, NC
Glenn White, PhD | Associate Professor,
| Human Development and Family Life
| University of Kansas
| Lawrence, KS
Tony L. Whitehead, PhD | Department of Anthropology
| University of Maryland
| College Park, MD

‡ RTI International - University of North Carolina Evidence-based Practice Center

## TEAG Members and Peer Reviewers

### Technical Expert Advisory Group

We also extend our appreciation to the members of our Technical Expert Advisory Group (TEAG), who provided advice and input during our research process. The RTI-UNC EPC team solicited the views of TEAG members from the beginning of the project. TEAG members also provided insights into and reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEAG members participated in refining the analytic framework and key questions and discussing the preliminary assessment of the literature, including inclusion/exclusion criteria, and also provided input on the information and categories, including evidence tables. The TEAG was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. TEAG members are listed below:

Alex Allen, MSA

AJA Consulting

Princeton, NJ

Gwen Bampfield-Wright, JD,MSW

The Access Network

Ridgeland, SC

Jack Geiger, MD

City University of New Work

School of Medicine

New York, NY

Russell Glasgow, PhD

AMC Cancer Center

Canyon City. CO

Barbara Israel, DrPH

University of Michigan

School of Public Health

Ann Arbor, MI

Deborah Jones-Saumty, PhD

CEO, American Indian Association

Talihina, OK

Meredith Minkler, DrPH

University of California at Berkeley

School of Public Health

Berkeley, CA

Jesus Ramirez-Valles, PhD, MPH

University of Illinois at Chicago

School of Public Health

Chicago, IL

Monika Suchowierska, MA/BCBA

University of Kansas

Lawrence, KS

Glenn White, PhD

University of Kansas

Lawrence, KS

### Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to David Atkins, MD, and Kaytura Felix Aaron, MD, from AHRQ for contributing peer review comments. Our peer review panel also includes six members of the TEAG: Alex Allen, Gwen Bampfield-Wright, Barbara Israel, Deborah Jones-Saumty, Mereidith Minkler, and Jesus Ramirez-Valles. Peer review was a separate duty for these individuals and not part of their commitment as TEAG members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Alex Allen, MSA

AJA Consulting

Princeton, NJ

Ann Beal, MD

Commonwealth Fund

New York, NY

Paul Estabrooks, PhD

Kaiser Permanente

Denver, CO

Deborah Jones-Saumty, PhD

CEO, American Indian Association

Talihina, OK

Jesus Ramirez-Valles, PhD, MPH

University of Illinois at Chicago

School of Public Health

Chicago, IL

Sarena Seifer, MD

Community Campus Partnerships for Health

Seattle, WA

JoAnn Umilani Tsark, MPH

Research Director

Papa Ola Lokahi

Honolulu, HI

Gwen Bampfield-Wright, JD,MSW

The Access Network

Ridgeland, SC

Tom Bruce, MD

University of Arkansas

College of Public Health

Little Rock, AR

Barbara Israel, DrPH

University of Michigan

School of Public Health

Ann Arbor, MI

Meredith Minkler, DrPH

University of California at Berkeley

School of Public Health

Berkeley, CA

Victor Rubin, PhD

Policy Link

Oakland, CA

Shobha Srinivasan, Ph.D.

National Institute of Environmental Health Sciences

Research Triangle Park, NC

Tony Whitehead, PhD

University of Maryland

College Park, MD