# Appendix C Evidence Tables

## Evidence Table Notes

Appendix C consists of two evidence tables; the first includes 12 evaluated interventions and the second includes 18 interventions that were either not completed or not evaluated. Entries are sorted by study design and then listed alphabetically by their study names. When articles gave no “official” study names, we used the key focus of the study. Entries in the evidence table may combine information from multiple articles to provide more complete information on a given study. Each study has two separate entries; the first lists research components and the second lists community participation components. A list of abbreviations used in the tables appears at the beginning of the appendix.

Glossary of Abbreviations and Acronyms Used in Evidence Tables

Abbreviation/Acronym | Definition
AHA | American Heart Association
CAB | Community Advisory Board
CAC | Community Advisory Committee
CANAP | Citizen Alert Native American Program
CBO | Community-based organization
CBPR | Community-based participatory research
CDC | Centers for Disease Control and Prevention
CHA | Community Health Advisor
CHR | Community Health Representative
HEPA | High-efficiency particulate arresting
HIV | Human immunodeficiency virus
IPV | Intimate partner violence
KCAB | Korean Community Advisory Board
MI | Myocardial infarction
n | Number
NA | Not applicable
NCFP | North Carolina Farmworkers' Project
NCI | National Cancer Institute
NIEHS | National Institute of Environmental Health Sciences
NR | Not reported
NY | New York
P | Probability
PAR | Participatory action research
RCT | Randomized controlled trial
SES | Socioeconomic status
VHW | Village Health Workers
WBJ | Workbook Journal
YANA | You Are Not Alone

## Evidence Table 1. Evaluated Interventions

Evidence Table 1. Communities Mobilizing for Change on Alcohol: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publication:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Wagenaar AC, Murray DM, Gehan JP, et al.,2000* | To evaluate the effectiveness of a community-based intervention to reduce | Experimental (RCT with pretest and posttest measures) | Community organizers worked with local public officials, agencies, media, and merchants to change community policies toward alcohol through | • High school students (grades 9 and 12) | Multiple variables on | • Socio-demographic factors | Community policies were changed to reduce youth access to alcohol | No
Wagenaar AC, Murray DM, Toomey TL, 2000 | • The availability of alcohol to young people | [underlined: Duration of Study:] | • Community enforcement actions | • Youth, aged 18 to 20 | • Access to alcohol | • Education | Measures for access to alcohol and drinking behaviors generally declined after the intervention, although only 1 measure showed a statistically significant difference to the control group in a multiple regression model (18- to 20-year olds: provided alcohol to youth; P = 0.01) | [underlined: Measures:]
Wagenaar AC, Murray DM, et al., 1994 | • Alcohol consumption for those under 21 | 5 years | • Community institutional policies | • Alcohol retailers | • Drinking behavior | • Characteristics of merchants | The authors report that there are significant overall effects for 18- to 20-year-olds and on-sale alcohol merchants measured in standard deviation units (P = 0.01, respectively P = 0.04) | No
Wagenaar AC, Gehan JP, et al., 1999 | • Injury, morbidity, health and social problems related to alcohol | [underlined: Setting:] | • Community initiated regulations | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | | [underlined: Recruitment:]
Wagenaar AC, Toomey TL, et al., 1996 | | 15 school districts in Minnesota and Wisconsin | • Community information dissemination | Of 24 eligible communities, 15 agreed to participate then matched according to characteristics and randomly assigned to intervention or control groups | Quantitative: | | | No
Wagenaar AC, Perry CL, 1994 | | | [underlined: Duration of Intervention:] | High School Student: | • Baseline and follow-up school surveys after 3 years | | | [underlined: Intervention:]
[underlined: Funder:] | | | 2.5 years | • 100% asked to participate | • Surveys of 18- to 20-year-olds | | | Yes
National Institute on Alcohol Abuse and Alcoholism, Center for Substance Abuse Prevention | | | | Youth: | • Alcohol purchase attempts | | | Core leadership groups were founded to plan and implement the interventions
[underlined: Funding Period:] | | | | • Random selection from state driver's license records | • Alcohol merchant surveys | | | [underlined: Dissemination:]
6 years (1991-1997) | | | | Alcohol purchase attempts on-sale (bars, restaurants): | • Media content analysis | | | Yes
[underlined: Study Name:] | | | | • 60% randomly selected | • Archival data using time series data on car crashes, arrests, etc | | | Strategy teams received data from time series and baseline surveys
The Communities Mobilizing for Change on Alcohol (CMCA) | | | | Alcohol purchase attempts off-sale (liquor stores, convenience stores, grocery stores): | | | | [underlined: Outcomes:]
Wagenaar AC, Murray DM, Gehan JP, et al., 2000* | | | | • 100% | | | | No
Wagenaar AC, Murray DM, Toomey TL, 2000 | | | | Alcohol merchant survey | | | | [underlined: Quality Rating:]
Wagenaar AC, Murray DM, et al., 1994 | | | | • nearly identical to alcohol purchase attempt survey | | | | 2.65
Wagenaar AC, Gehan JP, et al., 1999 | | | | [underlined: Sample Size]
Wagenaar AC, Toomey TL, et al., 1996 | | | | 1992/1995:
Wagenaar AC, PerryCL, 1994 | | | | High School:
| | | | 9th: 5,858
| | | | 12th: 4,506/4,487
| | | | 18- to 20-year-olds:
| | | | 3,095/1,721
| | | | Merchants: 502/556
| | | | Alcohol purchase attempts on-sale:
| | | | 229/251
| | | | Alcohol purchase attempts off-sale:
| | | | 273/305
| | | | [underlined: Response Rate at Each Measure:]
| | | | Baseline/Followup
| | | | High School
| | | | 9th: 92.8%/83.5%
| | | | 12th: 89.3%/NA
| | | | Youth: 92.5%/93.9%
| | | | Merchants:
| | | | 87.6%/91.5%
| | | | [underlined: Retention Rate:]
| | | | 62.8% for 1992 9th graders (this cohort not reported in analysis due to high loss of followup)

* Primary article for this study

Table 1 Evidence Table. Communities Mobilizing for Change on Alcohol: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
[underlined: Publication:] | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Wagenaar AC, Murray DM, Gehan JP, et al., 2000* | 5 years | 141 community residents participated in 7 CMCA strategy teams to provide leadership to the campaign; strategy teams developed work plans focusing on the special needs and preferences of the community | 2,415 residents were involved as a “mass base” to support activities without participating in meetings and activities such as attending campaign events, communicating with public officials, and providing in-kind support | Yes | Plans of action varied across communities depending on the special needs and interests | Members of the strategy teams developed skills in organizing through letter-writing, phone-calling, offering testimony, lobbying, public speaking, creating phone trees, producing mass mailings, presentations, building a data base, working with media, fundraising, conducting research, negotiating | Yes
Wagenaar AC, Murray DM, Toomey TL, 2000 | [underlined: Nature of Community Involvement:] | | | Sociodemographics, alcohol access and use | | | Strategy teams received results; dissemination of alcohol-related information major part of survey; organizers made 333 presentations to 2,048 people and generated 101 newspaper articles
Wagenaar AC, Gehan JP, et al., 1999 | • Recruitment and retention | | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
Wagenaar AC, Toomey TL, et al., 1996 | • Measurement instruments and data collection | | | Yes | | | Yes
Wagenaar AC, Murray DM, et al., 1994 | • Intervention development, implementation | | | Intervention sought to change policies on alcohol access and use | | | Changes in policies, procedures, and practices in the communities via
Wagenaar AC, Perry CL, 1994 | • Interpretation of findings | | | | | | • Alcohol merchants
| • Dissemination of findings | | | | | | • Law enforcement
| • Application of findings to health concern identified | | | | | | • Community events
| [underlined: Quality Rating:] | | | | | | • Hotels
| 2.81 | | | | | | • Media
| | | | | | | • Treatment agencies
| | | | | | | • Religious venues
| | | | | | | • Criminal justice
| | | | | | | [underlined: Sustainability:]
| | | | | | | Yes
| | | | | | | Some strategy teams applied for further funding

Table 1 Evidence Table. East Baltimore Health Promotion Program: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Morisky DA, Levine DM, et al., 1983* | To determine the effectiveness of a 3-staged health education program for hypertensive patients | Experimental (RCT) | • Exit interview to increase understanding of disease and compliance with prescribed regimen | High-risk, urban, mainly African-American, hypertensive patients | • Compliance | • Socioeconomic factors | • Overall mortality was 57.3% less in the combined experimental groups compared to conventional group (P < 0.5) | No
Levine DM, Becker DM, et al., 1992 | | [underlined: Duration of Study:] | • Home visit to encourage a family member to provide support | [underlined: Sampling Strategy:] | • Weight control | • Years of hypertension | • Hypertension-related mortality was 53.2 % less in experimental group (P < 0.01) | [underlined: Measures:]
Levine DM, Green LW, et al., 1979 | | 5 years | • Invitations to small group sessions | Probability: Sequential randomized, assignment at each intervention | • Appointment record | • Comorbidities | • Overall, intervention shows a positive effect on appointment keeping, weight control, and blood pressure | No
Green LW, Levine DM, et al., 1975 | | [underlined: Setting:] | [underlined: Duration of Intervention:] | [underlined: Sample Size:] | • Blood pressure | • Number of hospitalizations | | [underlined: Recruitment:]
[underlined: Funder:] | | 34 census tract areas, East Baltimore | 2 months for each intervention | 400 | • Mortality | | | No
National Heart, Blood, and Lung Institute | | | | [underlined: Response Rate at Each Measure:] | [underlined: Data Collection Methods:] | | | [underlined: Intervention:]
[underlined: Funding Period:] | | | | 80% for followup interview | Quantitative: | | | Patient survey was used to tailor the intervention
NR | | | | [underlined: Retention Rate:] | Blinded review of medical records | | | [underlined: Dissemination:]
[underlined: Study Name:] | | | | 290 (72.5%) | Home interview (followup) | | | No
East Baltimore Health Promotion Program | | | | | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.74

* Primary article for this study

Evidence Table 1. East Baltimore Health Promotion Program: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Morisky DA, Levine DM, et al., 1983* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Levine DM, Becker DM, et al., 1992 | NR | Initially a community advisory board directed efforts; eventually the partnership was enhanced to include churches, neighborhood and local grassroots organizations in a steering committee that coordinated the intervention | The intervention approaches were designed by community members to be sensitive to the culture and the needs of the specific groups in recognition of the fact that the urban African-American population is hard to reach | Yes | Intervention approaches were based on a comprehensive needs assessment and the results of a baseline study | Over time, churches developed a large-scale prevention program (“Heart, Body, and Soul”) | No
Levine DM, Green LW, et al., 1979 | [underlined: Nature of Community Involvement:] | Following a needs assessment, the interests of community leaders were taken into account to select hypertension and smoking as specific health status issues | | Sociodemographics, household composition | Intervention was designed by community members to be sensitive to the culture and the needs of the specific groups | Lay health workers with no previous health training were provided training according to American Heart Association (AHA) guidelines | [underlined: Application of Findings:]
Green LW, Levine DM, et al., 1975 | • Selection of research question | | | [underlined: Addressed]: | | | Yes
| • Recruitment and retention | | | Yes | | | Experience served as a basis for a broader-based community program to control hypertension
| • Measurement instruments and data collection | | | One of the interventions focused on family education and support | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | Yes
| • Interpretation of findings | | | | | | Steering committee developed leadership skills and resources to sustain the program
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 2.81

* Primary article for this study

Evidence Table 1. Health is Gold!: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Lam TK, McPhee SJ, et al., 2003 | To compare the effectiveness of a cervical cancer screening program using a media campaign and lay health workers to a program only using the media campaign | Experimental (RCT) | Lay health worker activities: | Vietnamese-American women | • Awareness and knowledge of cervical cancer and Pap tests | • Exposure to media education | Preliminary findings: | No
[underlined: Funder:] | | [underlined: Duration of Study:] | • 2 90-minute sessions with presentations and discussions at baseline | [underlined: Sampling Strategy:] | • Receipt or intention to receive a Pap test | • Sociodemo-graphic characteristics | • Percentage of women who had a Pap test increased significantly in the intervention group (P < 0.001) | [underlined: Measures:]
CDC | | Ongoing study | • 1 session after 2 months | Nonprobability sample — each lay health worker recruited 20 women from her social networks | [underlined: Data Collection Methods:] | | • Knowledge about cervical cancer and Pap tests increased in both groups | No
[underlined: Funding Period:] | | [underlined: Setting:] | [underlined: Duration of Intervention:] | [underlined: Sample Size:] | Quantitative: Written questionnaires for intervention group, telephone survey for control group | | | [underlined: Recruitment:]
4 years | | Santa Clara County, California | 2 months | 400 | | | | Yes
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | | | | Each lay health worker recruited 20 women from her social network leading to a higher number of recruits, but also possible selection bias
Health is Gold! | | | | 100% | | | | [underlined: Intervention:]
Vietnamese Community | | | | [underlined: Retention Rate:] | | | | Yes
Health Promotion | | | | 100% after the intervention (10 dropped out before the intervention and were replaced) | | | | Media strategy refined based on community feedback; control group received a delayed intervention based on the input of the Coalition
Project | | | | | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.61

Evidence Table 1. Health is Gold!: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Lam TK, McPhee SJ, et al., 2003 | [underlined: Duration:] | Researchers organized a coalition of 7 community-based organizations and 4 health agencies to meet monthly | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| 4 years | The Coalition established a one-member one-vote governance; coalition members formulated and implemented the project and monitored and modified the project as needed; researchers developed content, managed logistics, evaluated outcomes | Participants were offered $30 or gift incentives | Yes | Researchers instituted a delayed intervention for the control group based on coalition input | Lay workers acquired health knowledge, organizational skills, and facilitation experiences | No
| [underlined: Nature of Community Involvement:] | | Interviewers and lay health workers spoke Vietnamese | Sociodemographics, length of residence in the U.S. | Coalition members hosted community forums during the media campaign and used the information to refine existing media strategies and formulate new approaches | Partner agencies developed capacities to conceptualize and organize lay health worker outreach | [underlined: Application of Findings:]
| • Selection of research question | | | [underlined: Addressed:] | | Researchers developed the capacity to organize an effective coalition, develop intervention content, and formulate and implement protocols that meet both community and scientific standards | No
| • Proposal development | | | Yes | | | [underlined: Sustainability of Interventions:]
| • Financial responsibility for grant funds | | | Program offered reduced-cost Vietnamese staffed Pap clinic | | | No, study ongoing
| • Study design
| • Recruitment and retention
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 2.60

Evidence Table 1. Sierra Stanford Partnership: Research Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Angell KL, Kreshka MA, et al., 2003 * | To develop and evaluate a low-cost, community-based workbook journal for improving psychosocial functioning in geographically and economically isolated women with primary breast cancer | Experimental (RCT); pretest and posttest measure | Community-initiated workbook-journal as a support group alternative | Underserved rural women with primary breast cancer, either within 3 months of diagnosis or within 3 months of completing treatment | • Posttraumatic Stress Checklist | • Coping (Mental Adjustment to Cancer Scale) | • No significant differences between groups in primary outcome measures: | No
Koopman C, Angell K, et al., 2001 | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | • Profile of Mood States (mood disturbance) | • Demographic variables | - Posttraumatic Stress Disorder symptoms | [underlined: Measures:]
[underlined: Funder:] | | 6 months | 3 months | Simple random sample | [underlined: Data Collection Methods:] | • Illness variables (stage, treatment) | - Profile of Mood States | No
Community Initiated Research Collaboration award from Breast Cancer Research Program | | [underlined: Setting:] | | [underlined: Sample Size:] | Quantitative: Questionnaires and semi-structured interviews at baseline and follow-up (interviewers blinded at follow-up) | • Social support | • Emotional venting, mental disengagement | [underlined: Recruitment:]
[underlined: Funding Period:] | | 7 rural counties in the Sierra Nevada Foothills, California | | 100 | | | • Women who were treated in rural centers and received the workbook journal showed increased fighting spirit compared to the control group (P = 0.05) | Yes
NR | | | | [underlined: Response Rate at Each Measure:] | | | • 74% of women felt emotionally supported by the workbook journal | Community partners took the lead, designing strategies to reduce women's fears about participating
[underlined: Study Name:] | | | | NA | | | | [underlined: Intervention:]
The Sierra Stanford Partnership | | | | [underlined: Retention Rate:] | | | | Yes
| | | | 98% | | | | Community partners developed intervention
| | | | | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.83

* Primary article for this study

Evidence Table 1. Sierra Stanford Partnership: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Angell KL, Kreshka MA, et al., 2003 | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Koopman C, Angell K, et al., 2001 | Duration not reported | Community partners took lead in developing recruitment procedures and conducting assessment | Community partners took the lead in recruitment, designing strategies to reduce women's fears about participating | Yes | Flexibility with assessments to accommodate women's treatment schedules and provide a sense of control | Community recruiters received training in research design | No
| [underlined: Nature of Community Involvement:] | Local cancer support group was asked for input on the informed consent, which was altered to reduce potential anxieties about research | Several personal contacts with participants before enrollment | [underlined: Addressed:] | | | [underlined: Application of Findings:]
| • Selection of research question | | | No | | | No
| • Recruitment and retention | | | | | | [underlined: Sustainability of Interventions:]
| • Measurement instruments and data collection | | | | | | No
| • Intervention development, implementation
| • Dissemination of findings
| [underlined: Quality Rating:]
| 1.80

Evidence Table 1. HIV Testing and Counseling for Latina Women: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Flaskerud JH, Nyamathi AM, Gwen CU, 1997* | To assess the effectiveness of an HIV intervention program on the knowledge and practices of low-income Latina women | Quasi-experimental | Psychoeducational prior to and 2 weeks after HIV antibody testing: | Low-income Latina women | • Knowledge about HIV | • Self esteem | Participants in the intervention group made significant improvements in HIV knowledge and reported condom use; comparison group did not make significant pretest and posttest improvements in these measures | No
Flaskerud JH, Nyamathi AM, 2000 | | [underlined: Duration of Study:] | • HIV test | [underlined: Sampling Strategy:] | • Sexual risk behavior and practices | • Acculturation | | [underlined: Measures:]
Flaskerud JH, Nyamathi AM, 1996 | | 6 years | • Counseling | Nonprobability: Convenience | [underlined: Data Collection Methods:] | • Sociodemographics | | No
Flaskerud JH, Uman G, Lara R, et al., 1996 | | [underlined: Setting:] | • Free condoms | [underlined: Sample Size:] | Quantitative: Structured interviews | | | [underlined: Recruitment:]
Flaskerud JH, Calvillo ER, 1991 | | Los Angeles | • Skill development in condom use and cleaning needle | 570 (intervention.) | Qualitative: Focus groups prior to program design and after implementation of intervention | | | No
[underlined: Funder:] | | | • Pregnancy counseling | 51 (control) | | | | [underlined: Intervention:]
National Institute of Allergy and infectious Disease | | | • Referral and advocacy | Randomly selected subsample of 200 after 1 year | | | | Intervention was based on focus groups and interviews with health workers
[underlined: Funding Period:] | | | [underlined: Duration of Intervention:] | Focus group prior to program design: 59 | | | | [underlined: Dissemination:]
NR | | | 1 year | Focus groups after program intervention: 51 | | | | No
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Outcomes:]
NR; study on HIV testing and counseling for Latina women | | | | 89% (508) | | | | No
| | | | [underlined: Retention Rate:] | | | | [underlined: Quality Rating:]
| | | | 2 weeks posttest: 98% | | | | 1.78
| | | | 1 year retest of 200 random subsample: 96%

* Primary article for this study

Evidence Table 1. HIV Testing and Counseling for Latina Women: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participating Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Flaskerud JH, Nyamathi AM, Gwen CU, 1997* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Flaskerud JH, Nyamathi AM, 2000 | NR | Focus groups and advisory board meetings helped to frame research questions, evaluate intervention protocols, and interpret studies | Child care and snacks were provided during the interviews; interviewers shared ethnicity and spoke Spanish | Yes | Women's hesitancy to get their blood drawn resulted in the decision to use finger-stick HIV antibody tests | Community health workers received additional training and updates in HIV education | Results of program were published and presented at community conferences and workshops and scientific conferences
Flaskerud JH, Nyamathi AM, 1996 | [underlined: Nature of Community Involvement:] | | Educational materials reflected language and low literacy levels | Limited sociodemographic information was assessed | | A community resource directory was created | [underlined: Application of Findings:]
Flaskerud JH, Uman G, Lara R, et al., 1996 | • Selection of research question | | Participants reimbursed per interview | [underlined: Addressed:] | | | No
Flaskerud JH, Calvillo ER, 1991 | • Financial responsibility for grant funds | | | No | | | [underlined: Sustainability of Interventions:]
| • Study design | | | | | | No
| • Recruitment and retention
| • Measurement instruments and data collection
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 2.15

Evidence Table 1. Internet Access and Empowerment — A Community-Based Health Initiative: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Masi CM, Suarez-Balcazar Y, et al., 2003 | To determine whether access to health information via in-home Internet technology can positively influence empowerment among residents of a low-income urban community | Quasi-experimental | • Internet access via WebTV | Community residents | Answers to a modified Perceived Control Scale, information technology proficiency, aptitude, and acceptance | • Demographic factors | • Internet can positively influence health-related empowerment (6 of 8 items significantly different between intervention and control groups, compared to 1 item at baseline) | Yes
[underlined: Funder:] | | [underlined: Duration of Study:] | • Training | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | • Attitudes toward technology | • Significant improvement of technology aptitude and acceptance in the intervention group | Community residents were involved during the development of the study; advisory board was formed in the community; monthly phone interviews
U.S. Department of Commerce's Technology Opportunities Program; West Suburban Health Care | | NR | • Technical support | Intervention group: From a pool of residents who had previously served as block leaders | Qualitative: Monthly telephone interviews | | • No diffusion of attitudes and skills within the community | [underlined: Measures:]
[underlined: Funding Period:] | | [underlined: Setting:] | • Access to a community-specific health-oriented Web page | Control group: Neighbors of intervention group members identified randomly through geographical stratification and recruited by door-to-door canvassing | Quantitative: Surveys at baseline and after 1 year | | | NR
1999-2001 | | 57-block area, West Side of Chicago | • Placement of public Internet access in 10 community locations | [underlined: Sample Size:] | | | | [underlined: Recruitment:]
[underlined: Study Name:] | | | [underlined: Duration of Intervention:] | Intervention group: 42 | | | | Yes
Internet Access and Empowerment: A Community-Based Health Initiative | | | 1 year | Control group: 93 | | | | Intervention group was recruited from community leaders
| | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention:]
| | | | NA | | | | Yes
| | | | [underlined: Retention Rate:] | | | | Decision to partner with block leaders was made after discussion with the community
| | | | Intervention group: 60% (n = 25) | | | | [underlined: Dissemination:]
| | | | Control group: 38% (n = 35) | | | | NR
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | NR
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 1.83

Evidence Table 1. Internet Access and Empowerment — A Community-Based Health Initiative: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Masi CM, Suarez-Balcazar Y, et al., 2003 | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| 2 years | The decision to partner with block leaders and provide Internet access was made after discussion with the community | | No | Monthly phone interviews were conducted to assess the process | The core research team included staff from West Side Health Authority, a local community-based organization, and 2 community residents who served as research assistants | No
| [underlined: Nature of Community Involvement:] | An advisory board comprising local business owners and community leaders provided advice to the project on a regular basis | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
| • Study design | | | No | | | No
| • Recruitment and retention | | | | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | No
| [underlined: Quality Rating:]
| 2.09

Evidence Table 1. The Korean Breast and Cervical Cancer Screening Intervention Project “Health is Strength”: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objectives:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Wismer BA, Moskowitz JM, et al., 2001* | To investigate if a community intervention can improve the rate of breast and cervical cancer screening among Korean-American women in Alameda County, CA | Quasi-experimental | Community intervention through Korean-American lay health advisors primarily at Korean churches; educational materials and workshops in Korean about breast and cervical cancer screening; written material was also mailed to baseline survey participants | Korean-Americans aged 18 and older | 4 self-reported variables concerning adherence to breast and cervical cancer screening; in 1997, also assessment of exposure to intervention | • Sociodemon graphic factors | • No Significant differences in changes in screening between the intervention and control groups | Yes
Wismer BA, Moskowitz JM, et al., 1998 ^a^ | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | • Immigration | • No significant overall improvement in screening attributable to the intervention could be shown in the intervention group | Participation of Korean Community Advisory Board (KCAB) and Korean-speaking interviewers
Wismer BA, Moskowitz JM, et al., 1998 ^b^ | | 10 years | 5 years | Randomly selected phone numbers based on a Korean surname telephone list | Quantitative: Preintervention and postintervention cross-sectional telephone surveys | • Access to health care | • Stratification in subgroups did not reveal different results | [underlined: Measures:]
Chen AM, Wismer BA, et al., 1997 | | [underlined: Setting:] | | [underlined: Sample Size:] | | • Sources of health information | • Women with one or more intervention exposures tended to have significantly more Pap smears (P = 0.05) and mammograms (P = 0.041) than women with no exposure | Yes
[underlined: Funder:] | | Alameda (intervention) and Santa Clara (control) Counties, CA | | 1994: 10,087 | | • Prevalence of morbidity and screening behaviors | | Immigrant-specific SES data were assessed
CDC | | | | 1997: 9,929 | | | | [underlined: Recruitment:]
Avon Breast Health | | | | (12%–13% eligible) | | | | Yes
Access Fund | | | | [underlined: Response Rate at Each Measure:] | | | | Korean-speaking telephone interviewers
[underlined: Funding Period:] | | | | 1994: n = 818 | | | | [underlined: Intervention:]
10 years (exact period dates unclear) | | | | 1997: n = 724 | | | | Yes
[underlined: Study Name:] | | | | (n = 76%–80%) | | | | Due to CBPR- requirements, only reduced staff was available at the time of the intervention; authors conclude that the intervention was therefore not fully implemented (only 40% measurable exposure)
The Korean Breast and Cervical Cancer Screening Intervention Project, “Health is Strength” | | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination:]
| | | | NR | | | | Yes
| | | | | | | | KCAB members presented data at a Korean press conference
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | Yes
| | | | | | | | KCAB helped interpret data
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.43

* Primary article for this study

Evidence Table 1. The Korean Breast and Cervical Cancer Screening Intervention Project “Health is Strength”: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Wismer BA, Moskowitz JM, et al., 2001* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Wismer BA, Moskowitz JM, et al., 1998 | 10 years | The Korean Community Advisory Board (KCAB) helped to develop and implement the program to ensure cultural appropriateness | KCAB involvement throughout all stages of the project | Yes | Final question to invite respondents to Asian Health Services was added to survey | New study to assess the needs of elderly Korean-Americans was initiated by KCAB | Yes
Wismer BA, Moskowitz JM, et al., 1998 | [underlined: Nature of Community Involvement:] | | Telephone interviewers were bilingual Korean-Americans | Socioeconomic factors assessed in the survey | Intervention and survey questions were modified after first survey results | Korean staff and KCAB became conversant with survey methodology and analysis | KCAB members presented data at a Korean press conference
Chen AM, Wismer BA, et al., 1997 | • Selection of research question | | Relationship building with Korean American ministers began 2 years prior to the intervention | [underlined: Addressed:] | University staff wanted a control county with greater geographical separation but compromised with KCAB's desire for familiarity, potential for relationship building and postintervention dissemination | University researchers learned about Korean culture | [underlined: Application of Findings:]
| • Study design | | KCAB members provided ready access to Korean media to promote the survey | Not stated; mammogram facility negotiations mentioned | | | No
| • Recruitment and retention | | | | | | Sustainability of interventions
| • Measurement instruments and data collection | | | | | | Closer contact of community to Asian Health Services
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 2.72

* Primary article for this study

Evidence Table 1. Okanagan Diabetes Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Daniel M, Green LW, et al., 1999 | Address the effectiveness of the community-directed initiative in achieving | Quasi-experimental design with nonequivalent control groups and pretest and posttest measures | A wide variety of activities and education measures based on community assessment of need, aimed at | • Preintervention interviewees | Biological measures: | See Column 6 for all variables measured | Cohort: Statistically significant differences between changes in the intervention and comparison condition in the desired direction were found for BMI and systolic BP; changes in the opposite direction were found for glycosylated hemoglobin and sweat-producing activity ≥ 1/week. | Used preintervention interviews and meetings to identify community needs as well as challenges and barriers to the project
[underlined: Funder:] | • Risk reduction or improved control among “high-risk” individuals w/ or at familial risk for diabetes | [underlined: Duration of Study:] | • Primary prevention | • High-risk cohorts | • Blood pressure | | Cross-section: Changes were seen in sweat-producing activity ≥ 1/week and number of events of sweat-producing activity/week; a change was also seen in actual knowledge of diabetes, due to a decrease in knowledge in the comparison condition | [underlined: Measures:]
Health Canada (National Health Research and Development Program grant) | • Greater coping among individuals with diabetes and impaired glucose tolerance | 24 months | • Screening and secondary prevention | • Cross-sections of populations | Behavioral and social measures: | | The authors concluded that no effect was observed, as these changes were so few compared to the number of variables measured; changes were observed in the community systems, but the authors were careful to point out that such observations were highly subjective | Measures included surveys of community systems at 3 levels: subsystem changes within community groups, changes in relationships among subsystems, and intermediate steps in the social change process
[underlined: Funding Period:] | • Community-wide diabetes risk reduction | [underlined: Setting:] | Activities included | • Community-level research personnel who were residents in the intervention community | • Changes in community systems | | | [underlined: Recruitment:]
April 1994 to May 1996 | • Social environmental change | Three matched Indian Band communities in the Okanagan region of British Columbia, Canada | • Exercise classes/groups | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | | Participants recruited through face-to-face contact with community workers
[underlined: Study Name:] | | | • Health events | • Cohort: Identified through Medical Services Branch Records and recruited through meetings with community workers | Cohort: Measurements were taken in person; survey questions were self-completed except for low literacy (5% — mostly elderly) participants, who were surveyed orally | | | [underlined: Intervention:]
Okanagan Diabetes Project | | | • Cooking demonstrations | • Cross-sectional: Simple random sampling of Band membership lists | Cross-sectional: Survey instrument by telephone interview or home visit (if not telephone) | | | Intervention efforts were developed with the involvement of the intervention community
| | | • Stop smoking group | • Surveys of community systems: Surveyed at meetings w/ researchers | Community surveys: Standardized questions posed to community-level research personnel during meetings | | | [underlined: Dissemination:]
| | | • Supermarket/restaurant tours | [underlined: Sample Size:] | | | | No
| | | • Educational media campaigns | • Preintervention interviewees: n = 59 | | | | [underlined: Outcomes:]
| | | • Some environmental support via the Band Council of the Intervention Indian Band | • High-risk cohorts: n = 105 | | | | No (no intervention effect was observed)
| | | [underlined: Duration of Intervention:] | • Cross-sections: n = 295
| | | 16 months | • Community systems: NA
| | | | [underlined: Response Rate at Each Measure:]
| | | | • Preintervention interviewees: NA
| | | | • High-risk cohorts, intervention condition: 93.6, 71.3, 81.9
| | | | • Comparison condition: 84.1, 55.8, 63.7
| | | | • Cross-section: average = 80.1%
| | | | • System surveys: NA
| | | | [underlined: Retention Rate:]
| | | | Cohorts: 105/207 = 50.7%
| | | | Cross-section: NA, as same people not interviewed for second survey

Evidence Table 1. Okanagan Diabetes Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Daniel M, Green LW, et al, 1999 | [underlined: Duration:] | No | No | [underlined: Assessed:] | No | Yes | [underlined: Dissemination of Findings:]
| NR | | Paper states that previous studies may not have achieved results because of insensitivity to Aboriginal culture, and that this study therefore involves community in the planning and intervention process, but the authors do not detail specific barriers or how they were addressed | Yes | | A coalition evolved from project workers, who made local, regional, and national presentations on the project; the Band Council hired a recreation coordinator | Yes
| [underlined: Nature of Community Involvement:] | | | Literacy and education were assessed, though no report of income assessment | | | Public meetings held after each round of data collection; comparison communities told that results would be made available to them and that they would be given an opportunity to develop prevention programs on completion of the project
| • Study design | | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
| • Recruitment and retention | | | No | | | No
| • Measurement instruments and data collection | | | | | | [underlined: Sustainability:]
| • Intervention development, implementation | | | | | | No

Evidence Table 1. Wai'anae Cancer Research Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Question:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Gotay CC, Banner RO, et al., 2000* | To develop and test the effectiveness of a culturally appropriate intervention in increasing breast and cervical cancer screening practices among Native Hawaiian women | Quasi-experimental (pretest and posttest) | Kokua Group, lay health educator-led group discussions to provide support and education for breast and cervical cancer screening | English-speaking Native Hawaiian women ≥ 18 years old | • Changes in 4 screening behaviors for cervical and breast cancer | • Sociodemo-graphic factors | Increased compliance with screening guidelines (P < 0.05), evening cancer screening clinic for Kokua group members, cancer support group, improved research capabilities | Survey administered by local interviewers; administration protocols adapted for cultural appropriateness
Matsunaga DS, Enos R, et al., 1996 | | [underlined: Duration of Study:] | Vouchers for free mammograms and Pap tests provided to patient and friend | [underlined: Sampling Strategy:] | • Support for screening | • Kokua awareness | | [underlined: Measures:]
Banner RO, DeCambra H, et al., 1995 | | 3 years | | Simple random sample (empanelled) | [underlined: Data Collection Methods:] | • Kokua attendance | | Cultural adaptation of survey content
[underlined: Funder:] | | [underlined: Setting:] | | Random digit dialing in study communities; random selection from within eligible households | Quantitative: Telephone survey | • Knowledge | | [underlined: Recruitment:]
NCI | | Oahu, Hawaii neighborhood | | [underlined: Sample Size:] | Qualitative: Focus groups | • Attitudes/ belief | | Trained telephone interviewers to be culturally sensitive
[underlined: Funding Period:] | | | | 678 (intervention: n = 318; control: n = 360) | | | | [underlined: Intervention:]
1990-1994 | | | | [underlined: Response Rate at Each Measure:] | | | | Community members led groups, participated in recruitment; minimal intervention group created (by post-interview mailing)
[underlined: Study Name:] | | | | 54% of total sample at baseline (678/1260); intervention group = 318/1,260 (25%); control group = 360/1,260 (29%) | | | | [underlined: Dissemination:]
Wai'anae Cancer | | | | [underlined: Retention Rate:] | | | | Mailing “minimal intervention” for participants to be “first to know”; developed protocols shared with other professionals, researchers, etc.
Research Project | | | | 54% of total sample at baseline (678/1,260) | | | | [underlined: Outcomes:]
| | | | | | | | Economic benefits; improvements in health services and systems
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.39

* Primary article for this study

Evidence Table 1. Wai'anae Cancer Research Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Gotay CC, Banner RO, et al., 2000* | [underlined: Duration:] | [underlined: Structure/Mechanism]: | Yes | Yes | Yes | Yes | [underlined: Dissemination of Findings:]
Matsunaga DS, Enos R, et al., 1996 | 7 years | • Community Involvement Committee of Board of Directors | Survey incorporated appropriate language and familiar names, organizations and concepts | Sociodemographic factors measured | During survey administration (protocols and content) and dissemination of survey findings | [underlined: Individual]: | Principles and guidelines and project products to other communities, professionals and researcher; dissemination of findings to participants regarding cancer screening rates
Banner RO, DeCambra H, et al., 1995 | [underlined: Nature of Community Involvement:] | • Cancer Research Planning Committee | Survey employed Native Hawaiian speakers | Vouchers provided to address financial barriers | Several approaches used to facilitate participation by community advisory committee (in light of busy schedules and other responsibilities) | Interviewing skill | [underlined: Application of Findings:]
| • Selection of research question | • Task group to plan survey content and review drafts | | | | Experience in the research planning, implementation | Process (e.g., peer education, participatory approach) applied to training of students and health services/system design
| • Proposal development | • Planning committee — selection of local health center to administer grant | | | | [underlined: Community]: | [underlined: Sustainability of Findings:]
| • Financial responsibility for grant funds | • Community Research Committee — proposal development group; worked for 2 years | | | | Partnership building | Health services (women's clinic and cancer support group) developed during research project were sustained with local funding 3 years after project's end
| • Study design | • Community Advisory Committee: Community volunteers with involvement over 7 years | | | | Organization and participation on research planning committees/groups
| • Recruitment and retention | • Steering Committee — policymaking group including 2 community representatives | | | | Improvements in knowledge, skills, and resources: economic benefit to community health center; jobs/job training for local residents; new health services at the health center; securing additional local funds for program support after project ended; enhanced capacity for peer education; improved research capabilities; participation in publication of research findings
| • Measurement instruments and data collection
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 3.00

* Primary article for this study

Evidence Table 1. NY Immunizations: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Rosenberg Z, Findley S, et al., 1995 | To test the effectiveness of alternative community-based strategies to increase the immunization record among children | One group pretest and posttest design | Various outreach strategies to identify and enroll under-immunized children | Families with under-immunized children | • Enrollment of “hard to reach” children | • Ethnicity | Coverage rates for the basic antigens increased from 24% to 73% within recruited cohort | No
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | • Immunization status | • Residence | | [underlined: Measures:]
NY State Department of Health | | NR | 9 months | Nonprobability sample from a selected group of effective community-based organizations (CBOs) | • Effectiveness at recruitment | • Health insurance | | No
NY State Department of Social Services | | [underlined: Setting:] | | [underlined: Sample Size:] | • Effectiveness of primary care referrals | • CBO characteristics | | [underlined: Recruitment:]
[underlined: Funding Period:] | | New York City neighborhoods with high measles incidence (1981-1991) | | 3,928 (children under age 5 who were not up to date with immunization records after contacting 7,516 families) | • Effectiveness at tracking and retaining children | | | Selection bias likely: only most effective CBOs were selected to participate
NR | | | | [underlined: Response Rate at Each Measure:] | [underlined: Data Collection Methods:] | | | [underlined: Intervention:]
[underlined: Study Name:] | | | | 2,676 (79.9%) (children who were enrolled in the program) | Followup of participants mainly using phone calls | | | Yes CBOs were responsible for designing intervention
New York State Immunization and Primary Health Care Initiative | | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination:]
| | | | NR | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 1.52

Evidence Table 1. NY Immunizations: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Rosenberg Z, Findley S, et al., 1995 | [underlined: Duration:] | CBOs decided how to allocate their funds based on their outreach strategies | No | [underlined: Assessed:] | No | Yes | [underlined: Dissemination of Findings:]
| 9 months | | | Yes | | University staff trained CBOs in data collection, review of immunization records | No
| [underlined: Nature of Community Involvement:] | | | Sociodemographics, Medicaid status, immigrant status | | | [underlined: Application of Findings:]
| • Financial responsibility for grant funds | | | [underlined: Addressed:] | | | No
| • Recruitment and retention | | | Yes | | | [underlined: Sustainability of Interventions:]
| • Measurement instruments and data collection | | | Providers were eligible to receive free vaccinations for children referred through the program | | | No
| • Intervention development, implementation
| [underlined: Quality Rating:]
| 2.19

Evidence Table 1. Stress and Wellness Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Heaney CA, Israel BA, et al., 1993* | Objective 1: To increase the understanding of the relationship between occupational stress, psychosocial factors, job satisfaction, and mental and physical health | Objective 1: Observational | • Daily newsletter | Employees of a car components manufacturing plant | Surveys: stressors, health variables, and psychosocial mediating factors | • Labor management relations | Objective 1, survey results: | No
Schurman SJ, 1996 | Objective 2: To determine if a PAR project is more effective in a cooperative labor management setting at addressing factors in the stress process | Objective 2: Natural quasi-experimental with data collected before and after plant split into two | • Health awareness and screening programs | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | • Social support | Researchers and committee members identified 4 major problem areas as a result of the findings: | [underlined: Measures:]
Baker EA, Israel BA, et al., 1994 | | [underlined: Duration of Study:] | • Information display cases | Nonprobability | Quantitative: | • Participation in decision-making | • Lack of information | Yes
Israel BA, Schurman SJ, et al., 1992 | | 6 years | • Feedback and recommendations to people on sources of stress | [underlined: Sample Size:] | • 3 surveys in 1986, 1987, 1991 | | • Problems with supervisors | Wellness Committee identified stressors and other factors for which measures were created
Hugentobler MK, Israel BA, et al., 1992 | | [underlined: Setting:] | • Pilot project on quality improvement | Focus Group: NR | Qualitative | | • Lack of participation and influence on decisionmakers | [underlined: Recruitment:]
Israel BA, Schurman SJ, et al., 1989 | | South-central Michigan | • Appropriation of time on the job for leaders of existing employee participation programs to follow through on identified problems | In-depth interviews: 42 | • In depth Interviews | | • Conflict between producing quantity versus quality of product | Yes
Israel BA, House JS, et al., 1989 | | | • Modification of performance appraisal system for salaried workers | Surveys: 1,100 | • Focus groups | | Interventions addressing lack of information: | Committee involvement led to a much higher survey response rate than in previous surveys
[underlined: Funder:] | | | [underlined: Duration of Intervention:] | [underlined: Response Rate at Each Measure:] | • Field notes of committee meetings | | • Daily newsletter | [underlined: Intervention:]
National Institute for Alcohol Abuse and Alcoholism, joint union-management funds (United Autoworkers/General Motors) | | | NR | Surveys: | | | • Rumor mill (meetings with management) | Yes
[underlined: Funding Period:] | | | | 66% (1985) | | | Interventions addressing lack of participation and influence and conflict between quality and quantity: | Results of surveys were used by the committee to develop intervention strategies
NR | | | | 41% (1987) | | | • Pilot study on quality implementation and elimination of waste | [underlined: Dissemination:]
[underlined: Study Name:] | | | | 62% (1991) | | | Objective 2: Overall, social environment at work and employee well-being did not improve during the course of the study | Committee revised drafts of articles, e.g., the term “worker” was changed to “employee”
NR, focus on occupational stress | | | | [underlined: Retention Rate:] | | | Involvement in PAR stress project was associated with enhanced participation in decisionmaking in both settings, with improved climate for participation in the cooperative setting, increased coworker support, and decreased symptoms for depression in the adversarial setting | Committee disseminated results to plant members
| | | | NR | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 2.26

* Primary article for this study

Evidence Table 1. Stress and Wellness Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Heaney CA, Israel BA, et al., 1993* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Committee was larger than the researchers wanted, but the researchers agreed, resulting in a more representative and longer-lived group | Yes | [underlined: Dissemination of Findings:]
Schurman SJ, 1996 | 6 years | A Stress and Wellness Committee comprising union, management, and the university team guided the project on data collection, analysis, and intervention design, implementation, and evaluation | Committee members suggested scheduling interview sessions during working hours to raise participation even though this involved shutting down production; committee members met with upper management and obtained approval for this plan | Yes | Researchers gave a presentation to management leaders and union officials on request of the committee | Committee members began to collect their own data to understand how to revise the weekly newsletter with information necessary for employees to do their jobs | Yes
Baker EA, Israel BA, et al., 1994 | [underlined: Nature of Community Involvement:] | Committee and researchers cooperated in developing intervention strategies based on the outcomes of the surveys | Committee involvement led to a much higher survey response rate than previous surveys | Survey assessed psychosocial factors, work-related health stressors | Committee members wanted to hold a health promotion program despite researchers' reservations, then, the researchers suggested followup strategies that would strengthen the intervention | Committee obtained a $40,000 grant to carry out a health screening project | Researchers provided a written report to the committee and organized a 2-day meeting to analyze the findings
Israel BA, Schurman SJ, et al., 1992 | • Selection of research question | | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
Hugentobler MK, Israel BA, et al., 1992 | • Funding (researchers obtained initial funding, subsequent funding provided by joint management and union funds) | | | Yes | | | Yes
Israel BA, Schurman SJ, et al., 1989 | • Study design | | | Interventions addressed work-related stressors | | | Management worked with the committee to incorporate ideas and goals into the overall strategic management of the factory
Israel BA, House JS, et al., 1989 | • Recruitment and retention | | | | | | [underlined: Sustainability of Interventions:]
| • Measurement instruments and data collection | | | | | | No
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified
| [underlined: Quality Rating:]
| 2.90

Evidence Table 1. Women Dedicated to Demolishing Denial: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR, Quality Rating for Research Elements (Range 1–3)
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Stevens PE, Hall JM, 1998* | • To identify risk behaviors | Nonexperimental | • Individually tailored education based on interview contents | Lesbians and bisexual women socializing in women's bars, dance clubs, sex clubs, or gay/lesbian community events | No predefined variables specified | No predefined variables specified | Anecdotal evidence on the effect of the intervention; 20% of 626 women interviewed said that they had changed their behavior (using safer sex and HIV risk reduction behaviors); several of these women said that these changes were a result of Lyon Martins peer educators in clubs | No
Stevens PE, 1994 | • To explore strategies to prevent HIV | [underlined: Duration of Study:] | • Safer sex kits | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | [underlined: Results of Analysis:] | [underlined: Measures:]
[underlined: Funder:] | • To understand difficulties in reducing HIV | NR | • Presentations at clubs and bars | Nonprobability: convenience sample | Qualitative: | | Key findings describe the HIV risk taking common in this population and their needs for support in reducing risk | No
American Foundation for AIDS Research Targeted Education | • To provide specific education | [underlined: Setting:] | [underlined: Duration of Intervention:] | [underlined: Sample Size:] | Field interviews | | | [underlined: Recruitment:]
[underlined: Funding Period:] | | San Francisco | NR | 1,189 interviews (number of respondents likely to be fewer; duplicate interviews) | Content analysis | | | Yes
2 years (6/1992 to 6/1994) | | | | [underlined: Response Rate at Each Measure:] | | | | Peer educators had to be lesbian or bisexual to reflect the study's intended population
[underlined: Study Name:] | | | | NR | | | | [underlined: Intervention:]
Women Dedicated to Demolishing Denial: HIV Risk Reduction for Lesbians and Bisexual Women | | | | [underlined: Retention Rate:] | | | | No
| | | | NA | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No
| | | | | | | | [underlined: Quality Rating:]
| | | | | | | | 1.52

* Primary article for this study

Evidence Table 1. Women Dedicated to Demolishing Denial: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement, Quality Rating for Participatory Elements (Range 1–3) | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Stevens PE, Hall JM, 1998* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | No | Yes | [underlined: Dissemination of Findings:]
Stevens PE, 1994 | 2 years | Project was sponsored by Lyon-Martin women's health services, a primary health care clinic emphasizing health care for lesbian and bisexual women | Educators had to be lesbian or bisexual | Yes | | Educators learned how to conduct interviews and gained social prestige within the community through their involvement | No
| [underlined: Nature of Community Involvement:] | Lyon-Martin hired peer educators and the project coordinator | No direct questions about sexual identity were asked in the interviews to ensure that women freely discussed behaviors and perceptions | Minimal sociodemographics on age and race; no identifying information was collected | | | [underlined: Application of Findings:]
| • Selection of research question | | | [underlined: Addressed:] | | | No
| • Financial responsibility for grant funds | | | No | | | [underlined: Sustainability of Interventions:]
| • Recruitment and retention | | | | | | No
| • Measurement instruments and data collection
| • Intervention development, implementation
| • Interpretation of findings
| [underlined: Quality Rating:]
| 2.19

* Primary article for this study

## Evidence Table 2. Interventions Either Not Completed or Not Evaluated

Evidence Table 2. Community Action Against Asthma: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Identified:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Keeler GJ, Dvonch TJ, et al., 2002* | Study Objective: To gain an increased understanding of and to address the environmental and psychosocial triggers for asthma in children's homes and neighborhoods | Intended study design: Experimental | Community Environmental Specialists provided education and materials that relate to the reduction of asthma-triggers during home visits (minimum 12 visits) | Intervention: Families of children 7 to 11 years old with moderate to severe asthma | • Health outcomes | Environmental and meteorological data | NR (analysis ongoing) | No
Parker EA, Israel BA, et al., 2003 | A process evaluation of the community-based partnership elements of the study was also conducted | Baseline data: Observational | [underlined: Duration of Intervention:] | Process evaluation: Steering Committee members | • Psychosocial factors | | [underlined: Results of Process Evaluation:] | [underlined: Measures:]
Clark NM, Brown RW, et al., 1999 | | Process evaluation: Non-experimental | 2 years | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | Steering Committee members identified partnership accomplishments and challenges | No
[underlined: Funder:] | | [underlined: Duration of Study:] | | Intervention: Probability sample, staggered randomization | Intervention: Quantitative. | | | [underlined: Recruitment:]
National Institute of Environmental Health Sciences | | NR | | Process evaluation: NR | • Self-administered screening questionnaire | | | Yes
US Environment Protection Agency | | [underlined: Setting:] | | [underlined: Sample Size:] | • Microenviron-mental measurements in schools and homes | | | Steering Committee actively participated in hiring and training outreach workers who performed measurements
[underlined: Funding Period:] | | East side and southwest portion of Detroit | | Screening questionnaire: 3,067 valid questionnaires returned; 331 agree to participate and are randomized into the study | • Pulmonary function tests | | | [underlined: Intervention:]
5 years | | | | Indoor measurements: 20 | • Daily diary of symptoms and medications used | | | NA
[underlined: Study Name:] | | | | Process evaluation: 22 out of 25 Steering Committee members | • Annual household environmental assessment | | | [underlined: Dissemination:]
Community Action Against Asthma | | | | [underlined: Response Rate at Each Measure:] | • Annual questionnaire for caregivers and children | | | No
| | | | NR | Process evaluation: Qualitative, in-depth interviews | | | [underlined: Outcomes:]
| | | | [underlined: Retention Rate:] | | | | No
| | | | NR

* Primary article for this study

Evidence Table 2. Community Action Against Asthma: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Keeler GJ, Dvonch TJ, et al., 2002* | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | Since the Steering Committee met only once monthly, community partners felt shut out of decisions that were made in-between monthly meetings; the research team instituted a process to handle such situations | Yes | [underlined: Dissemination of Findings:]
Parker EA, Israel BA, et al., 2003 | NR | Steering Committee comprising 13 community-based partner representatives out of 25 members guided the project | | Yes | | Community-based organizations: | Yes
Clark NM, Brown RW, et al., 1999 | [underlined: Nature of Community Involvement:] | | | Sociodemographics and psychosocial factors | | • Credibility to community-based organizations' projects | Findings were disseminated to the community and at conferences
| • Selection of research question | | | [underlined: Addressed:] | | • Increased understanding of asthma | [underlined: Application of Findings:]
| • Proposal development | | | No | | • Ability to disseminate information to the community | No
| • Study design | | | | | • Researchers: | [underlined: Sustainability of Interventions:]
| • Recruitment and retention | | | | | • Participation in the research | No
| • Measurement instruments and data collection | | | | | • Funding
| • Intervention development, implementation | | | | | • Publicity and recognition
| • Interpretation of findings | | | | | • Opportunities for interdisciplinary learning
| • Dissemination of findings | | | | | • Career advancement

* Primary article for this study

Evidence Table 2. PRAISE!: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Ammerman A, Washington C, et al., 2002 | Research objective of PRAISE!: | Experimental (RCT) | • 3 workshops on dietary cancer prevention | African American church members | Perception of trust in the research project, benefit from involvement, satisfaction with the project, perception of burden associated with participation (also dietary outcome measures and biochemical measures) | • Health | • Overall high levels of trust, perceived benefit, and satisfaction; low levels of perceived burden in both groups | Yes
Corbie-Smith G, Ammerman A, et al., 2003 | • To develop and test a culturally sensitive intervention for dietary change among African Americans | Exploratory (for qualitative data) | • Communication center | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | • Psychosocial factors | • Participants in the intervention group reported more perceived benefit and trust (P < 0.05) | Community members were hired as staff and involved with decisions about survey design and implementation
[underlined: Funder:] | Objective of these articles: | [underlined: Duration of Study:] | • Quarterly packets | Participating churches (n = 60) were allocated randomly to intervention or control groups; the individuals in the “measurement groups” were volunteers and not randomly selected | Quantitative: 2 phone interviews at baseline | • Demographics | • Members of smaller churches were associated with higher perceived benefit (P < 0.01) | [underlined: Measures:]
National Institute of Health; Robert Wood Johnson Minority Medical Faculty Development Program; National Cancer Institute | • To examine community member's perceptions of trust, benefit, satisfaction, and burden associated with their participation | 5 years (data for this article were collected after 1 year) | • Tailored health bulletin | [underlined: Sample Size:] | 2 followup phone surveys of the same participants after 1 year, administered by blinded interviewers | • Church related questions | Articles do not report results of RCT and the effectiveness of the intervention | Yes
[underlined: Funding Period:] | • To collect qualitative data to ensure culturally appropriate intervention design | [underlined: Setting:] | • Food festival | 1,309 | [underlined: Qualitative:] | | | Involvement of community members
1996-2001 | | 60 African American churches in 8 North Carolina counties | • Food events | Intervention: n = 624 | Focus groups with church members and pastors | | | [underlined: Recruitment:]
[underlined: Study Name:] | | | • Inspirational booklet | Control: n = 685 | | | | Yes
Partnership to Reach African Americans to Increase Smart Eating (PRAISE!) | | | • Skills assessment of the congregation | [underlined: Response Rate at Each Measure:] | | | | Based on advice from church consultants, participants were not selected randomly but were volunteers
| | | [underlined: Duration of Intervention:] | Intervention: 63.9% (n = 399) | | | | [underlined: Intervention:]
| | | 12 months | Control: 70.7% (n = 484) | | | | Yes
| | | | [underlined: Retention Rate:] | | | | Study team relied on input from members of the church
| | | | NA | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No

Evidence Table 2. PRAISE!: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Ammerman A, Washington C, et al., 2002 | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Corbie-Smith G, Ammerman A, et al., 2003 | 5 years | Design included a delayed intervention control group responding to concerns that the control group would not get the intervention | All members of PRAISE! staff who interacted with the churches were African American or pastor's wives | Yes | Survey administration was timed around church events and holidays following guidance from community partners | Training focused on providing skill-building and educational resources to church members | No
| [underlined: Nature of Community Involvement:] | | | Baseline interview assessed socioeconomic variables | | A strong sense of local ownership of the program was developed; many churches have indicated interest in sharing the program with other nearby churches | [underlined: Application of Findings:]
| • Study design | | | [underlined: Addressed:] | | | No
| • Recruitment and retention | | | No | | | [underlined: Sustainability of Interventions:]
| • Measurement instruments and data collection | | | | | | No
| • Intervention development, implementation

Evidence Table 2. Seattle King County Healthy Homes Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Krieger JW, Song L, et al., 2000 | To evaluate whether outreach, education, and simple tools can reduce indoor asthma triggers and asthma morbidity; this article reports preliminary baseline findings | Experimental (RCT) | Outreach workers conduct home assessments and develop action plans; educational and social support | Households with a child aged 4 to 12 years with asthma, household income less than 200% of poverty or Medicaid enrollment | NR | • Sociodemographic data | NR | No
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | • Medication compliance | | [underlined: Measures:]
National Institutes of Environmental Health Sciences; CDC | | NR | NR | Nonprobability selection: eligible parents recruited through clinics, government and community agencies, and other outreach efforts | Surveys and observation | • Smoking | | Yes
[underlined: Funding Period:] | | [underlined: Setting:] | | [underlined: Sample Size:] | | • Household resources to control asthma | | Draft questions were discussed with Project Advisory Board
NR | | King County, Washington | | Planned: 300 | | • Caregiver knowledge | | [underlined: Recruitment:]
[underlined: Study Name:] | | | | Reported: 155 | | | | Yes
Seattle King County Healthy Homes Project | | | | [underlined: Response Rate at Each Measure:] | | | | Community agencies and churches participated in recruitment
| | | | 85% (n = 131) | | | | [underlined: Intervention:]
| | | | [underlined: Retention Rate:] | | | | NR
| | | | NA | | | | [underlined: Dissemination:]
| | | | | | | | NR
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | NR

Evidence Table 2. Seattle King County Healthy Homes Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Krieger JW, Song L, et al., 2000 | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | No | No | [underlined: Dissemination of Findings:]
| NR | Survey questions were revised after discussion with Project Advisory Board | | Yes | | | No
| [underlined: Nature of Community Involvement:] | | | Sociodemographics, income, insurance coverage, household composition | | | [underlined: Application of Findings:]
| • Recruitment and retention | | | [underlined: Addressed:] | | | No
| • Measurement instruments and data collection | | | Yes | | | [underlined: Sustainability of Interventions:]
| | | | Social support and provision of anti-allergic materials | | | No

Evidence Table 2. Seattle Vaccine: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Krieger JW, Castorina JS, et al., 2000 | To develop and evaluate a Senior Center-based program to increase influenza and pneumococcal immunization rates | RCT | A specially designed educational brochure was mailed along with a postage-paid reply card to track immunization status | Seniors ≥ 65 years old | • Proportion of individuals reporting receipt of influenza immunization during the study period | Changes in knowledge, attitudes, and perceived barriers related to immunizations and participant appraisal of the intervention | Pneumococcal (P < 0.001) and influenza (P < 0.0001) immunization rates increased more in the intervention group and among participants of the intervention group who did not receive a vaccine in the previous year | No
[underlined: Funder:] | | [underlined: Duration of Study:] | If response card not received, Senior Center volunteers made telephone contact using a script to encourage receipt of immunizations and to address specific barriers to immunization | [underlined: Sampling Strategy:] | • Proportion of individuals reporting receipt of pneumoccal immunization during study period among individuals reporting never having received a pneumoccal vaccine | Also performed a cost analysis of vaccine-promotion activities | Personal contact for isolated seniors, increased capacity of a senior center to conduct health-promotion activities, training of community members in research methods, providing an opportunity for the senior volunteers to feel useful and to make a valuable contribution to their community, and creating linkages between public institutions, private agencies, and community members | [underlined: Measures:]
CDC, United Way of King County | | NR | [underlined: Duration of Intervention:] | Subjects identified by Senior Center membership and marketing database | [underlined: Data Collection Methods:] | | | No
[underlined: Funding Period:] | | [underlined: Setting:] | 6 weeks | • All potential subjects sent recruitment letter and baseline survey | Quantitative: Surveys | | | [underlined: Recruitment:]
NR | | Seattle Senior Center | | • All who returned the surveys and were eligible were enrolled | | | | Self-selection of participants could diminish research quality
[underlined: Study Name:] | | | | [underlined: Sample Size:] | | | | [underlined: Intervention:]
Seattle Vaccine | | | | 1,246 | | | | No
| | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Dissemination:]
| | | | Intervention: 530/622 | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | Control group: 553/624 | | | | No
| | | | [underlined: Retention Rate:]
| | | | NR

Evidence Table 2. Seattle Vaccine: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Krieger JW, Castorina JS, et al., 2000 | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | No | Yes | [underlined: Dissemination of Findings:]
| NR | Community members involved in focus groups conducted to develop the protocol for the intervention. | | Yes | | Increased capacity of Senior Center to conduct health-promotion activities | No
| [underlined: Nature of Community Involvement:] | | | Demographic data were collected | | Training of community members in research methods; providing opportunity for senior volunteers to feel useful and to make a valuable contribution to their community | [underlined: Application of Findings:]
| • Study design | | | [underlined: Addressed:] | | Creating linkages between public institutions, private agencies, and community members | No
| • Recruitment and retention | | | No | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | No

Evidence Table 2. TEAL: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Kegler MC, Malcoe LH, et al., 2000 | To design, implement, and examine the effectiveness of the project in | Quasi-experimental | Only for Native Americans; 40 lay health advisors who disseminate information through their social networks | Native American (intervention) and white (control) residents with a child aged 1 to 6 | Blood lead level | • Basic social network information | NR (ongoing study) | No
[underlined: Funder:] | • Reducing the prevalence of elevated blood lead levels in Native American children | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Interviews:] | • Food frequency questionnaire | | [underlined: Measures:]
National Institute of Environmental Health Sciences | • Inducing sustainable behavioral changes | NR | NR (ongoing study) | Probability: Random sampling (city blocks and residences were randomly selected) | • Health beliefs | • Sociodemographic factors | | No
[underlined: Funding Period:] | • Changing health beliefs to support preventive behaviors | [underlined: Setting:] | | [underlined: Sample Size:] | • Knowledge | | | [underlined: Recruitment:]
NR | • Enhancing the capacity of the Native American community to address environmental lead exposure | Ottawa County, Oklahoma | | Blood samples: | • Lead exposure | | | Yes
[underlined: Study Name:] | | | | Native American: 144 | • Risk factors | | | Researchers hired local residents as canvassers, interviewers, and screening coordinators
Tribal Efforts Against Lead (TEAL) | | | | White: 187 | • Preventive behaviors | | | [underlined: Intervention:]
| | | | Structured interviews with: | [underlined: Data Collection Methods:] | | | Yes
| | | | Caregivers: 332 | • Blood samples | | | Community Advisory Board (CAB) developed training manual for lay health advisors
| | | | Tribal decisionmakers: 23 | • Structured interviews | | | [underlined: Dissemination:]
| | | | Environmental assessments: 245 | • Environmental assessments | | | No
| | | | Survey: NR | • Survey | | | [underlined: Outcomes:]
| | | | [underlined: Response Rate at Each Measure:] | | | | No
| | | | 60.2% (overall)
| | | | [underlined: Retention Rate:]
| | | | NA

Evidence Table 2. TEAL: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Kegler MC, Malcoe LH, et al., 2000 | [underlined: Duration:] | Yes | Yes | [underlined: Assessed]: | Yes | Yes | [underlined: Dissemination of Findings:]
| NR | CAB was established prior to the baseline assessment and provided guidance and direction to the project | Lay health advisors received a monthly stipend of $150, participants received a $15 gift certificate | Yes | Intervention was modeled along the concept of a clan mother; lay health advisors called themselves the “Society of Clan Mothers and Clan Fathers” | Project created jobs for the community and provided residents with research skills that might be transferred to other job settings | Researches presented assessment data to the CAB to gain insight and to distribute information to the tribes
| [underlined: Nature of Community Involvement:] | | | Caregiver survey assessed sociodemographic data | | Each tribe received HEPA vacuums | [underlined: Application of Findings:]
| • Recruitment and retention | | | [underlined: Addressed:] | | | Yes
| • Measurement instruments and data collection | | | No | | | CAB developed an action plan to face the long-term environmental lead problem
| • Intervention development, implementation | | | | | | [underlined: Sustainability of Interventions:]
| • Interpretation of findings | | | | | | No
| • Dissemination of findings
| • Application of findings to health concern identified

Evidence Table 2. East Side Village Health Worker Partnership: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Schulz AJ, Parker EA, et al., 1998* | • To identify stressors and protective factors that contribute to poor health outcomes for women and children | Nonexperimental | 30 lay health advisers (Village Health Workers) focused on increasing the problem-solving capacity of their community to reduce stressors or increase protective factors: | Survey: | • Stressors | • SES | NR | No
van Olphen J, Schulz A, et al., 2003 | • To assess community concerns and resources to guide the intervention | [underlined: Duration of Study:] | Informational support | Women aged 18 and older with the responsibility of child care for 5 hours a week or more | • Protective factors | • Religion/ spirituality | (intervention ongoing) | [underlined: Measures:]
Becker AB, Israel BA, et al., 2002 | • To gather baseline data | NR | • Information on health-related topics and resources | In-depth interviews: Residents who were actively engaged in the community and were selected as Village Health Workers (VHWs) | • Social support | • Neighborhood ties | | Yes
Israel BA, Farquhar SA, et al., 2002 | • To develop and evaluate a lay health advisor intervention aimed at reducing stressors, strengthening protective factors, and enhancing health | [underlined: Setting:] | Emotional support | Focus group interviews | • General health | | | Steering Committee helped to identify stressors
Schulz AJ, Parker EA, et al., 2002 | | East Side Village, Detroit | • Grief support program entitled You Are Not Alone (YANA) | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | | [underlined: Recruitment:]
Parker EA, Lichtenstein RL, et al., 2001 | | | Instrumental support | Surveys: | Quantitative: | | | Yes
Schulz AJ, Israel BA, et al., 2001 | | | • Providing transportation to clinics, helping to locate food, organizing and implementing health fairs | 2-stage simple random sample of 2,800 out of 6,124 blocklisted households bounded by 4 major streets and then random selection from eligible individuals within households | • Cross-sectional face-to-face surveys | | | Steering Committee selected and trained interviewers to administer the surveys
Schulz AJ, Israel BA, et al., 2000 | | | • Creating new resources | [underlined: Sample Size:] | Qualitative: | | | [underlined: Intervention:]
Parker EA, Schulz AJ, et al., 1998 | | | - YANA | Survey: 865 | • In-depth interviews with VHWs | | | Yes
Schulz AJ, Israel BA, Becker AB, et al., 1997 | | | - Village Voice newsletter | In-depth interviews: 48 | • Observations by committee members | | | Findings of survey were used to guide the intervention
[underlined: Funder:] | | | Organized change efforts and participated in other efforts | Focus groups: NR | • Focus group interviews | | | [underlined: Dissemination:]
CDC | | | • Community law enforcement and neighborhoods work on arson prevention, abandoned vehicle removal, and monitoring food safety in local food stores | [underlined: Response Rate at Each Measure:] | | | | Committee members served as coauthors, developing and distributing the report to the community
[underlined: Funding Period:] | | | Educating state legislators to influence policies and programs | 81% (n = 700) | | | | [underlined: Outcomes:]
1995-2003 | | | • Helped to reestablish smoking cessation program funding through letter-writing campaign | [underlined: Retention Rate:] | | | | No
[underlined: Study Name:] | | | [underlined: Duration of Intervention:] | NA
East Side Village Health Worker Partnership | | | NR

* Primary article for this study

Evidence Table 2. East Side Village Health Worker Partnership: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Schulz AJ, Parker EA, et al., 1998* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
van Olphen J, Schulz A, et al., 2003 | 1995-2003 (8 years) | Steering Committee developed survey and selected intervention sites | • Questionnaire was pretested and revised by the Steering Committee | Yes | Researchers agreed to implement intervention sooner than intended after renegotiations with the Steering Committee | • VHWs received training and a honorarium | Yes
Becker AB, Israel BA, et al., 2002 | [underlined: Nature of Community Involvement:] | | • On Steering Committee's suggestion, respondents were given a copy of the local resource directory and a small gift certificate | Sociodemographics | | • East Side Village Health Workers Partnership (ESVHWP) obtained a small grant to train VHWs about diabetes | Steering Committees evaluated and discussed findings; results were discussed at regularly scheduled meeting, special community events, and Partnership retreats
Israel BA, Farquhar SA, et al., 2002 | • Study design | | • Community interviewers were able to encourage community members to participate | [underlined: Addressed:] | | • Detroit Health Department established formal links with YANA to address violence in the community and committed ongoing funding support | [underlined: Application of Findings:]
Schulz AJ, Parker EA, et al., 2002 | • Recruitment and retention | | | Yes | | • Community members hired and trained as interviewers | Yes
Parker EA, Lichtenstein RL, et al., 2001 | • Measurement instruments and data collection | | | Local minimarkets held at community establishments offered fruits and vegetables at lower prices | | | Findings of survey were used to guide the intervention
Parker EA, Schulz AJ, et al., 2001 | • Intervention development, implementation | | | | | | [underlined: Sustainability of Interventions:]
Schulz AJ, Israel BA, et al., 2001 | • Interpretation of findings | | | | | | No
Schulz AJ, Israel BA, et al 2000 | • Dissemination of findings | | | | | | Intervention ongoing
Parker EA, Schulz AJ, et al., 1998 | • Application of findings to health concern identified

* Primary article for this study

Evidence Table 2. Elderly in Need: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Moyer A, Coristine M, MacLean L, et al., 1999 | To assess needs and design and test interventions to integrate them into the community | Nonexperimental, exploratory | • Individual interventions through public health nurses focusing on empowering the client | Elderly persons (>75 years), living alone and not receiving nursing services | • Physical Self Maintenance Scale | • Social support | Effectiveness of the intervention was not assessed | No
Moyer A, Coristine M, Jamault M, et al., 1999 | | [underlined: Duration of Study:] | • Interventions on community levels to increase outreach to elderly residents | [underlined: Sampling Strategy:] | • Instrumental Activities of Daily Living | • Social ties | [underlined: Study results:] | [underlined: Measures:]
[underlined: Funder:] | | 3 years | [underlined: Duration of Intervention:] | Nonprobability | [underlined: Data Collection Methods:] | | • Profile of older people in need | No
Ottawa Carlton Health Department, Community Health Research Unit | | [underlined: Setting:] | 3 years | [underlined: Sample Size:] | Quantitative: Functional capacity | | • 3 patterns of inadequate social networks | [underlined: Recruitment:]
[underlined: Funding Period:] | | French-speaking area, Canada | | 101 | Qualitative: Field notes, semistructured interviews | | | No
NR | | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention:]
[underlined: Study Name:] | | | | 92 | | | | No
Elderly In Need | | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination:]
| | | | NR | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No

Evidence Table 2. Elderly in Need: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Moyer A, Coristine M, MacLean L, et al., 1999 | [underlined: Duration:] | NR | No | [underlined: Assessed]: | Yes | Yes | [underlined: Dissemination of Findings:]
Moyer A, Coristine M, Jamault M, et al., 1999 | 3 years | | | No | All visits were conducted in the clients' language of choice | Project team provided skill training workshop for church volunteers | No
| [underlined: Nature of Community Involvement:] | | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
| • Recruitment and retention | | | No | | | No
| • Intervention development, implementation | | | | | | [underlined: Sustainability of Interventions:]
| | | | | | | No

Evidence Table 2. Haida Gwaii Diabetes Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Herbert, 1996 | Develop culturally sensitive approaches to the prevention and management of diabetes in the Haida people and implement these approaches while monitoring quantitative and qualitative outcomes | NR | NR, except for 2 examples: a walking group, and a group to gather traditional foods | NR | NR | NR | NR | NR
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | (not specifically reported, but appears to be the entire population of both villages) | [underlined: Data Collection Methods:] | | | [underlined: Measures:]
British Columbia Health Research Foundation | | NR | 12 months | [underlined: Sampling Strategy:] | NR | | | Choice of diabetes as intervention target based on input from community health representatives (some topics, such as alcoholism, are “highly charged,” and might have resulted in community resistance)
[underlined: Funding Period:] | | [underlined: Setting:] | | NR | | | | [underlined: Recruitment:]
NR | | Two villages (Skidegate and Old Massett) with mostly aboriginal populations in the Queen Charlotte Islands/Haida Gwaii, British Columbia, Canada | | [underlined: Sample Size:] | | | | NR
[underlined: Study Name:] | | | | NR | | | | [underlined: Intervention:]
Haida Gwaii Diabetes Project | | | | [underlined: Response Rate at Each:] | | | | NR
| | | | NR | | | | [underlined: Dissemination:]
| | | | [underlined: Retention Rate:] | | | | NR
| | | | NR | | | | [underlined: Outcomes:]
| | | | | | | | NR

Evidence Table 2. Haida Gwaii Diabetes Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Herbert, 1996 | [underlined: Duration]: | Research team's working principles: | Yes | [underlined: Assessed:] | NA | Yes | [underlined: Dissemination of Findings:]
| NR | • All members of research team are equal partners | Working principles in shared decisionmaking column were established to relieve concerns of the CHRs regarding acting as intermediaries in another research project | No | | CHRs used focus groups as a tool to decide how to use other funds | Yes
| [underlined: Nature of Community Involvement:] | • All manuscripts reviewed by all members of team | | [underlined: Addressed:] | | | Community reviewed all publications and researchers agreed to publish results only if the community approved
| • Selection of research question | • Data belong to participants and will be returned to them | | No | | | [underlined: Application of Findings:]
| • Financial responsibility for grant funds | • Analyses discussed with community health representatives (CHRs) | | | | | No
| • Measurement instruments and data collection | • Analyses discussed with key community members | | | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | • If community opposes publication, results only reported to funding agency | | | | | Yes
| • Dissemination of findings | Health or social issues raised due to research will be addressed | | | | | Statements by community leaders of commitment to and belief in the value of research

Evidence Table 2. Healthy Home, Healthy Child: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Green L, Fullilove M, et al., 2002* | To develop, implement, and evaluate a community-wide intervention to increase awareness of environmental health hazards; these articles describe studies at the beginning and during the program | Nonexperimental | Community education campaign to increase local residents' awareness of environmental health threats and protective techniques | Focus groups: Residents with at least one child living in their home | No predefined variables specified | Focus groups tested the relevancy of 5 strategies to reduce the risk of exposure to environmental hazards to children | Not fully reported, but respondents had high levels of awareness of the health risks targeted by the campaign | No
Perera FP, Illman SM, et al., 2002 | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | Survey: Mothers between 18 and 35, mainly African American and Latinas | [underlined: Data Collection Methods:] | Survey assessed women's awareness of environmental health risks associated with the Healthy Home, Healthy Child campaign and protective actions they take to reduce the risks | [underlined: Results of Analysis:] | [underlined: Measures:]
Evans DT, Fullilove MT, et al., 2002 | | Focus groups: 12/1998 to 7/1999 | NR | [underlined: Sampling Strategy:] | Qualitative: Focus groups using an interview guide | | • Control environmental tobacco smoke | No
[underlined: Funder:] | | Survey: 8/1999 to 12/1999 | | Nonprobability | Quantitative: Survey | | • Eat balanced meals with family | [underlined: Recruitment:]
National Institute of Environmental Health Sciences | | [underlined: Setting:] | | Focus groups: Self selection, snowball sampling | | | • Prevent exposure to lead | No
US Environmental Protection Agency | | Northern Manhattan, South Bronx | | Survey: Convenience sampling | | | • Control pests safely | [underlined: Intervention:]
[underlined: Funding Period:] | | | | [underlined: Sample Size:] | | | • Fight drug and alcohol abuse | Yes
NR | | | | Focus groups: 103 | | | • Manage garbage properly | Findings of the focus groups shaped the intervention campaign
[underlined: Study Name:] | | | | Survey: 555 | | | • Join a clean air campaign | [underlined: Dissemination:]
Healthy Home, Healthy Child | | | | [underlined: Response Rate at Each Measure:] | | | | No
| | | | NR | | | | [underlined: Outcomes:]
| | | | [underlined: Retention Rate:] | | | | No
| | | | NA

* Primary article for this study

Evidence Table 2. Healthy Home, Healthy Child: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Green L, Fullilove M, et al., 2002* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Perera FP, Illman SM, et al., 2002 | NR | Focus group and survey results were discussed with the Community Advisory Board and shaped the focus of the intervention campaign | Participants were reimbursed for travel expenses and compensated for their time | Yes | Additional topics were added to the campaign (e.g., garbage, fighting drugs) due to concerns of the community | Researchers trained members of the Community Advisory Board | No
Evans D, Fullilove MT, et al., 2002 | [underlined: Nature of Community Involvement:] | | | Demographic information was obtained | | Cooperation and contact with researchers helped to dissolve some barriers to better health care in the community | [underlined: Application of Findings:]
| • Selection of research question | | | [underlined: Addressed:] | | | Yes
| • Recruitment and retention | | | No | | | Focus group and survey results were discussed with the Community Advisory Board and shaped the focus of the intervention campaign
| • Measurement instruments and data collection | | | | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | No
| • Application of findings to health concern identified

* Primary article for this study

Evidence Table 2. Kahnawake Schools Diabetes Prevention Project: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Macaulay AC, Paradis G, et al., 1997* | Program Objective: To decrease the future occurrence of Diabetes Mellitus, reduce high-fat diets, and increase physical activity | Nonexperimental exploratory | Elementary school-based program with a variety of activities to promote healthy lifestyles | Elementary school children grades 1 to 6 | • Variables that assess fitness and body composition | • Self efficacy | NR (only baseline data reported) | No
Potvin L, Cargo M, et al., 2003 | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy]: | • Eating habits | • Perceived parental support | | [underlined: Measures:]
Macaulay AC, Cross EJ, et al., 1998 | | 3 years | 3 years | Nonprobability: Convenience | • Physical activity patterns | | | Yes
Macaulay AC, Delormier T, et al., 1998 | | [underlined: Setting:] | | [underlined: Sample Size:] | [underlined: Data Collection Methods:] | | | Diminished research quality; researchers could not publish a comparison of data of intervention group with control group
McComber AM, Macaulay AC, et al., 1996 | | Montreal, Canada | | 458 | Quantitative: | | | [underlined: Recruitment:]
[underlined: Funder:] | | | | [underlined: Response Rate at Each Measure:] | • Survey | | | No
Health Canada, Quebec Ministry of Health and Social Services | | | | 87% | • Anthropometric measurements | | | [underlined: Intervention:]
[underlined: Funding Period:] | | | | [underlined: Retention Rate:] | | | | No
NR | | | | NR | | | | [underlined: Dissemination:]
[underlined: Study Name]: | | | | | | | | No
Kahnawake Schools Diabetes Prevention Project | | | | | | | | [underlined: Outcomes:]
| | | | | | | | No

* Primary article for this study

Evidence Table 2. Kahnawake Schools Diabetes Prevention Project: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Macaulay AC, Paradis G, et al., 1997* | [underlined: Duration:] | Community Advisory Board was involved throughout the study | Yes | [underlined: Assessed]: | Yes | Yes | [underlined: Dissemination of Findings:]
Potvin L, Cargo M, et al., 2003 | 3 years | A Code of Research Ethics was developed specifying the community as full partners in all aspects of the research | Incentives provided for teachers and classes to participate | No | Intervention incorporated traditional learning styles of Native children | Project members have successfully lobbied for a change in school nutrition policies | Yes
Macaulay AC, Cross EJ, et al., 1998 | [underlined: Nature of Community Involvement:] | | | [underlined: Addressed:] | Project team agreed not to make comparisons of raw data between intervention and control groups | Project allowed the community to develop knowledge and expertise | Project team disseminated findings to the community and at scientific conferences
Macaulay AC, Delormier T, et al., 1998 | • Selection of research question | | | No | | Academic researchers obtained opportunities for masters' and post-doctoral training | [underlined: Application of Findings:]
McComber AM, Macaulay AC, et al., 1996 | • Proposal development | | | | | | No
| • Financial responsibility for grant funds | | | | | | [underlined: Sustainability of Interventions:]
| • Study design | | | | | | The project sustained itself past initial funding and identified and obtained additional funding
| • Recruitment and retention
| • Measurement instruments and data collection
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified

* Primary article for this study

Evidence Table 2. La Vida: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Maciak BJ, Guzman R, et al. 1999 | Description of a community-based participatory project | Nonexperimental, exploratory | Not specified | La Vida partners | No predefined variables specified | No predefined variables specified | NA | No
[underlined: Funder:] | [underlined: Project Objective:] | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | [underlined: Results of Analysis:] | [underlined: Measures:]
CDC | • To establish a partnership to prevent intimate partner violence | NR | Planned: 5 years | Nonprobability: Purposive sampling | Qualitative: | | Challenges identified: | NA
[underlined: Funding Period:] | • To collect, analyze, and disseminate information on intimate partner violence | [underlined: Setting:] | | [underlined: Sample Size:] | • Individual interviews | | • Maintaining ownership within the Latino community | [underlined: Recruitment:]
NR | • To develop, implement and evaluate prevention and intervention activities building on local knowledge and contributing to community capacity | Southwest Detroit | | Individual interviews: 15 | • Group interviews | | • Lack of trust and respect | NA
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | • Field notes | | • Striking a balance between research and action | [underlined: Intervention:]
La Vida | | | | NR | • Content analysis | | • Lack of knowledge about cultural differences | NA
| | | | [underlined: Retention Rate:] | | | • Lack of funding for development activities | [underlined: Dissemination:]
| | | | NA | | | Lessons learned: | No
| | | | | | | • Maintaining ownership with local communities is essential | [underlined: Outcomes:]
| | | | | | | • Strong and stable leadership within communities is critical | No
| | | | | | | • Community partners must demonstrate a long-term commitment
| | | | | | | • Community diagnosis can help to understand history and cultural context
| | | | | | | • CBPR efforts must be culturally competent

Evidence Table 2. La Vida: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Maciak BJ, Guzman R, et al., 1999 | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| At the time the article was written: 2 years | Initially a group of community partners made up a community action group to provide oversight; as their commitment grew and their roles evolved, they called themselves first a task force and later a partnership | Lead agency director sought support from other agency directors to deal with factors that hampered earlier attempts to address intimate partner violence | No | Researchers ensured that the initiative remained community owned by approaching agencies with Latino leadership and/or experience working with Latina women | Community members received training to serve as cofacilitators for group discussions | Yes
| Planned: 5 years | La Vida partners developed the framework for identifying Intimate Partner Violence (IPV) prevention and intervention activities | | [underlined: Addressed:] | | | Major themes of the analysis were discussed and revised by participants in the partnership
| [underlined: Nature of Community Involvement:] | | | No | | | [underlined: Application of Findings:]
| • Selection of research question | | | | | | No
| • Recruitment and retention | | | | | | [underlined: Sustainability of Interventions:]
| • Measurement instruments and data collection | | | | | | NA

Evidence Table 2. Mom Empowerment, Too!: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Baldwin JH, Rawlings A, et al., 1999 | To identify perceptions and behaviors of participants before and during the ME2 program | Nonexperimental | Participatory educational and support program involving a workshop with 16 group sessions, home visits, and case management (support, resource referrals, information); expected outcome of the intervention not clearly stated | Substance-abusing single or teen mothers | Content analysis of sessions suggested 2 major domains: | Participants described the worst and best of their lives before and during the program | Participants were able to articulate areas of growth in taking responsibility, learning to trust, and achieving some degree of success in their daily lives, but explicitly reported as an outcome of the program | No
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | • Risk perceptions and behaviors | | | [underlined: Measures:]
Brigham Young University College of Nursing, Research and Scholarship Committee | | NR | NR | NR | • Health-promoting perceptions and behaviors | | | No
[underlined: Funding Period:] | | [underlined: Setting:] | | [underlined: Sample Size:] | [underlined: Data Collection Methods:] | | | [underlined: Recruitment:]
NR | | Utah | | 42 | Qualitative: focus groups | | | No
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention:]
Mom Empowerment, Too! (ME2) | | | | NA | | | | Yes
| | | | [underlined: Retention Rate:] | | | | Mutual evaluation of workshops resulted in better supported program outcomes (no details provided)
| | | | NA | | | | [underlined: Dissemination:]
| | | | | | | | Yes
| | | | | | | | Participants reviewed the data
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | NA

Evidence Table 2. Mom Empowerment, Too!: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Baldwin JH, Rawlings A, et al., 1999 | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| NR | ME2 women collaborated to determine reality-based outcomes for the group (no details provided) | Age-appropriate activities were provided for children of participants to support the discussions their parents were having in the adult workshops | Yes | Mutual evaluation of workshops resulted in better supported program outcomes (no details provided) | Women reported areas of growth in taking responsibilities in their daily lives | Yes
| [underlined: Nature of Community Involvement:] | | | [underlined: Addressed:] | | | Participants reviewed the data
| • Recruitment and retention | | | Yes | | | [underlined: Application of Findings:]
| • Measurement instruments and data collection | | | Program provided information about medical care, shelter, basic needs | | | No
| • Intervention development, implementation | | | | | | [underlined: Sustainability of Findings:]
| • Interpretation of findings | | | | | | No
| • Dissemination of findings

Evidence Table 2. Nuclear Risk Management for Native Communities: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Quigley D, Handy D, et al., 2000 | To build community capacity for managing the health risks of nuclear contamination | Nonexperimental | Educational activities (workshops, presentations) | Native Americans | No predefined variables specified | No predefined variables specified | NA | No
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | [underlined: Results of Analysis:] | [underlined: Measures:]
National Institute of Environmental Health Sciences | | NR | NR | Nonprobability | Qualitative: | | No themes reported | No
Agency for Toxic Substances and Disease Registry | | [underlined: Setting:] | | [underlined: Sample Size:] | • Interviews | | | [underlined: Recruitment:]
[underlined: Funding Period:] | | Nevada, Utah, Southern California | | 71 interviews | • Content analysis of interviews | | | No
NR | | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention:]
[underlined: Study Name:] | | | | NR | | | | NA
The Nuclear Risk Management for Native Communities Project | | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination:]
| | | | NA | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No

Evidence Table 2. Nuclear Risk Management for Native Communities: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Quigley D, Handy D, et al., 2000 | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| NR | Community Advisory Committee was recruited for shared decisionmaking | | No | Researchers shared grant with Citizen Alert Native American Program (CANAP) to enable it to hire staff | • Development of new training and occupational opportunities for native community members | Yes
| [underlined: Nature of Community Involvement:] | Funding was shared between the CBO and the researchers | | [underlined: Addressed:] | | • Strengthening of the CANAP organizational stability through additional income and capacity | Community was involved in all levels of the program
| • Selection of research question | | | No | | • Researchers learned about native communities | [underlined: Application of Findings:]
| • Financial responsibility for grant funds | | | | | | Yes
| • Recruitment and retention | | | | | | Community-based hazard management plan was developed
| • Measurement instruments and data collection | | | | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | No
| • Interpretation of findings
| • Dissemination of findings
| • Application of findings to health concern identified

Evidence Table 2. PACE: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Arcury TA, Austin CK, et al., 1999* | To develop, implement, and disseminate culturally appropriate interventions to reduce chemical exposure among farm-workers | Nonexperimental formative research followed by planned intervention evaluated by RCT | • Training package for pesticide safety | Farm workers employed in tobacco and cucumber production | No predefined variables specified | No predefined variables specified | NR | No
Quandt SA, Arcury TA, et al., 2001 | | [underlined: Duration of Study:] | • Health promoter workshops | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | During interviews farmworkers described their experiences with and beliefs about agricultural chemicals | [underlined: Results of analysis:] | [underlined: Measures:]
[underlined: Funder:] | | 4 years | [underlined: Duration of Intervention:] | Nonprobability | Qualitative: | | No themes reported | No
National Institute of Environmental Health Sciences | | [underlined: Setting:] | NR | Snowball sampling | | | | [underlined: Recruitment:]
[underlined: Funding Period:] | | East-central North Carolina | | [underlined: Sample Size:] | • In-depth interviews | | | No
4 years | | | | Interviews: 26 | • Focus groups | | | [underlined: Intervention:]
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | | | | Yes
Preventing Agricultural, Chemical Exposure in North Carolina Farmworkers (PACE) | | | | NR | | | | North Carolina Farmworkers' Project (NCFP) staff helped to develop an intervention that was practical and culturally appropriate
| | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination:]
| | | | NA | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | NA

* Primary article for this study

Evidence Table 2. PACE: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Arcury TA, Austin CK, et al., 1999* | [underlined: Duration]: | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Quandt SA, Arcury TA, et al., 2001 | 4 years | Initial interactions were through a community-based organization, but later evolved to take place through a Project Advisory Committee comprising farmworkers | Spanish translation and interpretation were a priority in all domains of participation | No | Researchers allowed time for socializing during meetings; face-to-face contact was very important for community members | Project Advisory Committee members acquired new skills and the organization has built its capacity to undertake future projects, learned to conduct focus groups and in-depth interviews and systematically analyze results; they developed skills for organizing farmworkers | Yes
| [underlined: Nature of Community Involvement:] | PACE staff modified the approach of using an onsite health promoter after input from farmworkers | Researchers looked beyond the community-based organization to expand the range of those participating | [underlined: Addressed:] | Transportation to meetings was arranged by NCFP staff members | | Project staff made presentations on Committee's meetings
| • Selection of research question | | | No | | | [underlined: Application of Findings:]
| • Proposal development | | | | | | No
| • Financial responsibility for grant funds | | | | | | [underlined: Sustainability of Interventions:]
| • Study design | | | | | | No
| • Recruitment and retention
| • Measurement instruments and data collection
| • Intervention development, implementation
| • Interpretation of findings
| • Dissemination of findings

Evidence Table 2. PINAH: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Eng E, Parker E, 1994 | Project objectives: | Program evaluation | • Health fairs | Key informants | No predefined variables specified | No predefined variables specified | NR | No
[underlined: Funder:] | • To improve health-promoting behaviors | [underlined: Duration of Study:] | • Clean-up campaigns | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | [underlined: Results of analysis:] | [underlined: Measures:]
Freedom from Hunger, Mississippi State Department of Health, Mississippi Cooperative Extension Agency | • To improve outreach and referral patterns of local health and human service agencies | NR | • Teen pregnancy | Nonprobability: Purposive | Qualitative: Interviews | | Community competence moved from social interactions internal to communities to those more externally focused | No
[underlined: Funding Period:] | • To improve community competence | [underlined: Setting:] | • Drug awareness workshops | [underlined: Sample Size:] | | | | [underlined: Recruitment:]
5 years (1988-1993) | Study objective: Program evaluation of the third intervention (to improve community competence) | Mississippi Delta | [underlined: Duration of Intervention:] | 45 | | | | Yes
[underlined: Study Name:] | | | NR | [underlined: Response Rate at Each Measure:] | | | | Community Health Advisors selected key informants for interviews
The Partners for Improved Nutrition and Health Project (PINAH) | | | | NR | | | | [underlined: Intervention:]
| | | | [underlined: Retention Rate:] | | | | Yes
| | | | NA | | | | Community Health Advisors helped to interpret preliminary findings and fine-tune project activities
| | | | | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes]
| | | | | | | | No

Evidence Table 2. PINAH: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Eng E, Parker E, 1994 | [underlined: Duration:] | NR | No | [underlined: Assessed:] | No | Yes | [underlined: Dissemination of Findings:]
| 5 years | | | No | | Community Health Advisors drew up a written strategic plan and presented it to town officials although there was growing opposition from town officials | Yes
| [underlined: Nature of Community Involvement:] | | | [underlined: Addressed:] | | | Community Health Advisors received preliminary findings at periodic meetings with staff
| • Study design | | | Yes | | | PINAH evaluators sought validation of results through consultation with PINAH staff, Community Health Advisors, and PINAH's Board of Advisors
| • Recruitment and retention | | | Addresses community competence | | | [underlined: Application of Findings:]
| • Measurement instruments and data collection | | | | | | No
| • Intervention development, implementation | | | | | | [underlined: Sustainability of Interventions:]
| • Interpretation of findings | | | | | | No
| • Dissemination of findings

Evidence Table 2. Preventing Halloween Arson: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Determinants of Intervention Effects:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Maciak BJ, Moore MT, et al., 1998 | To describe and evaluate a citywide intervention to curtail arson fires during the Halloween period | Process evaluation | • Elimination of arson targets | City officials volunteers | Data on fires, arson fires, number of volunteers | No predefined variables specified | Overall decline of reported Halloween fires | No
[underlined: Funder:] | (This is a retrospective evaluation of a program implemented by city officials in cooperation with communities; researchers were not involved in the planning and implementation of the program) | [underlined: Duration of Study:] | • Deployment of public safety personnel | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | | [underlined: Measures:]
NR | | NR | • Youth curfew | Nonprobability: convenience | Archival data | | | No
[underlined: Funding Period:] | | [underlined: Setting:] | • Volunteer mobilization | [underlined: Sample Size:] | Qualitative: | | | [underlined: Recruitment:]
NR | | Detroit | • Activities for children and teenagers | NR | Interviews | | | No
[underlined: Study Name:] | | | • Media campaign | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention:]
Preventing Halloween Arson in an Urban Setting | | | [underlined: Duration of Intervention:] | NA | | | | Yes
| | | 1985-1996 | [underlined: Retention Rate:] | | | | Decentralized planning to ensure neighborhood relevance
| | | | NA | | | | [underlined: Dissemination:]
| | | | | | | | No
| | | | | | | | [underlined: Outcomes:]
| | | | | | | | No

Evidence Table 2. Preventing Halloween Arson: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Maciak BJ, Moore MT, et al., 1998 | [underlined: Duration:] | No | No | [underlined: Assessed:] | No | No | [underlined: Dissemination of Findings:]
| 11 years | | | No | | | No
| [underlined: Nature of Community Involvement:] | | | [underlined: Addressed:] | | | [underlined: Application of Findings:]
| • Intervention development, implementation | | | No | | | No
| | | | | | | [underlined: Sustainability of Interventions:]
| | | | | | | Yes
| | | | | | | Intervention is an ongoing program

Evidence Table 2. Survival Guide: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Factor SH, Galea S, et al., 2002* | To develop a guide to provide informational support for substance users to improve access to community services | Nonexperimental formative research followed by intervention, evaluated through an RCT | Survival guide for substance users to provide connections to treatment services | Substance users older than age 18 in East and Central Harlem | No predefined variables specified | No predefined variables specified | NA | No
Galea S, Factor SH, et al., 2002 | To gather information about substance users' perceptions of access to and information about services | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | Focus groups discussed the design and content of the survival guide | [underlined: Results of Analysis of Focus Groups:] | [underlined: Measures:]
[underlined: Funder:] | (An RCT is planned to determine the effectiveness of the intervention in improving knowledge and access to services; articles describe programs prior to the development of the survival guide) | 6 months | NR | Service providers: List of key informants provided by community liaison | Qualitative: Focus groups | | • Participants favored idea of a pocket-sized “survival guide” in bold colors and with forthright language | Survey instrument developed in collaboration with Community Advisory Board (CAB)
CDC | | [underlined: Setting:] | | Drug users: Convenience and snowball sampling | Quantitative: Surveys | | • Need for legal services | [underlined: Recruitment:]
[underlined: Funding Period:] | | East and Central Harlem | | [underlined: Sample Size:] | | | • Information about medical services | No
NR | | | | Service providers: 91 | | | • Information about job and educational opportunities | [underlined: Intervention:]
[underlined: Study Name:] | | | | Drug users: 353 | | | • Need for emotional support | Yes
NR | | | | [underlined: Response Rate at Each Measure:] | | | • Inspirational messages based on success stories | Substance users determined the content and appearance of the guide
| | | | Service providers: 25% | | | [underlined: Survey Results:] | [underlined: Dissemination:]
| | | | Drug users: NA | | | • 45% have difficulties accessing job services | No
| | | | [underlined: Retention Rate:] | | | • 35% have difficulties accessing housing services, 17% medical services, 10% education, 8% drug-related services | [underlined: Outcomes:]
| | | | NA | | | • Lack of information and too much paperwork were identified as main barriers | No

* Primary article for this study

Evidence Table 2. Survival Guide: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Factor SH, Galea S, et al., 2002* | [underlined: Duration:] | Yes | Yes | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
Galea S, Factor SH, et al., 2002 | NR | CAB contributed to identification of priorities and design of intervention | Focus group participants were reimbursed $20 for their time and were offered refreshments and free transportation | Yes | Initially the guide was targeting service providers; CAB members felt that the guide should be developed for substance users themselves; subsequently substance users determined the content and appearance of the guide | The involvement of substance users in the guide development gave them an opportunity to build social support | No
| [underlined: Nature of Community Involvement:] | | Survey participants were given $15 as compensation | Demographic characteristics were assessed in interviews | | | [underlined: Application of Findings:]
| • Selection of research question | | | [underlined: Addressed:] | | | Yes
| • Recruitment and retention | | | Not in formative phase (intervention will provide information on accessing services) | | | Results of surveys and focus groups were used for the design of the survival guide
| • Measurement instruments and data collection | | | | | | [underlined: Sustainability of Interventions:]
| • Intervention development, implementation | | | | | | No

* Primary article for this study

Evidence Table 2. Women and Heart Disease: Research Components

Authors, Funder, Funding Period, Study Name (If applicable) | Research Objectives | Study Design, Duration, Setting | Intervention, Duration | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate | Primary Outcome Variables Measured, Data Collection Methods | Other Variables Measured | Intended and Unintended Effects of Intervention | Evidence of Enhanced or Diminished Research Quality Due to CBPR
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other Variables Measured:] | [underlined: Intervention Effects:] | [underlined: Methodology:]
Arthur HM, Wright DM, et al., 2001 | To develop and implement a community-based communication and psycho-educational support group for women living with heart disease | Nonexperimental, exploratory | Telephone communication network, and monthly 2-hour group sessions | Women identified from daily hospital admission lists of patients who had MI, coronary artery bypass graft surgery, or percutaneous transluminal coronary angioplasty within the past 6 months or angina during the previous year | No predefined variables specified | • Evaluation of the telephone network | NR | No
[underlined: Funder:] | | [underlined: Duration of Study:] | [underlined: Duration of Intervention:] | Able to speak, read and understand English | [underlined: Data Collection Methods:] | • Diary entries about experiences living with heart disease both within and outside of the group | [underlined: Findings:] | [underlined: Measures:]
NR | | 1 year | 5 months | [underlined: Sampling Strategy:] | Qualitative: Focus groups | | • Identified a current deficit in both institutional and community-based health care in terms of dealing with women's issues related to living with heart disease | Participants generate issues being examined
[underlined: Funding Period:] | | [underlined: Setting:] | | Consecutive sample of women | | | • Telephone network difficult to use in practice | [underlined: Recruitment:]
NR | | Ontario, Canada | | [underlined: Sample Size:] | | | • Identified stress of living with heart disease and associated family pressures and the need for support and information related to heart disease, medical management, and communication with physicians as major issues | No
[underlined: Study Name:] | | | | 20 women: 10 in group 1 and 10 in group 2 | | | | [underlined: Intervention:]
Women and Heart Disease | | | | [underlined: Response Rate at Each Measure:] | | | | Participants codesigned the program that they thought would be of the most benefit to other women living with heart disease
| | | | NA | | | | [underlined: Dissemination:]
| | | | [underlined: Retention Rate:] | | | | No
| | | | Group 1: 9/10 | | | | [underlined: Outcomes:]
| | | | Group 2: 7/10 | | | | Summaries of sessions were provided to the women who were given the opportunity to accept, reject, or refine the investigators' interpretations

Evidence Table 2. Women and Heart Disease: Community-Based, Participatory Components

Authors | Duration and Nature of Community Involvement | Evidence of Shared Decisionmaking Between Researchers and the Community | Evidence That Study Is Designed to Remove Prior Barriers to Research Participation | Evidence That Socioeconomic Determinants of Health Are Addressed | Evidence That the Research Team Was Flexible to Community Needs and Priorities During Research Implementation | Evidence That the Research Effort Contributed to Individual or Community Capacity Building | Evidence That the Research Findings Were Used or Intended to Be Used to Address the Original Health Concern
Arthur HM, Wright DM, et al., 2001* | [underlined: Duration:] | Yes | No | [underlined: Assessed:] | Yes | Yes | [underlined: Dissemination of Findings:]
| NR | Summaries of sessions were provided to the women who were given the opportunity to accept, reject, or refine the investigators' interpretations | | No | Participants codeveloped program that they thought would be most beneficial to women | Participants felt both supported and supportive during the group process; no evidence of community capacity building | Yes
| [underlined: Nature of Community Involvement:] | Participants codesigned the program that they thought would be of the most benefit to other women living with heart disease | | [underlined: Addressed:] | | | Findings were disseminated to participants who were given the opportunity to accept, reject, or refine the investigators' interpretations
| • Dissemination of findings | Consensus-driven issue identification continued throughout the monthly group meetings | | No | | | [underlined: Application of Findings:]
| • Intervention development, implementation | | | | | | The authors state that an ongoing community-based support group for women with heart disease may enhance coping, but no indication of continuation of the groups
| • Interpretation of findings | | | | | | [underlined: Sustainability of intervention:]
| | | | | | | No

* Primary article for this study