# Appendix B Sample Abstraction Forms/Quality Rating Forms

Sample Abstraction Form for Definition Articles

| Not specific | Identify issues And concerns | Study design And funding | Participant Recruitment and Retention | Measures And Data Collection | Intervention Design And Implementation | Data analysis, Interpretation And Dissemination | Partnership Structure
Essential Elements Of community Participation
Essential Elements Of research
Characteristics Of Best Practices
Expected outcomes From community Perspective
Expected outcomes From research Perspective

Draft Evidence Table Headings for Research Components | | | | | | | | | Draft Evidence Table Headings for Community-Based, Participatory Components
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | 15 | 16 | 17
Study ID, Authors,^a^ Funder, Funding Period, Study Name (If applicable) | Research Objectives^b^ | Study Design^c^, Duration, Setting^d^ | Intervention^e^ | Participants, Sampling Strategy, Sample Size, Response Rate, Retention Rate^f^ | Primary Outcome Variables Measured^g^ | Other Variables Measured^i^ | Intended and Unintended Effects of Intervention^j^ | Evidence of enhanced or diminished research quality due to CBPR^k^ | Study ID, Authors | Duration and Nature of Community Involvement^lm^ | Evidence of shared decision-making between researchers and the community^n^ | Evidence that study is designed to remove prior barriers to research participation^o^ | Evidence that socio-economic determinants of health are addressed^p^ | Evidence that the research team was flexible to community needs and priorities during research implementation^q^ | Evidence that the research effort contributed to individual or community capacity building^r^ | Evidence that the research findings were used or intended to be used to address the original health concern:
| | | | | Data Collection Methods^h^ | | | | | | | | | | | • dissemination of findings to participants
| | | | | | | | | | | | | | | | • application of findings to a health-related intervention or policy change^s^
| | | | | | | | | | | | | | | | • sustainability of research-related interventions in the community
[underlined: Publications:] | [underlined: Research Objective:] | [underlined: Study Design:] | [underlined: Intervention:] | [underlined: Participants:] | [underlined: Primary Variables Measured:] | [underlined: Other variables measured:] | [underlined: Intervention Effects:] | [underlined: Methodology]
[underlined: Funder:] | | [underlined: Duration:] | [underlined: Duration:] | [underlined: Sampling Strategy:] | [underlined: Data Collection Methods:] | | | [underlined: Measures]
[underlined: Funding Period:] | | [underlined: Setting:] | | [underlined: Sample Size:] | | | | [underlined: Recruitment]
[underlined: Study Name:] | | | | [underlined: Response Rate at Each Measure:] | | | | [underlined: Intervention]
| | | | [underlined: Retention Rate:] | | | | [underlined: Dissemination]
| | | | | | | | [underlined: Outcomes]

* Primary article for this study

a Should be first and second author, et al. if applicable, and year (i.e. Smith, Jones et al., 1995). Put a star against the major publication for this study (the one that reports findings for the major research question. If you are not sure which the major publication is, or if there appears to be more than one, make a note in this column so that the senior reviewer can make a decision. Add the names of all other publications for the study from which you draw information that enters the evidence table. For the date, list the years given. For punctuation, list each study of a set with space between.

b Check for differences in the research objectives across articles in sets. If there is a difference, make a notation of it here and mark in the article where the different statements occur.

c Report study design as given. For study design, include only design (i.e. quasi-experimental), not methodology (i.e. survey). Types of study designs are suggested in the table below. This is not an exhaustive guide - there are other variants and hybrid designs that this table does not cover - check with your senior reviewer if you have questions. Enter appropriate key words from columns 1 and 2 for study design, ie, type of design (1), type of design (2) and allocation of participants (e.g., quasi-experimental design, pre- and post-test measures, snowball sample). Enter additional notes if the study is an RCT, or if the allocation of the intervention differs from the selection of the intervention and control groups. Data collection methods may be qualitative and/or quantitative under any of these categories, but these are reported under column 6. Type of sampling (systematic, snowball, etc, is reported in column 5 under sampling strategy, but is included in the table below for clarification.

From Cook and Campbell 1979 (Quasi-experimentation), William Trochim's website on quasi-experimentation and numerous other websites.

d Describe the intervention as planned by researchers. Include length of intervention in this column.

e For duration, include duration of intervention here. Report setting as the geographical location (column 4) and participant information (column 5) as the community studied, with as much detail as possible for each.

f Report the sample size for each phase of measurement. Report the numerator and denominator with percentages when given. If the study reports a response rate, enter that information for each measure separately, ie, for baseline, follow-up 1, follow-up 2, etc. Report the retention rate between baseline and last measure.

g Report primary variables measured, as they relate to the research question.

h This is where to report methods such as telephone survey, focus groups, etc.

i These would be the other variables measured, perhaps during a phase of a study, or a subgroup, prevalence rates, demographics, knowledge, attitudes, etc. If the intervention is complete, and there is little relevant information in this column, you may just list the topics (race, income, etc).

In the case of completed interventions, this column should report variables that are theoretical determinants of the intervention effects, but are not the final outcome. (For instance, the intervention may be designed to cause changes in breast and cervical cancer screening rates, reported in Column 8. However, the intervention may have produced effects on knowledge and beliefs - theoretical determinants of screening rates - these should be reported in Column 7 for completed interventions).

If this is an incomplete intervention or an observational study, other variables are those related to the study objective. In this case, please provide sufficient detail on these findings to judge whether the objective was met.

j Intervention effects address the research question. Provide sufficient detail to assess whether the study has answered the research question. Include p values where relevant. Do include unintended effects of the intervention where reported. Also, if studies have analyzed the link between the theoretical determinants and the outcome, do include it here (for instance, among women in the intervention group, those whose beliefs changed were more likely to get screened by x%, as compared to y% in the non-intervention group).

k Includes methodology, measures, recruitment, intervention and dissemination, as well as outcomes. Where CBPR has resulted in changes in methodology, measures, recruitment, intervention or dissemination. Make notes so that the reviewer will know whether your entries are based upon the text in the articles or on inferences you have made regarding enhanced or diminished quality.

l Nature of Community Involvement (can list as 1–10 if applicable, otherwise list each number)-

1. Selection of research question
2. Proposal development
3. Financial responsibility for grant funds
4. Study design
5. Recruitment and retention
6. Measurement instruments and data collection
7. Intervention development, implementation
8. Interpretation of Findings
9. Dissemination of findings
10. Application of findings to health concern identified

m Both the intention of the researchers and the reality at end of study, if reported

n This is a “how” response- give information on the structure or mechanism of shared decision-making. This is different from nature of involvement because can have one without the other, and both should be reported if given. NR will be a more common response than No. Give as much detail as possible.

o Evidence of the researchers' efforts to remove barriers and the community's willingness to act as a partner. Should be yes/no and description of evidence, with as much detail as possible.

p Yes/No and description of evidence, with as much detail as possible. Note whether the socio-economic determinants of health were just assessed or addressed as well through the research or design of the intervention.

q Yes/No and description of evidence with detail.

r Yes/No and description of evidence with detail. Research effort includes duration and purpose of continued funding if provided. Separate ‘individual’ from ‘community’ if possible.

s Duration is the length of the relationship between partners if given.

TYPES OF STUDY DESIGNS

1 | 2 | 3 | 4
Type of design (1) | Type of design (2) | Allocation of participants to control and intervention | Additional notes of explanation
Experimental | Pre- and post-test measures | Probability sample - random allocation of treatment at baseline, same participants at baseline and follow-up | The key is the randomization of communities or individuals -this makes the intervention and control groups equivalent because all differences between the groups can be explained by chance. If the study is an RCT (randomized controlled trial), make a note of it. The participants may or may not be crossed over from one treatment group to another. Also make a note if it is a crossover trial.
| | Types of probability samples:
| | 1. Simple random sample - equal chance of getting selected.
| | 2. Systematic sampling- every nth person
| | 3. Stratified sampling - the population is divided into strata, from which further selection is done using either simple random sampling or systematic sampling.
| | 4. Multi-stage cluster - divide the area into progressively smaller areas, using a method of selection at each stage.
Experimental | Post-test measures only | Probability sample - random allocation of treatment at intervention | Sometimes prestest values cannot be measured, or do not make sense to measure - (e.g., measures before an emergency room visit when intervention is provided in the emergency room). Still requires random assignment to intervention and control groups
Quasi-experimental | Pre- and post-test measures | Non random allocation of treatment, same participants at baseline and follow-up. | All quasi-experimental designs lack random assignment. There are many different types - some are better able to address the nonequivalence of the groups than others. In this particular version, even though the treatment groups are nonequivalent (non-random allocation), the pretest measures account for differences between intervention and control groups before the intervention. Although the treatment (intervention vs. control) is non-randomly allocated, there may be studies in which the study groups are randomly selected (think Wai'anae). If so, note that the study participants are selected randomly, while the intervention is non randomly allocated. Random selection of study participants with non-random allocation of treatment can sometimes buy additional validity - see separate pre and post samples design below.
| | Types of non-probability samples
| | 1. Purposive, e.g., key informant surveys
| | 2. Quota, e.g., age/race/marital status samples
| | 3. Convenience, e.g., mall surveys
| | 4. Snowball, ie, participants refer others to study
| | 5. Self-selection, e.g., web polls
| | 6. Case-control (matched participants in intervention and control groups on key variables)
Quasi-experimental | Proxy Pretest and post-test (Proxy pretest based on recall, collected at post-test) | Non random allocation of treatment | Groups are non-equivalent, and measurement is conducted only at post-test. Pretest measures are collected at the same time, and often rely on recall. Although a flawed design for measuring ‘objective’ changes, this design works for tests of changes in participants' own perceptions.
Quasi-experimental | Regression Point Displacement (RPD) Design | Non random allocation of treatment, same participants at baseline and follow-up | This design is sometime used in community interventions. Instead of comparing the intervention community with a single control community, data are pooled from heterogeneous set of nonequivalent communities to model the comparison condition
Quasi-experimental | Separate Pre-Post Samples Design | Non-random allocation of treatment, different participants at baseline and follow-up. The strongest variant of this approach has random selection of pre and post test groups in each of the treatment groups. In other words, pre and posttest groups should be comparable, within the intervention group and within the control group. | Sometimes, when interventions are applied in the service setting, clients may cycle through the agency, making it difficult to recruit the same people for pre- and post-tests. In this design, the 4 groups are different (pretest intervention, pretest control, posttest intervention, posttest control)
Pre-experimental | One group post-test only | Non-random allocation of treatment | Note that this category has much stigma associated with it.
Pre-experimental | Post-test only for intervention and control groups | Non random allocation of treatment | This design relies on group differences alone to measure the effect of the intervention, and does not account for nonequivalence at baseline -this design is sometimes used when the intervention has been implemented before the research design is worked out.
Pre-experimental | One group pretest-posttest design | Non random allocation of treatment, same participants at baseline and follow-up | No control group